# Peer Reviewers

Peer Reviewers are invited to provide written comments on the draft report based on their clinical, content, or methodology expertise. Peer review comments on the preliminary draft of the report are considered by the EPC in preparation of the final draft of the report. Peer Reviewers do not participate in writing or editing of the final report or other products. The synthesis of the scientific literature presented in the final report does not necessarily represent the views of individual reviewers. The dispositions of the peer review comments are documented and will, for CERs and Technical briefs, be published 3 months after the publication of the Evidence Report.

Potential reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Invited Peer Reviewers may not have any financial conflict of interest greater than $10,000. Peer Reviewers who disclose potential business or professional conflicts of interest may submit comments on draft reports through the public comment mechanism.

- Melissa Brodowski, M.S.W., M.P.H.
  Office on Child Abuse and Neglect
  Children’s Bureau, ACYF, ACF, HHS
  Washington, DC
- Neal Boris, M.D.
  Tulane University
  New Orleans, LA
- Marylene Cloitre, Ph.D.
  New York University
  New York, NY
- Julian Ford, Ph.D.
  University of Connecticut Health Center
  Department of Psychiatry
  Farmington, CT
- Robert Franks, Ph.D.
  University of Connecticut Health Center
  Farmington, CT
- Malcolm Gordon, Ph.D.
  Emergency Mental Health and Traumatic Stress Services Branch
  Center for Mental Health Services
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Penelope Knapp, M.D.
  California Department of Mental Health
  Sacramento, CA