# Technical Expert Panel

Technical Experts comprise a multidisciplinary group of clinical, content, and methodologic experts who provide input in defining populations, interventions, comparisons, or outcomes as well as identifying particular studies or databases to search. They are selected to provide broad expertise and perspectives specific to the topic under development. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore study questions, design, and/or methodological approaches do not necessarily represent the views of individual technical and content experts. Technical Experts provide information to the EPC to identify literature search strategies and recommend approaches to specific issues as requested by the EPC. Technical Experts do not do analysis of any kind nor contribute to the writing of the report and have not reviewed the report, except as given the opportunity to do so through the peer or public review mechanism

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals are invited to serve as Technical Experts, and those who present with potential conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

- Melissa Brodowski, M.S.W., M.P.H.
  Office on Child Abuse and Neglect
  Children’s Bureau, ACYF, ACF, HHS
  Washington, DC
- Julian Ford, Ph.D.
  University of Connecticut Health Center
  Department of Psychiatry
  Farmington, CT
- Malcolm Gordon, Ph.D.
  Emergency Mental Health and Traumatic Stress Services Branch
  Center for Mental Health Services
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Brenda Jones Harden, Ph.D.
  Institute for Child Study
  Department of Human Development
  University of Maryland College Park
  College Park, MD
- Penelope Knapp, M.D.
  California Department of Mental Health
  Sacramento, CA
- John Landsverk, Ph.D.
  Child and Adolescent Services Research Center
  Rady Children’s Hospital of San Diego
  San Diego, CA
- Laurel Leslie, M.D., M.P.H.
  Associate Professor, Medicine and Pediatrics
  Tufts Medical Center Floating Hospital for Children
  Director, Center for Aligning Researchers and Communities for Health
  Tufts Clinical and Translational Science Institute
  Boston, MA