# Acknowledgments

The authors gratefully acknowledge the continuing support of our AHRQ Task Order Officer, Stephanie Chang, M.D., and that of the former Task Order Officer, Sonia Tyutyulkova, M.D., Ph.D. We extend our appreciation to our Key Informants and members of our Technical Expert Panel (listed below), all of whom provided thoughtful advice and input during our research process.

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at the RTI-UNC Evidence Based Practice Center. We express our gratitude to the following individuals for their contributions to this project: Leyla Stambaugh, Loraine Monroe, Jennifer Drolet, Susan Beck, Wallace Campbell, and Carol Woodell.