# Discussion

This chapter summarizes key findings and strength of evidence (SOE) for each key question (KQ), followed by a section on the applicability of the findings, a summary of the limitations of the comparative review process, limitations of the evidence base, and gaps in the evidence that may benefit from future research.

## Key Findings and Strength of Evidence

### Overview

Overall, the evidence from 24 trials (23 randomized and 1 nonrandomized controlled trial) and one cohort study (reported in 53 articles) included in this comparative effectiveness review (CER) provides preliminary support for a number of promising approaches for addressing child exposure to maltreatment. We categorized the array of interventions in the literature as parenting interventions, trauma-focused treatments, or enhanced foster care intervention approaches. Within and across these intervention types, approaches varied in treatment target, intensity, modality, and theoretical conceptualizations of therapeutic change. Most studies identified for this review were conducted in the United States and evaluated parenting interventions. In contrast, comparative studies of trauma-focused treatments were sparse, with three of seven trials focused on one intervention or an adaptation of that intervention.108,115,116 Our review also included five trials of enhanced foster care interventions; these approaches all were directed at the child—either alone or in combination with a caregiver component. With the exception of two interventions, KEEP and SafeCare, the body of evidence for interventions that addressed child well-being or child welfare outcomes in maltreated children was predominantly low strength of evidence or was insufficient to draw firm conclusions.

We acknowledge that the inclusion criterion of children with known CPS involvement or maltreatment may be considered a rarified approach by some. We recognize, as well, that this decision may have resulted in the exclusion of trials that, arguably, might bolster evidence for included interventions or support inclusion of other interventions with at least low strength of evidence. Our intent was threefold: (1) to reduce the noise of clinical heterogeneity that currently undermines the extant evidence base, (2) to maintain the rigorous approach for study inclusion that has been employed across AHRQ CERs, and (3) to avert yet more heterogeneity due to inconsistent, vague, or absent definitions of samples of children defined as ‘at risk’ or an admixture of ‘at risk’ and maltreated. As we attempted to follow these principles, we have striven for clarity about our decisions in order to better inform readers. With these perspectives in mind, we believe that this review makes a groundbreaking contribution to the field that challenges researchers, clinicians, and policymakers.

Given the apriori exclusions, our review illuminates major substantive and methodological gaps in the evidence and highlights critical areas for future research. To be fair, these gaps reflect the relatively new field of evidence-based mental health treatment provided in the context of the myriad and complex challenges of caring for maltreated children, engaging and retaining maltreating parents in treatment, and working within the parameters of the child welfare arena. Head-to-head studies are scarce, as are multiple or independent (i.e., tested by researchers unaffiliated with intervention developers) trials. Sample sizes are commonly very small. A gap in the literature with implications for widespread implementation is the issue of “dose” or how much of an intervention is needed to effect change. None of the included studies addressed this issue. With the exception of studies involving younger children, few interventions were designed for or studied efficacy or effectiveness within specific age or developmental ranges. Similarly, studies rarely took into consideration or elucidated findings as they related to maltreatment type, severity, chronicity, timing, and exposure to other traumatic experiences. Also underrepresented in the literature were intervention studies explicitly evaluating efficacy or effectiveness with the most vulnerable and challenging-to-serve families, that is, maltreated children whose biological parents were struggling with substance abuse, mental health problems, or domestic violence. In some instances, such families were intentionally excluded from a study sample.

### Key Question 1 Comparative Effectiveness of Interventions for Improving Child Well-Being Outcomes

The summary of results for KQ 1 is presented in Table 114. For KQ 1, we proposed four sets of outcomes representing key dimensions of child well-being: child mental and behavioral health, the quality of the caregiver-child relationship (e.g., child attachment, caregiver responsivity and sensitivity, positive parental attitudes toward childrearing), children’s development (e.g., cognition, language, physical maturation), and school-based functioning (e.g., grade retention, disciplinary referrals, attendance). Only three trials reported developmental outcomes, and we identified no studies eligible for inclusion that assessed school-based functioning. The body of evidence for interventions that addressed child well-being in maltreated children was predominantly low SOE or was insufficient to draw firm conclusions. As specified in the results section, low SOE was attributable to the presence of a small number of distinct trials; in some cases, the SOE also took into account inconsistent findings across outcomes, imprecise or nonstatistically significant results, and/or samples that resulted in underpowered analyses. The low SOE ratings represent an important limitation of the extant research and call into question the replicability and generalizability of results. At the same time, the ratings should be considered in light of the emerging status of this line of research and noteworthy barriers to the rigorous study of interventions for maltreated children.

Table 114 Summary strength of evidence KQ 1 and KQ 2

Type | Intervention (G1) | Comparison (G2) | Outcome | n Trials, Participants | Strength of Evidence; Magnitude of Effect
Parenting Interventions | Attachment and Biobehavioral Catch-up | Active control^a^ | Mental and behavioral health | 2^77,78,82,83^; 213 | Low; NR
Parenting Interventions | Attachment and Biobehavioral Catch-up | Active control^a^ | Healthy caregiver-child relationship | 2^79,81^; 166 | Low; NR
Parenting Interventions | Attachment and Biobehavioral Catch-up | Active control^a^ | Healthy development | 1^85^; 37 | Low; NR
Parenting Interventions | Attachment and Biobehavioral Catch-up | Wait list | Mental and behavioral health | 1^80^; 58 | Low; medium (Partial eta squared=0.436 or 0.511)
Parenting Interventions | Attachment and Biobehavioral Catch-up | Wait list | Healthy caregiver-child relationship | 1^80^; 58 | Low; medium or large (Partial eta squared=0.59 or 0.791)
Parenting Interventions | Attachment-based Intervention | Usual care | Mental and behavioral health | 1^86^; 79 | Insufficient
Parenting Interventions | Attachment-based Intervention | Usual care | Healthy caregiver-child relationship | 1^86^; 79 | Low; small to medium (d=0.47, r=0.36 or 0.37)
Parenting Interventions | Child-Parent Psychotherapy^b^ | Active control^a^ | Healthy caregiver-child relationship | 2^87,88^; 159 | Insufficient
Parenting Interventions | Child-Parent Psychotherapy^b^ | Usual care | Healthy caregiver-child relationship | 2^87,88^; 141 | Low; medium to large (h=0.64 to 1.34)
Parenting Interventions | Incredible Years CoParenting Adaptation | Usual care | Mental and behavioral health | 1^89^; 64 | Insufficient
Parenting Interventions | Incredible Years CoParenting Adaptation | Usual care | Healthy caregiver-child relationship | 1^89^; 64 | Low; small to medium (d=0.40 or 0.59)
Parenting Interventions | Keeping Foster and Kinship Parents Trained and Supported | Usual care | Mental and behavioral health | 1^91^; 700 | Moderate; small (d=0.26)
Parenting Interventions | Keeping Foster and Kinship Parents Trained and Supported | Usual care | Healthy caregiver-child relationship | 1^91^; 700 | Moderate; small (d=0.29)
Parenting Interventions | Keeping Foster and Kinship Parents Trained and Supported | Usual care | Placement stability | 1^91^; 700 | Insufficient
Parenting Interventions | Keeping Foster and Kinship Parents Trained and Supported | Usual care | Permanency | 1^91^; 700 | Moderate; NR
Parenting Interventions | Nurse-Home Visitation Intervention | Usual care | Mental and behavioral health | 1^93^; 163 | Insufficient
Parenting Interventions | Nurse-Home Visitation Intervention | Usual care | Healthy caregiver-child relationship | 1^93^; 163 | Insufficient
Parenting Interventions | Nurse-Home Visitation Intervention | Usual care | Safety | 1^93^; 163 | Insufficient
Parenting Interventions | PCIT Adaptation Package | PCIT Adaptation Package enhanced^c^ | Safety | 1^96^; 75 | Insufficient
Parenting Interventions | PCIT Adaptation Package | Usual care | Safety | 2^95,96^; 153 | Low; NR^d^
Parenting Interventions | PCIT Adaptation Package enhanced^c^ | Usual care | Safety | 1^96^; 88 | Insufficient
Parenting Interventions | SafeCare | Usual care | Safety | 1^100^; 2,175 | Moderate; HR=0.74 to 0.83
Parenting Interventions | Videotape Intervention | Control videotape | Mental and behavioral health | 1^101^; 30 | Insufficient
Parenting Interventions | Videotape Intervention | Control videotape | Healthy caregiver-child relationship | 1^101^; 30 | Insufficient
Trauma-Focused Treatments | Combined Parent-Child Cognitive Behavioral Therapy | Active control^a^ | Mental and behavioral health | 1^107^; 75 | Low; medium (d=0.61)
Trauma-Focused Treatments | Combined Parent-Child Cognitive Behavioral Therapy | Active control^a^ | Healthy caregiver-child relationship | 1^107^; 75 | Insufficient
Trauma-Focused Treatments | Eye Movement Desensitization and Reprocessing | Active control^a^ | Mental and behavioral health | 1^112^; 14 | Insufficient
Trauma-Focused Treatments | Group Psychotherapy for Sexually Abused Girls | Active control^e^ | Mental and behavioral health | 1^113^; 71 | Low (G1<G2); small to medium (d=0.36 to 0.79)
Trauma-Focused Treatments | Group Treatment Program for Sexual Abuse | Inactive control | Mental and behavioral health | 1^114^; 30 | Low; NR
Trauma-Focused Treatments | Trauma-Focused Cognitive Behavioral Therapy | Active control^f^ | Mental and behavioral health | 2^108,115^; 315 | Low; small to medium (d=0.30 to 0.70)
Trauma-Focused Treatments | Trauma-Focused Cognitive Behavioral Therapy | Active control^f^ | Healthy caregiver-child relationship | 1^108^; 229 | Low; small to medium (d=0.38 or 0.57)
Trauma-Focused Treatments | Trauma-Focused Cognitive Behavioral Therapy Group Adaptation | Active control^e^ | Mental and behavioral Health | 1^116^; 44 | Insufficient
Trauma-Focused Treatments | Trauma-Focused Cognitive Behavioral Therapy Group Adaptation | Active control^e^ | Healthy caregiver-child relationship | 1^116^; 44 | Insufficient
Enhanced Foster Care Interventions | Bucharest Early Intervention Project | Usual care (institutional care in Romania) | Mental health and behavior | 1^118,120,123,125,129; 136^ | Low; Odds ratio 2.8 [95%CI 1.2 to 6.4]
Enhanced Foster Care Interventions | Bucharest Early Intervention Project | Usual care (institutional care in Romania) | Healthy caregiver-child relationship | 1^121,125,127^; 136 | Low; NR
Enhanced Foster Care Interventions | Bucharest Early Intervention Project | Usual care (institutional care in Romania) | Healthy development | 1^117,119,121,122,124,126,128^; 136 | Low; effect size^g^ =0.47 or 0.62
Enhanced Foster Care Interventions | Fostering Healthy Futures | Inactive control | Mental and behavioral health | 1^131^; 156 | Low; small to medium (d=0.30 to 0.51)
Enhanced Foster Care Interventions | Fostering Healthy Futures | Inactive control | Placement stability | 1^132^; 110 | Low; OR=0.18 to 0.56
Enhanced Foster Care Interventions | Fostering Healthy Futures | Inactive control | Permanency | 1^132^;110 | Low; OR=5.14
Enhanced Foster Care Interventions | Middle School Success | Usual care | Mental health and behavior | 1^136,137^; 100 | Low; small to medium (d=0.35 to 0.57)
Enhanced Foster Care Interventions | Middle School Success | Usual care | Placement stability | 1^136^; 100 | Low; medium (d=0.50)
Enhanced Foster Care Interventions | Multi-dimensional Treatment Foster Care for Preschoolers | Usual care | Mental health and behavior | 1^142,179^; 117 | Low; medium (d=0.64 to 0.68)
Enhanced Foster Care Interventions | Multi-dimensional Treatment Foster Care for Preschoolers | Usual care | Healthy caregiver-child relationship | 1^139,141^; 117 | Low; NR
Enhanced Foster Care Interventions | Multi-dimensional Treatment Foster Care for Preschoolers | Usual care | Healthy development | 1^138^; 23 | Low; NR
Enhanced Foster Care Interventions | Multi-dimensional Treatment Foster Care for Preschoolers | Usual care | Permanency | 1^140,143^; 90 | Low; NR
Enhanced Foster Care Interventions | New Orleans Intervention | Usual care | Safety | 1^130^; 255 | Low; RRR=0.67 to 0.75
Enhanced Foster Care Interventions | New Orleans Intervention | Usual care | Permanency | 1^130^; 240 | Low (G1<G2); NR

a Active comparator is an approach derived from an intervention wherein the degree to which core components of the original model are implemented is unclear and/or core components are omitted or substantively modified.

b Intervention is a variant of relationship-based dyadic psychotherapy as developed and manualized by Cicchetti and colleagues.87,88

c ”Enhanced” refers to the provision of individualized services to the parents.

d Chaffin et al. (2011) report a hazard ratio, but it is not statistically significant (i.e., reported as a trend).

e Active comparator is an approach representative of a conventional practice in the field.

f One comparator is a conventional approach; the other a derived approach.

g Effect size measure is not specified; therefore, we did not classify the magnitude of effect as small, medium, or large.

Note: Table is organized alphabetically by intervention name. All results are G1>G2 unless otherwise noted. For estimation of the magnitude of effect, we include only the statistically significant (p<0.05) effect sizes provided by study authors and do not calculate effect sizes as part of our analysis. Interpretation of the effect size as small, medium, or large is defined as follows: Cohen’s d=0.20, 0.50, and 0.80; Cohen’s h=0.20, 0.50, and 0.80; and correlation coefficient r=0.10, 0.30, and 0.50.^176^ When authors use Eta or partial eta squared effect sizes we use the interpretation that the authors provide.80,177 We include an effect size range when more than two effect sizes are reported.

Abbreviations: G = group; HR = hazard ratio; KQ = key question; n = number; NR = not reported; OR = odds ratio; RRR = relative risk reduction.

Of the 21 eligible trials for this KQ, the vast majority provided evidence for different interventions with most bodies of evidence consisting of only one trial, many with very small sample sizes. Among the 19 trials assessing children’s mental and behavioral health, 14 trials resulted in statistically significant between-group differences in one or more measures. A moderate SOE grade was applied for only one intervention, KEEP, which was assessed in a large effectiveness trial. Only two interventions were tested in more than 1 trial (both graded as low SOE): Attachment and Biobehavioral Catch-up77–83,85 and Trauma-Focused Cognitive-Behavioral Therapy.108,115

Regarding healthy caregiver-child relationship outcomes, 11 of the 16 trials assessing relevant outcomes resulted in statistically significant between-group differences on one or more measures. A moderate SOE grade was applied only to KEEP, which was assessed in a large effectiveness trial. Studies predominantly assessed caregiver behavior changes via parent self-report measures or subscales of measures, which reflected varying degrees of established validity. This heterogeneity of measurement made it difficult to generalize findings across studies for the caregiver-child relationship outcomes.

Of the three trials that assessed developmental outcomes, two assessed enhanced foster care interventions that applied specific strategies designed to promote children’s development.117,119,121,122,124,126,128,139,141 For example, children participating in Multidimensional Foster Care for Preschoolers received services from a behavioral specialist working in preschool, child care, and home-based settings.140 The third study, which reported cognitive processes as outcomes, was examining the efficacy of Attachment and Biobehavioral Catch-up.85

We found no eligible studies that assessed school-based functioning, an anomaly given the pervasive emphasis on school readiness and performance in the U.S. educational system.

### Key Question 2 Comparative Effectiveness of Interventions for Improving Child Welfare Outcomes

The summary of results for KQ 2 is also presented in Table 114. The outcomes for KQ 2 pertain to indicators particular to the child welfare system: safety (i.e., maltreatment recurrence), placement stability over time, and permanency (e.g., positive permanency arrangements such as reunification with the parent or adoption by the biological parent or another relative). The evidence for child welfare outcomes is relatively sparse compared with the research providing evidence on child well-being outcomes (KQ 1). One caveat is that this paucity of studies likely reflects our exclusion of (a) system-level interventions, such as differential response or systems-integration approaches, that have a central premise of improving child welfare status and (b) youth more than 14 years of age, because intervention research in the child welfare arena commonly targets families involved with Child Protective Services (CPS) regardless of the child’s age or focuses specifically on adolescents.

Of the nine eligible trials reviewed for this KQ, five investigated the efficacy or effectiveness of parenting interventions, and four examined enhanced foster care interventions for safety, placement stability, or permanency outcomes. Four trials were not among those included in the results for KQ 1: three pertained to parenting interventions (Parent-Child Interaction Therapy [PCIT] that integrates a Motivational Intervention and SafeCare95,96,100 and one pertained to an enhanced foster care intervention (New Orleans Intervention).130 All other trials included in KQ 2 evaluated interventions that were also reviewed under KQ 1.^92,93,132,140,143,144^ The studies analyzed for KQ 2 include two large effectiveness trials92,100, one smaller effectiveness trial,95 and one nonconcurrent cohort study.130 The included studies targeted (1) maltreating families to prevent maltreatment recurrence93,95,96,100,130 or (2) foster parents to promote placement stability and positive permanency outcomes.92,140,143,144

We found moderate SOE for one intervention that addressed child safety with maltreating parents. Based on the results of a large effectiveness RCT, the SafeCare home-visiting intervention resulted in lower rates of child maltreatment recidivism compared with usual care.100 Results of a smaller effectiveness trial with maltreating parents that assessed safety outcomes for an adaptation of PCIT combined with a motivational intervention (referred to here as an adaptation package or PCIT-AP) showed a trend toward benefit in favor of the intervention over usual care consistent with findings from a previous efficacy trial of the same intervention.95,96 Additionally, PCIT-AP was more efficacious in reducing maltreatment recurrence than an enhanced version that included individual services for the parent along with home visiting to support parenting behaviors learned in the clinical sessions.

Another large effectiveness trial focused on improved placement and permanency outcomes for children in foster care. This brief parent training intervention, known as Keeping Foster and Kinship Parents Trained and Supported (KEEP), resulted in improved permanency outcomes (e.g., reunification or adoption by a relative).92 Although there was insufficient evidence regarding the benefit of KEEP in reducing the risk of placement disruption (negative exits), the study found that the intervention mitigated the risk of placement changes associated with multiple previous placements. The KEEP trial offers moderate strength of evidence that a low-intensity approach can effectively promote positive permanency outcomes.

Several other interventions included in KQ 2 resulted in significant benefit compared with usual care, although the strength of the evidence was graded as low because of single trials. Two interventions with older children showed benefit in increasing placement stability and/or positive permanency outcomes. Fostering Healthy Futures, a high-intensity approach and the only child-focused intervention reviewed in KQ 2, resulted in fewer placement changes and increased permanency for youth ages 9 to 11 living in nonrelative foster care, increased reunification rates, and fewer placements in residential treatment center.132 Middle School Success, which targeted girls ages 10 to 12, also showed a significant benefit for reduced placement changes and also for decreased marijuana use, a major risk factor for placement change. A high-intensity intervention for young children, Multidimensional Treatment Foster Care for Preschoolers (MTFC-P), also showed benefit for positive permanency outcomes, measured in various ways: compared with usual care, MTFC-P resulted in fewer permanent placement failures, a greater proportion of attempts at permanent placement resulting in successful placement, and a greater proportion of cases resulting in permanent placement compared with usual care. However, no benefit was found for MTFC-P in number of placement disruptions or time in foster care prior to placement disruption.92,140,143,144

Another multimodal approach, referred to as the New Orleans Intervention, resulted in a significant reduction in the risk of child recidivism among infants and toddlers in CPS custody and placed in foster care. This study also found reduced risk of maternal recidivism for subsequent children among mothers whose parental rights were terminated. This intensive and individualized approach increased termination of parental rights and decreased reunification between the child and his or her biological caregiver. The study authors suggested that the increased scrutiny afforded by the intensive intervention may have contributed to these permanency outcomes. Ideally, a positive outcome for adjudicated children involves reunification with a rehabilitated parent wherein the risks to safety and child well-being have been effectively mitigated through intervention. However, the termination of parental rights may have been a de facto protective outcome for this vulnerable population of maltreated, foster care children.

We found insufficient evidence to draw conclusions regarding the effectiveness of a home visiting intervention in promoting child welfare outcomes. The approach was derived from an existing intervention that had been developed originally as a preventive approach (i.e., an intervention that was not designed to prevent maltreatment recurrence in families where abuse or neglect had already occurred). Although maltreated children and those at risk for maltreatment have similar risk profiles, these findings suggest there may be important distinctions not yet fully understood in terms of clinical need.

### Key Question 3 Comparative Effectiveness of Interventions With Different Characteristics

Several treatment characteristics were identified a priori for this KQ: modality (i.e., service delivery format), theoretical orientation, and type of service delivery setting. We found three trials relevant to KQ 3, all included comparisons that pertained to theoretical orientation.77–79,81–83,85,108 We found no studies that compared the efficacy or effectiveness of interventions delivered in different settings. We also found no studies in which the design or methods clearly indicated that modality (i.e., service delivery format) was a comparison of interest, and our team carefully avoided excessive interpretation to make a study “fit” with this KQ.

We were able to identify two interventions for which the theoretical orientation was clearly differentiated across experimental and control conditions. Meaningful contrasts were elusive due to the eclectic nature of the interventions we reviewed, with the majority of interventions drawn from multiple or unspecified theoretical bases, and minimal discussion of the therapeutic underpinnings by study authors. In cases where the comparator was a derived approach, it was difficult to ascertain the degree to which the original model’s theoretical orientation was maintained or implemented. For example, the CPP studies reported using a nurse home visitation model that has been described by the intervention developer as aiming to enhance early attachment among its other intervention targets.192 Our a priori focus on theoretical orientation did not intentionally aim to elevate treatments with a unifying theory over multiply determined approaches; yet it was difficult to interpret results comparing eclectic approaches. Taken together, these many challenges resulted in our including only two interventions in KQ 3: Attachment and Biobehavioral Catch-up (ABC) compared with a didactic, nonrelationship-based approach and Trauma-Focused Cognitive Behavioral Therapy (TF-CBT) compared with psychodynamic child-centered treatment. The trials all showed benefit in favor of the experimental intervention’s theoretical approach. However, it should be noted that the comparator in the case of the ABC trials was not a bona fide alternative therapy designed to address child attachment or child emotional well-being but a derived approach that targeted only developmental skills (e.g., cognitive, language).

The intervention characteristics specified for KQ 3 were identified a priori following the approach of previous systematic reviews conducted by Agency for Healthcare Research and Quality (AHRQ) Evidence-based Practice Centers. They were selected because of their cost and treatment implications and to build on previous systematic reviews with maltreated children that examined intervention effectiveness by therapy type.145,146,182 However, the difficulty we encountered in carrying out KQ 3, namely the paucity of relevant contrasts, suggests a need for a qualitative analysis of the literature to identify treatment characteristics that are relevant to and useful for the field. Although an ad hoc analysis was beyond the scope of this review, through our immersion in this literature we noted the distinction between and unequal attention paid to specific techniques (e.g., intervention-specific strategies and content) in relation to factors that may be common across interventions at the level of client-therapist interactions (e.g., therapeutic relationship, personal characteristics of therapist and patient, engagement). The latter may be essential to understanding treatment efficacy or effectiveness.183–185 Thus, explicitly attending to differentiating and common treatment characteristics in the scientific literature is one important area for future research.

### Key Question 4 Comparison of Intervention Effectiveness for Improving Child Well-Being or Child Welfare Outcomes in Population Subgroups

KQ 4 summarized the comparative effectiveness of interventions for different child and caregiver subgroups. All trials analyzed for this KQ were also examined in either or both KQ 1 and KQ 2. Table 115 presents the summary of results for KQ 4. The table presents the SOE and also indicates with which subgroup population(s) the intervention was evaluated; many interventions pertained to multiple subgroups.

Table 115 KQ 4 summary

Subgroup/Intervention (G1) | Comparison (G2) | Mental and Behavioral Health | Caregiver-Child Relationship | Development | Safety | Placement stability | Permanency
Age: Early Childhood | - | - | - | - | - | - | -
Attachment and Biobehavioral Catch-up | Active control | L | L | L | - | - | -
Attachment and Biobehavioral Catch-up | Inactive control | L | L | - | - | - | -
Attachment-based Intervention | Usual care | | L | - | - | - | -
Bucharest Early Intervention Project | Usual care | L | L | L | - | - | -
Child-Parent Psychotherapy | Usual care | | L | - | - | - | -
Multidimensional Treatment Foster Care for Preschoolers | Usual care | L | L | L | - | L | -
New Orleans Intervention | Usual care | - | - | - | L | - | L, G1<G2
SafeCare | Usual care | - | - | - | M | - | -
Age: Middle Childhood | - | - | - | - | - | - | -
Fostering Healthy Futures | Inactive control | L | - | - | - | L | L
Age: Early adolescence | - | - | - | - | - | - | -
Middle School Success | Usual care | L | - | - | - | L | -
Sex: Females | - | | - | - | - | - | -
Group Psychotherapy for Sexual Abused Girls | Active control | L | - | - | - | - | -
Group Treatment Program for Sexual Abuse | Inactive control | L | - | - | - | - | -
Type of Maltreatment: Neglect | - | - | - | - | - | - | -
Bucharest Early Intervention Project | Usual care | L | L | L | - | - | -
SafeCare | Usual care | - | - | - | M | - | -
Type of Maltreatment: Physical abuse | - | - | - | - | - | - | -
Combined Parent-Child Cognitive Behavioral Therapy | Active control | L | - | - | - | - | -
Parent-Child Interaction Therapy Adaptation Package | Usual care | - | - | - | L | - | -
Type of Maltreatment: Sexual abuse | - | - | - | - | - | - | -
Group Psychotherapy for Sexual Abused Girls | Active control | L | - | - | - | - | -
Group Treatment Program for Sexual Abuse | Inactive control | L | - | - | - | - | -
Trauma-focused Cognitive Behavioral Therapy | Active control | L | L | - | - | - | -
Presence of Mental or Behavioral Problems | - | - | - | - | - | - | -
Combined Parent-Child Cognitive Behavioral Therapy | Active control | L | - | - | - | - | -
Group Psychotherapy for Sexual Abused Girls | Active control | L, G1<G2 | - | - | - | - | -
Group Treatment Program for Sexual Abuse | Inactive control | L | - | - | - | - | -
Trauma-focused Cognitive Behavioral Therapy | Active control | L | L | - | - | - | -
Caregiving Context: Maltreating parent | - | - | - | - | - | - | -
Attachment and Biobehavioral Catch-up | Active control | L | L | - | - | - | -
Attachment-based Intervention | Usual care | - | L | - | - | - | -
Child-Parent Psychotherapy | Usual care | - | L | - | - | - | -
Combined Parent-Child Cognitive Behavioral Therapy | Active control | L | | - | - | - | -
Incredible Years Adaptation for Neglecting Parents | Inactive control | L | L | - | - | - | -
New Orleans Intervention | Usual care | - | - | - | L | - | L, G1<G2
Parent-Child Interaction Therapy Adaptation Package | Usual care | - | - | - | L | - | -
Project Support | Usual care | - | - | - | - | - | -
SafeCare | Usual care | - | - | - | M | - | -
Caregiving Context: Foster Parent | - | - | - | - | - | - | -
Attachment and Biobehavioral Catch-up | Active control | L | L | L | - | - | -
Attachment and Biobehavioral Catch-up | Inactive control | L | L | | - | - | -
Bucharest Early Intervention Project | Usual care | L | L | L | - | - | -
Keeping Foster and Kinship Parents Trained and Supported | Usual care | M | M | - | - | - | M
Middle School Success | Usual care | L | - | - | - | L | -
Multidimensional Treatment Foster Care for Preschoolers | Usual care | L | L | L | | L | -

Abbreviations: G = group; KQ = key question; L = low; M = moderate

For child subgroups, we summarized the evidence for age and sex, maltreatment type, and the presence of mental or behavioral health problems. For caregiver subgroups, we summarized the evidence for children and their maltreating parents and children and the foster or kinship parents. No studies eligible for inclusion focused on children in residential care or children who had been adopted from foster care. We a priori had identified other salient child and caregiver characteristics as subgroups to examine; however, we identified no eligible studies for these additional areas: (a) caregiver mental health problems, substance abuse, domestic violence, and sociodemographic subpopulations and (b) severity of maltreatment and children with special needs (e.g., prenatal substance exposure). It was particularly notable that we could not identify studies for inclusion in this KQ that attended to race or ethnicity, given the attention to disproportionality in the child welfare arena. We also did not find any eligible studies that explicitly focused on these subgroups or stratified findings by these subgroups, so they are not represented in the results for KQ 4. A number of studies excluded parents with active substance abuse or mental illness and children with documented developmental disabilities.

In sum, the results for KQ 4 provide readers with a roadmap listing interventions for different subgroups for which there is comparative effectiveness research showing low or moderate SOE. These results also point out the substantive gaps in the existing evidence base for addressing the question for what child and/or caregiver characteristics do interventions have impact or the most impact? This gap largely reflects the paucity of studies that could identify moderators or treatment response due to small sample sizes.

### Key Question 5 Comparative Effectiveness of Interventions With Children Exposed to Maltreatment for Engaging Children and/or Caregivers in Treatment

We identified three trials in the literature relevant to KQ 5, which assessed the comparative effectiveness of a motivational intervention designed to increase maltreating parents’ engagement and retention in a parenting intervention. The motivational intervention was a 6-week group-based motivational orientation to parenting services for families referred by CPS for maltreatment.

The researchers compared PCIT combined with either the motivational intervention or service-as-usual CPS orientation for maltreating families referred for parenting services (see description of study design in the Results KQ 2 and KQ 5). The PCIT package that incorporated the motivational intervention yielded better parental treatment engagement relative to those assigned to receive PCIT with the standard CPS orientation. The strength of evidence for the motivational intervention was graded as moderate. In addition, PCIT plus the motivational intervention yielded improved treatment retention outcomes compared with PCIT plus the usual CPS orientation. These findings are notable in light of the paucity of comparative research on participant engagement and retention.

### Key Question 6 Adverse Events Associated With Interventions for Children Exposed to Maltreatment

We included a KQ examining adverse events because there is the potential for harms, even temporary, associated with treatment of children exposed to maltreatment. Such harms may take the form of retraumatization associated with gradual exposure or caregiver distress resulting from an increased awareness of the harm to a child exposed to abuse and neglect experiences. Only two trials reported an incident that the authors classified as an adverse event. Of those trials, only one reported active surveillance of adverse events, which was an inclusion criterion for KQ 6. This trial assessed the comparative efficacy of TF-CBT and nondirective supportive therapy (active control) for sexually-abused preschoolers. Fewer children in TF-CBT experienced the adverse event of removal from treatment because of persistent sexually inappropriate behavior involving another child or adult (low SOE).

### Findings in Relationship to What Is Already Known

This review contributes to the literature by providing a comprehensive assessment of the range of interventions that have been evaluated for children exposed to maltreatment and who live in different caregiving and custodial contexts (i.e., with a maltreating parent, in formal or informal foster or kinship care). To the extent possible, we analyzed the efficacy or effectiveness of interventions for different child and caregiver subgroups in KQ 4 (as described above). Some reviews have limited their purview to specific interventions, to children exposed to specific types of maltreatment, or to other specific subgroups. For example, a 2007 Cochrane review examined the effects of cognitive behavioral training for foster parents in managing challenging child behavior.147 Another review reported on the effectiveness of family therapy for children who had been physically abused.186 Other reviews limited to particular intervention types or subgroups include a meta-analysis of the effectiveness of psychotherapy with sexually abused children,145 a meta-analysis of parent training programs,146 and a review of psychotherapeutic interventions with children in foster care.187 Each contributes to knowledge and understanding of segments of this field, yet none attempt to examine a broader range of maltreated children, caregivers, interventions, and types of outcomes.

This review includes a comprehensive and developmentally informed set of child well-being outcomes. For example, we assessed caregiver-child relationship, developmental, and school-based functioning outcomes in addition to child mental and behavioral health outcomes. Our treatment of parenting ideations and behaviors as indicators of the caregiver-child relationship rather than “parent-level risk factors” emphasizes the transactional nature of a child’s development in the context of the caregiving environment.188 We believe this is the first systematic review guided explicitly by such developmental consideration.

Overall, the findings presented in this report do not contradict but expand on and extend previously published findings. By following the rigorous and transparent CER methods of AHRQ’s Effective Health Care (EHC) program, our report provides a comprehensive assessment of the limitations of the evidence base and critical research, clinical, and policy issues that must be addressed to move the field forward.

## Applicability

As noted, during the review process we systematically abstracted key factors that may affect the applicability of the evidence base. We identified these key factors a priori, using as our guidepost the definition of applicability provided by the AHRQ EHC program that defines applicability as “the extent to which the effects observed in published studies are likely to reflect the expected results when a specific intervention is applied to the population of interest under real-world conditions.” We explicitly sought to identify factors that related to each element of the population, interventions, comparators, outcomes, timing, and settings (PICOTS) framework that was used to guide the review. We present below the major issues that emerged from our analysis of factors affecting the applicability of the evidence base.

### Population

The findings from this review must be understood in the context of treatment that occurs in recognition of the potential traumatogenic nature of maltreatment exposure, which begins from a different perspective than treatment in response to clinical symptoms and impairment. Accordingly, the evidence base primarily reflects two related contingents of maltreated children: those for whom child welfare involvement or custody represents a proxy for maltreatment and those for whom maltreatment is concluded based on clinical assessment. Each of the two approaches is subject to false negative conclusions, but at a broad level they together reflect the target population of children exposed to maltreatment. Among the studies evaluating parenting interventions with maltreating parents, exclusion criteria may have affected the applicability of the findings in important ways. These exclusion criteria encompass parents unwilling to participate in the intervention and study, parents with active substance use or abuse, parents with psychiatric impairment (e.g., severe depression, psychosis), and parents affected by a cognitive or neurological disability. Because these population characteristics represent baseline risks that are prevalent in the target population,51 particularly maternal depression,189,190 the applicability of the evidence to the complex presentations encountered in clinical settings is somewhat limited.

### Intervention

The evidence base reflects the diverse range of intervention approaches in the field, which vary considerably in intensity. Those interventions with lower intensity (≤ 12 weekly sessions or approximately 3 months in duration) or moderate intensity (13 to 24 weekly sessions or approximately 6 months in duration) may fit well with the structural needs and expectations encountered in child welfare systems operating under the strict timeline set for permanency planning under the Adoption and Safe Families Act.191 The majority of studies delivered the intervention of interest under conditions more favorable than encountered in community settings. The discrepancy appeared most salient in terms of provider qualifications, as those in the experimental conditions tended to receive specialized training and close supervision from a highly specialized clinician, often the intervention developer. The interventions analyzed in the results all indicated that a manual was available. However, the interventions appear to vary considerably in the degree to which they attend to issues critical to effective implementation, particularly as relates to fidelity measurement and maintenance.

### Comparators

Many the comparisons in the evidence base evaluated the efficacy or effectiveness of the intervention against an active control. Of these, 36 percent represented conventional practices in the field and 64 percent represented approaches that were derivations of other approaches. The derived approaches made assessment of applicability difficult because it was not clear whether they reflected the best alternative treatments in the field. On the contrary, in several cases the comparator was a modified version of an original model for which evidence of effectiveness exists in the scientific literature or did not appear to maintain core components of the original model with fidelity (the case in five trials).77–79,81–83,85,87,88,112 The derived approaches also included two that were developed to control for nonspecific aspects of the experimental intervention. As newly developed interventions, the extent to which each represented a “best” alternative treatment could not be determined.

### Outcomes

The evidence base for the efficacy or effectiveness of parenting interventions in changing parenting behavior associated with maltreatment is limited by the reliance on parent self-report measures of behavioral or attitudinal change, often using only subscales of measures or measures with weak evidence of their validity to the study population. Although parent self-reports of parenting practices are important indices of the quality of the caregiver-child relationship and the risk of maltreatment recurrence, measurement of actual behavior change would strengthen the evidence of benefits.

Few parenting interventions with maltreating parents used an objective, observational measure of child attachment to measure change in the caregiver-child relationship. The most widely used and validated measure of attachment between a child and his or her parent (or primary caregiver) is a structured procedure in which the child experiences separations from and reunions with the parent that represent laboratory analogues of normative parent-child separations.181 This laboratory-based procedure, known as the “Strange Situation,” is the “measure of first choice for examining attachment intervention outcomes.”192 However, the validity of this measure has not been established for the foster care context, because a child in foster care may have been in a placement too briefly or experienced such disruption that a primary caregiving relationship with the foster parent would be premature at best. These measurement issues related to the caregiver-child relationship undermine the applicability of the evidence to the target population. In contrast, child mental and behavioral health outcomes, as assessed across the different types of interventions included in this review, were based on a narrow set of measures with established validity for the target population. However, very few studies used child report.107,131

The child welfare outcomes reported in the included studies were based on data drawn primarily from child welfare agency records. This approach may offer important insights into the integration of treatment into child welfare systems but only to the extent that records objectively, accurately, and consistently report the relevant variables within a system and across regions and states. The duration of follow up to assess maltreatment recurrence (i.e., safety) was variable across studies, making it somewhat difficult to apply the findings to the already complex recurrence data in the State Child and Family Service Reviews (the data used by the Federal Government to monitor State child welfare programs in meeting safety, permanency, and family and child well-being outcomes).

The majority of studies included in KQ 1, regardless of intervention type, collected outcomes only at postintervention. When present, follow-up assessments rarely extended beyond 3 to 6 months after the intervention ended. Both short- and long-term improvements have important applicability to maltreated children, particularly children at risk for out-of-home placement and parents at risk of losing custody or parental rights unless the actions that brought their case to the attention of the child welfare system are addressed. For KQ 2, safety outcomes spanned much greater periods of time, although there was considerable variability in time to followup across studies assessing child recidivism.

### Setting

Many of the studies were conducted in university- or community-based clinics, including organizations providing services for the child welfare system. Thus, they are generally, but not wholly, representative of the settings in which interventions are delivered in the field. The studies were predominantly conducted in the United States. Four studies were conducted in other Western countries: two in Canada and one in the United Kingdom. Although these other settings were also Western countries, differences in child welfare systems and health service systems may affect the applicability of the study findings. One study was conducted in Iran, and another other in Romania. The evidence from these latter studies is less broadly applicable, despite offering perspectives on caring for maltreated children in low- and middle-income countries and potentially informing intervention in appreciably underresourced areas.

## Limitations of the Comparative Effectiveness Review

Our review required that included studies be of at least medium or low risk of bias and include comparators and pairwise comparisons as a basis for conclusions regarding effectiveness. The decision to emphasize certain aspects of study design resulted in the exclusion of evaluations of ongoing, highly adaptable programs that are widely used in the field but come with limited empirical support. This review did not limit interventions based on the ready availability of a manual or training to support effective implementation, although all of the studies included in the results referred to a manual or treatment program. Another limitation of the review relates to the issue of heterogeneity. A key tenet of an AHRQ review involves the effort to restrict sample heterogeneity in favor of generalizability. Our efforts in this regard resulted in exclusions that admittedly may have come at the cost of a more representative review. However, each exclusion decision was made with the intention of focusing the review and controlling for important sources of heterogeneity. For example, youth older than 14 years of age were excluded. We recognize that the decision to exclude older adolescents meant excluding a large body of evidence about widely used and well-respected interventions, such as, Multidimensional Treatment Foster Care,193,194 Multisystemic Therapy for Child Abuse and Neglect,195,196 and the Sanctuary Model^®^.197,198 Although clearly a relevant population, the nature of adolescent development (e.g., increases in autonomy, independence, physical maturity) and the nature of caregiving during this period undergo significant changes and evolution. With some variation, maltreatment rates decrease with children’s age with the highest rates among infants. Although rates tend to increase during early adolescence relative to elementary school years, they revert to their decline during mid-adolescence. We imposed the age cutoff in recognition of how maltreatment and its sequelae evolve across the development spectrum and shift in frequency as youth age.

Other exclusions pertained to type of intervention. We excluded evaluations of primary or secondary prevention, namely studies where maltreatment was not indicated or substantiated, families had no evident current involvement with CPS, or the description of the study population was too vague for a determination about maltreatment. However, despite this exclusion, the review encompasses an array of interventions that span a broad spectrum of development that includes infancy, early childhood, school age, and early adolescence. Systems-level interventions likewise were excluded to focus on more “clinical level” approaches at the child, parent, and family levels. Understanding how systems can effectively respond to maltreatment and how interventions can be effectively implemented within these complex systems is critically important. Systems approaches, such as differential response and solution-focused casework, are well accepted and widely used within child welfare and affect the work of related care systems. At the same time, these approaches and their evaluations were so diverse that they warranted a separate review.

Finally, perhaps the most difficult exclusion decision for this review pertained to children exposed to domestic violence. The exclusion was made in the interest of reducing clinical heterogeneity and also out of concern about the potential for readers to conflate domestic violence and maltreatment if they were combined in a single review. Despite the high concordance of domestic violence with physical and sexual abuse, emotional victimization, and neglect, the experience of witnessing domestic violence relative to that of being a direct victim of caregiver maltreatment may vary. Further, many jurisdictions classify exposure to domestic violence as distinct from maltreatment.

Even with these exclusions, we strongly acknowledge that this review encompasses a notably heterogeneous population with widely varying need for intervention. We were unable to account for the inherent clinical heterogeneity in the population of maltreated children whether in community or child welfare and foster care settings. Approximately 20 percent of children in foster care are removed from the home for reasons other than abuse or neglect. Reasons may involve exposure to risk rather than direct victimization of the child (e.g., prenatal drug exposure, parental substance abuse, domestic violence, unconfirmed maltreatment but in need of services).51

## Limitations of the Evidence Base

This review applied stringent evidentiary standards to the still relatively new field of evidence-based mental health treatment for maltreated children whose backgrounds of victimization, ambivalence toward maltreating parents or caregivers, complex symptoms and functional impairments, and disruptions in care present extreme challenges to traditional research. We did not pursue a quantitative meta-analysis for this review because of the diversity in interventions, comparators, and outcomes measured in the literature. Specific limitations we encountered are described below.

### Study Design and Methodology

Several issues related to design and methodology hampered the comparative review process. At a broad level, studies rarely distinguished themselves as either efficacy or effectiveness trials. This speaks to a serious issue in the field that contributes to variability in definitions of evidence-based practice and understanding of when practices are ready for dissemination.199 At the level of intervention, studies infrequently undertook head-to-head comparisons with named active treatments; also, studies that used a usual-care comparator varied widely in the definition and content of usual care. Regarding the former limitation, our systematic review found several instances where comparators were derived from commonly used interventions that included variations specific to the setting or the study. Overall, the active control treatments varied widely within and across studies and often lacked a clear treatment rationale and specificity about procedures. Such variations, particularly when unlabeled and untested for efficacy, make it difficult to arrive at conclusions regarding comparative effectiveness. Regarding “usual care” or “services as usual” as the control intervention, which was the case for the majority of studies reviewed, there is no standard for this type of control group in the field. Thus, usual care as the control represented a problematic comparator insofar as it is an ill-defined concept.

Studies either lacked or failed to report power analyses. Because the evidence base features many small studies, this omission hampered our ability to assess whether the absence of effect reflected lack of effectiveness or insufficient statistical power. The vulnerability of the population increases the urgency of the need to identify effective interventions (and weed out ineffective interventions). Adequately powered studies, coupled with clear statements of statistical power calculations, can help redirect resources and attention to the most promising interventions.

Our review also made clear that the very definition of maltreatment itself presents a barrier for researchers. Many of the included studies define maltreatment in terms of a child’s involvement with CPS or substantiation of alleged abuse. Neither criterion should be considered equivalent to the broader population of maltreated children because child welfare determinations are affected by community and state-level differences in how maltreatment is defined and reported. Additionally, differences in child welfare scrutiny for impoverished and minority families are well documented. The alternative of clinical assessment commonly seen in the literature often is vague in terms of how maltreatment is specifically operationalized and assessed, whether by informal clinical interview or standardized measures.

Studies were also often vague about their own inclusion criteria, which influenced our decision to restrict the review to children who had a reasonably clear history of maltreatment, rather than include at-risk or mixed samples that posed further definitional challenges. We did not encounter any study that stratified findings by children at risk or with known exposure. Many studies did not provide specific information about the type and number of events, timing, chronicity, context of children’s maltreatment, or any co-occurrence of other potentially traumatic events. Although common problems in the research literature, we recognize that the effort to improve clarity about aspects of maltreatment is fraught with difficulty. CPS records and clinical assessment protocols both are subject to inaccuracy, misidentification, and omission errors; both are only as accurate as the information that has observed, reported, or inferred.

Theoretical orientation proved a daunting area to examine in this review. Even when a treatment ascribed to a primary theory of change, rarely did an intervention adhere exclusively to that theory or related intervention strategies. Some “borrowed” facets of various orientations; others balanced one or more perspectives. For example, PCIT emphasizes the behavioral aspects of its approach yet also includes an explicitly relational phase based in attachment theory that precedes the focus on effective behavioral management. Additionally, many studies did not fully describe the key components of their interventions, making it difficult to know what actually occurred within treatment sessions and whether the therapist’s actions corresponded to the purported theory.

### Study Measurement and Analysis

Many studies were reviewed but subsequently excluded because they did not employ well-established, reliable, and valid assessment measures. We required that outcome measures offer more than face validity; we looked for some evidence of construct or predictive validity. When such evidence was clearly lacking in the extant literature, we excluded the studies or the specific outcomes within a study. As a result, our review does not include all data from included studies.

Identification of child symptomatology was inconsistent across studies, for both younger and older children. Typically, intervention was based on an event, maltreatment or involvement with CPS, rather than symptomatic or functional impairment. This reflects a general tendency for systems to refer for mental health care based on events of concern, whereas families describe symptoms and functional problems as reasons for treatment. A further complication was that the approaches used to assess symptomatology and impairment varied and did not always involve commonly used, well-validated measures.

Many, far from all, studies compared baseline characteristics, usually demographics, between treatment and control groups. Ideally analyses should account for other potentially important differences at baseline (e.g., exposure to trauma, symptom patterns and levels, severity of maltreatment, family characteristics). Moreover, the majority of studies we reviewed failed to provide sufficient attention to differences in children’s cognitive, social-emotional, and language development. As a result, there was limited evidence to assess treatment effectiveness or issues that affected treatment response by age group. The lack of developmental differentiation is consistent with other limitations that are, at least in part, sequelae of small samples that preclude subgroup analyses and examination of moderating and mediating effects.

A large number of studies exceeded our criteria for risk of attrition bias: total study attrition above 30 percent or differential attrition between the active treatment and control groups greater than 15 percent.200 We excluded several trials that admirably followed participants over a longer period (e.g., greater than 1 year) because too many of the participants were missing from the analysis of follow-up data.201–206

## Future Research Needs

The predominance of low SOE and inconsistent or no difference findings in the studies we reviewed calls for further research to resolve incongruous findings and improve our confidence that the evidence is free of error, accurate, and as representative as possible. A number of specific areas should be addressed in future research.

### Head-to-Head Trials

The evidence base for effective interventions for maltreated children is composed primarily of single trials with relatively short-term results absent head-to-head studies comparing interventions of interest. At this juncture, additional comparative efficacy and effectiveness trials are needed to build the evidence for interventions with low SOE. When studies include multiple conditions, reporting of one-to-one (pairwise) comparisons is critical.110,207 Comparisons of bona fide interventions that are fully representative of alternative treatment options is another substantive gap to address.

### Intervention Considerations

A gap in the current literature is comparative research with existing interventions that have an established evidence base of efficacy or effectiveness with other populations and rigorous testing of adaptations. Adaptations may exclude or substantially modify components of an original version, resulting in fundamental changes relative to the original intervention. Thus, research on adaptations demands particularly close attention on the part of the researcher to therapist-and participant-level characteristics and other factors (e.g., setting, timing). The paucity of relevant contrasts for KQ 3 suggests a need for a qualitative analysis of the literature to identify treatment characteristics that are relevant to and useful for the field. We noted the distinction between and unequal attention paid to specific techniques (e.g., intervention-specific strategies and content) in relation to factors that may be common across interventions at the level of client-therapist interactions (e.g., therapeutic relationship, personal characteristics of therapist and patient, engagement). The latter may be essential to understanding treatment efficacy or effectiveness and merits further attention.183–185

### Assessment of Clinical Need

The use of common and validated measures for identifying symptomatology is a major omission undermining the strength of the evidence base. Greater coalescence around such measures will help future reviews generalize findings across studies and settings and create greater consensus in the field around effective and ineffective interventions by introducing common metrics. Additional research is particularly needed to determine the relative benefits of various interventions across age subgroups.

### Outcomes

The use of well-established, reliable, and valid assessment measurement and more consistent use of measures is imperative for interpreting the precision and directness of outcomes. Future research is also needed in the area of longer-term outcomes, including duration of symptom remission or functional improvement, generalization of outcomes from one setting to another, outcome variability according to clinically heterogeneous subgroups, and subsequent retraumatization. An outcome that is particularly deserving of deeper assessment is the extent to which children involved in the child protective system achieve a meaningfully positive placement. Currently, permanency outcomes generally reflect study constraints rather than the desired outcome of a constant, stable relationship with a parent or caregiver who comes to love and accept responsibility for a maltreated child.

### Research on Engagement/Retention

Another future research need is intensified attention to strategies that foster treatment and study retention. We were able to find only one comparative study for inclusion in this review relevant to the issue of engagement and retention. This is an area that has remained elusive for decades because of numerous barriers experienced by vulnerable families. Commitment of time and effort is not limited to participation in treatment sessions. It often includes time, effort, and cost for transportation; conflicting work schedules; child care for other siblings; and early established impressions about the responsiveness of the therapist and the potential benefit of treatment. Families where maltreatment has occurred or who are providing out-of-home care contend with a host of other challenges (e.g., poverty, familial conflict, requirements of child welfare and other service systems) that can preclude their participating in interventions or research. These many issues similarly affect sustained participation in study assessments. One immediate next step in this area is building further research on motivational cointerventions, given the promising findings regarding PCIT combined with a motivational orientation.95–97 Future research could compare interventions in terms of retention or examine features of interventions associated with engagement and retention.

### Study Design and Reporting

Researchers should review and use the CONSORT statement to ensure the greatest clarity in reporting of trials.208 Future studies need to be adequately powered and statistical power calculations presented. Trials in this field do not typically blind participants or providers, but future studies should make every effort to blind outcome assessors to reduce the risk of detection bias.

### Statistical Considerations

Even with concerns about limited sample sizes and attrition, few studies in the literature we reviewed included an intention to treat (ITT) analysis. ITT analysis may not be useful when there is differential attrition across study conditions, as was often the case for the maltreatment studies we reviewed. However, in cases where there is not high differential attrition, ITT analysis helps avoid the error of incorrectly attributing effectiveness to an intervention that actually may result from underlying differences in the final study groups. More consistent use and clear reporting of ITT analysis would enhance the interpretability and generalizability of study findings. Other concerns related to statistical analysis and inferences pertain to the need to control for multiple comparisons and limit post-hoc analyses. Future studies should account for multiple comparisons and clearly state planned statistical analyses. In complex multifactorial interventions, planned statistical analyses should include the assessment of mediators and moderators.

Beyond these more common statistical issues, a more fundamental question that merits increased attention in future research is how scientists should approach probabilistic estimates of effects and how to express confidence in their findings. Across the scientific literature we reviewed, researchers used only a classical/frequentist approach to hypothesis testing that views probability as the likelihood of a given result being true or false with a null hypothesis rejected or accepted with a certain probability of an accurate conclusion or “true effect.” Relying on p-values to assess whether a research finding is true may be subject to inherent error associated with small sample sizes and extensive heterogeneity of design, definitions, and outcomes, among other considerations.209 Hence, the use of alternative statistical analyses, namely Bayesian methods, may be warranted in future research because of the complexity of the population and heterogeneity of clinical need.

### Implementation and Sustainability Research

Finally, a major gap in the current evidence base is rigorous study of implementation and/or issues related to maintenance of an intervention. Fidelity to the intervention model was infrequently reported and sparse in detail. To address the twin challenges of a stressed population and tight reimbursement guidelines, successful interventions must be effective and feasible to implement and maintain. Issues that will inform transportability to general community settings, accessibility and utilization by maltreating families, or their effective use by implementing clinicians should be more explicitly considered in future research. For example, future efficacy studies are needed on lower intensity interventions and factors that affect accessibility for this highly vulnerable population. Relatedly, there is a notable gap in attention to “dose” or how much of an intervention is needed to effect change that should be addressed in future research.

Another practical consideration for the development and testing of real-world interventions relates to the costs of service delivery (e.g., provider training, clinical effort, and practice infrastructure), service receipt (e.g., family transportation, child care, health care deductibles and coinsurance), and potential revenue (e.g., Medicaid, private insurance, public and private funders). With most mental health care based on service reimbursement, future research is clearly needed on the interplay of treatment model and structure, service definitions, utilization management, treatment authorization, and claims submission and authorization.

## Implications for Research

The myriad methodological, conceptual, and operational challenges to clinical research with maltreated children and maltreating families, which led to the methodological and substantive gaps in the evidence base described above, cannot be overcome by individual, site-specific, time-limited studies largely conducted by the developers of interventions or single research teams. To move the science forward, there clearly is a need for extensive multisite collaboration. A research network, for example, would provide the platform for efficient and methodologically rigorous collaborative clinical trials. It would allow for large enough samples to examine moderators of treatment response and investigate subgroups for whom treatments are less, or more, effective.210,211 A clinical research network could be an extension of an existing structure or structures, such as the National Child Traumatic Stress Network.

A central and ongoing barrier to conducting rigorous research in this area is employing randomization or quasi-randomization procedures, because these designs raise thorny issues for clinicians and other stakeholders serving maltreated children and their families. Although the concerns are not unique to maltreatment research, community-based professionals may be, for example, reluctant to see their clientele randomized to a no intervention or usual care group that they perceive as less effective than the intervention under investigation. This dynamic plays out across clinical trials where community providers and clients may feel that a valuable treatment option, even if it is experimental, has been denied to them. This subsequently may foster differential study engagement and attrition. Again, a multisite collaborative could provide a powerful nexus for shared strategies and best practices that result in successful implementation of controlled research studies in this challenging field.

## Implications for Clinical Practice

For clinicians, the stringent criteria of this CER may raise questions about its applicability for typical practice settings such as community mental health agencies, health centers, schools, and private practices. Faced with relatively few interventions meeting the criteria for greater SOE, there is a potential to conclude that this report has little relevance to a community provider. Clinicians are well aware of the complexity of direct service for maltreated children and for many other vulnerable populations who present with multiple comorbid diagnoses and where individual, family, and community risk factors, experiences of trauma and adversity, and barriers to treatment participation exist. Although there has been a groundswell of support for using evidence-based treatments, they are relatively new models that often are unfamiliar to a community practitioner. Additionally, community therapists do not have the luxury of treating only clientele whose presentation accords to an evidence-based treatment. Nor can they await the fulfillment of calls for better research, for example, in the form of head-to-head comparisons of active treatments or designs that allow larger samples to address varied populations subgroups. Instead, and in this report, they are challenged to consider the relative evidence of one or another approach in a given clinical context.

Further, this report offers clinicians a synthesis of research limitations associated with widely used practices and point to factors clinicians might consider in their own formulations and treatment decisions. For example, the interventions highlighted as benefiting mental and behavioral health, caregiver-child relationships, child development, and child welfare status represent treatment selection priorities. Studies that were included yet found to have lesser scientific support may be second-line options or represent best available options for given predisposing maltreatment events or certain clinical presentations. Of course, selection from among the interventions in this review must be considered in light of clinical context (e.g., comorbidities, motivation for treatment, primary symptoms). Finally, providers will, no doubt, turn to other interventions. The selection criteria in this review may still guide that process. Clinicians may consider the extent to which their clientele are reflected in studies of a particular intervention (i.e., sample representativeness), the relevance of study outcomes (i.e., applicability), and the extent to which they are able to adopt a practice with strong attention to fidelity. Outcome findings in this review may assist clinicians to fine-tune outcomes to be expected from a particular approach, modality, or level of care. Based on this refined knowledge, expectations may be communicated to clients to facilitate engagement and positive, realistic expectations for change. These suggestions are but an early step toward improving the relevance of research to therapists and other providers, which is critical if standards of care are to improve rather than remain static.

A primary motive for clinicians involves their desire for effective work that benefits their clients and engenders a sense of competence, mastery, and satisfaction. Thus, in the face of such a limited base of evidence for interventions with maltreated children, this review may heighten clinicians’ awareness and investment in sound implementation practices. These include attention, at both the provider and supervisor levels, to systematic treatment fidelity, barriers to implementation, and obstacles to sustainable practice.212 Attention to adoption and effective implementation of a new practice is crucial and depends on clinical training that is supported by adherence to a clear treatment manual, ongoing consultation in model application to clinical practice, and practice that is guided by an expert provider and trainer.

## Implications for Policy

This report presents highly specific research that may not correspond readily to practices in real-world community settings. The two approaches for which there was strongest evidence based on effectiveness studies91,92,100 were each tested in only one trial, and the SOE for most interventions included in this review was low. Given the early stage of research in the field, we caution that this report should not be taken as a guide to the selection of specific approaches for wider dissemination. Rather, the central finding of this review for policymakers and payers is the relative scarcity of evidence to guide the field in meeting the needs of this vulnerable population of children.

Two implications for policymakers are immediately evident. First, there is an urgent need for collaborative clinical trials to move the field of child maltreatment intervention forward. A multisite research network is a powerful platform that could efficiently furnish collaborative studies of sufficient quality and size to build a stronger evidence base for effective practice. The National Child Traumatic Stress Network offers an existing infrastructure that could be expanded to support and provide scientific leadership for collaborative multisite trials. Alternatively, or in addition, an existing clinical research network could be expanded or a new network formed to focus on child maltreatment intervention. Such initiatives will, in many respects, require a paradigm shift in funding to prioritize and adequately support complex research endeavors over single-site, small studies conducted by treatment developers or single research groups. It also will also require a recalibration of time frame expectations for study implementation with vulnerable populations and the creation of flexible funding mechanisms that seamlessly support the trajectory from efficacy to translation for rigorously examined interventions that show consistent, robust effects.

A second area where policymakers can have a major positive impact is in incentivizing higher quality program and administrative data that will both serve research needs and drive data-informed decision-making at the program and clinical levels. Program-record databases typically collect the minimal information pertinent to billing or other administrative needs and not necessarily case-outcome data. Field agencies that must compete for limited dollars to support their programs are rarely able to focus on systematic data or participate readily in rigorous research activities. The collection of implementation and outcome data is rarely incentivized within an agency or practice or in the form of enhanced payment rates from insurers. The end result, in a context of dwindling resources to support the cost of providing quality care, is disincentive for programs to engage in activity beyond what is specifically reimbursed.

## Conclusions

Maltreatment intervention research, particularly comparative research, remains a relatively nascent field. Much of the research relies on small samples and has limited statistical power, so data cannot be stratified based on subgroups or considered in terms of potential mediators and moderators of effect (e.g., age, type and chronicity of maltreatment). It is critical to note that low or insufficient SOE is not equivalent to a judgment of an intervention as ineffective. Rather it reflects the justifiable state of affairs where many promising or widely used approaches have not been the subjects of empirical study. This review draws attention to the herculean efforts involved in conducting high-quality trials of mental health and psychosocial interventions, a challenge that is potentiated with the vulnerable, maltreated population that is the focus of this review.

Although several interventions emerged with evidence to support their efficacy or effectiveness, the strength of the evidence was low for the vast majority of outcomes. Consequently, our main finding was that the literature in this field is strikingly limited due to numerous substantive and methodological gaps. These limitations include (a) the predominance of single trials conducted by the treatment developers testing unique interventions that often employ strategies very similar to those of other approaches, (b) usual care or wait-list controls rather than head-to-head comparisons, (c) short-term outcomes, (d) inadequate reporting of attrition, and (e) wide heterogeneity in type and psychometric soundness of outcome measurement across studies.

Thus, this review serves as an urgent call for improving and building the evidence base for interventions to promote the well-being of maltreated children. A multisite research network is a powerful platform that could facilitate the conduct of large, methodologically rigorous comparative efficacy and effectiveness trials that are needed to move the field forward. More broadly, a paradigm shift is required on the part of researchers and funders alike to galvanize the commitment and resources necessary for conducting collaborative clinical trials with these particularly vulnerable children and families.