# Evidence Tables

## Attachment and Biobehavioral Catch-Up

Table E-1 Attachment and biobehavioral catch-up, study characteristics

Table E-2 Attachment and biobehavioral catch-up, population characteristics

Table E-3 Attachment and biobehavioral catch-up, population clinical characteristics

Table E-4 Attachment and biobehavioral catch-up, intervention characteristics

Table E-5 Attachment and biobehavioral catch-up, mental health outcomes

Table E-6 Attachment and biobehavioral catch-up, healthy caregiver child relationship outcomes

## Attachment-Based Intervention

Table E-7 Attachment-based intervention, study characteristics

Table E-8 Attachment-based intervention, population characteristics

Table E-9 Attachment-based intervention, population clinical characteristics

Table E-10 Attachment-based intervention, intervention characteristics

Table E-11 Attachment-based intervention, mental health outcomes

Table E-12 Attachment-based intervention, healthy caregiver child relationship outcomes

## Bucharest Early Intervention Project

Table E-13 Bucharest early intervention project, study characteristics

Table E-14 Bucharest early intervention project, population characteristics

Table E-15 Bucharest early intervention project, population clinical characteristics

Table E-16 Bucharest early intervention project, intervention characteristics

Table E-17 Bucharest early intervention project, mental health outcomes

Table E-18 Bucharest early intervention project, healthy caregiver child relationship outcomes

Table E-19 Bucharest early intervention project, healthy development outcomes

## Child-Parent Psychotherapy

Table E-20 Child-parent psychotherapy, study characteristics

Table E-21 Child-parent psychotherapy, population characteristics

Table E-22 Child-parent psychotherapy, population clinical characteristics

Table E-23 Child-parent psychotherapy, intervention characteristics

Table E-24 Child-parent psychotherapy, healthy caregiver child relationship outcomes

## Combined Parent-Child Cognitive Behavioral Therapy

Table E-25 Combined parent-child cognitive behavioral therapy, study characteristics

Table E-26 Combined parent-child cognitive behavioral therapy, population characteristics

Table E-27 Combined parent-child cognitive behavioral therapy, population clinical characteristics

Table E-28 Combined parent-child cognitive behavioral therapy, intervention characteristics

Table E-29 Combined parent-child cognitive behavioral therapy, mental health outcomes

Table E-30 Combined parent-child cognitive behavioral therapy, healthy caregiver child relationship outcomes

## Eye Movement Desensitization and Reprocessing

Table E-31 Eye movement desensitization and reprocessing, study characteristics

Table E-32 Eye movement desensitization and reprocessing, population characteristics

Table E-33 Eye movement desensitization and reprocessing, population clinical characteristics

Table E-34 Eye movement desensitization and reprocessing, intervention characteristics

Table E-35 Eye movement desensitization and reprocessing, mental health outcomes

## Fostering Healthy Futures

Table E-36 Fostering healthy futures, study characteristics

Table E-37 Fostering healthy futures, population characteristics

Table E-38 Fostering healthy futures, population clinical characteristics

Table E-39 Fostering healthy futures, intervention characteristics

Table E-40 Fostering healthy futures, mental health outcomes

Table E-41 Fostering healthy futures, child welfare outcomes

## Group Psychotherapy for Sexually Abused Girls

Table E-42 Group psychotherapy for sexually abused girls, study characteristics

Table E-43 Group psychotherapy for sexually abused girls, population characteristics

Table E-44 Group psychotherapy for sexually abused girls, population, clinical characteristics

Table E-45 Group psychotherapy for sexually abused girls, intervention characteristics

Table E-46 Group psychotherapy for sexually abused girls, mental health outcomes

## Group Treatment Program for Sexual Abuse

Table E-47 Group treatment program for sexual abuse, study characteristics

Table E-48 Group treatment program for sexual abuse, population characteristics

Table E-49 Group treatment program for sexual abuse, population clinical characteristics

Table E-50 Group treatment program for sexual abuse, intervention characteristics

Table E-51 Group treatment program for sexual abuse, mental health outcomes

## Incredible Years Adaptation

Table E-52 Incredible years, study characteristics

Table E-53 Incredible years adaptation, population characteristics

Table E-54 Incredible years adaptation, population clinical characteristics

Table E-55 Incredible years adaptation, intervention characteristics

Table E-56 Incredible years adaptation, mental health outcomes

Table E-57 Incredible years adaptation, healthy caregiver child relationship outcomes

## Keeping Foster Parents Trained and Supported

Table E-58 Keeping foster parents trained and supported, study characteristics

Table E-59 Keeping foster parents trained and supported, population characteristics

Table E-60 Keeping foster parents trained and supported, population clinical characteristics

Table E-61 Keeping foster parents trained and supported, intervention characteristics

Table E-62 Keeping foster parents trained and supported, mental health outcomes

Table E-63 Keeping foster parents trained and supported, child welfare outcomes

## Middle School Success

Table E-64 Middle School Success (MSS), study characteristics

Table E-65 MSS intervention, population characteristics

Table E-66 MSS intervention, population clinical characteristics

Table E-67 MSS intervention, intervention characteristics

Table E-68 MSS intervention, mental health outcomes

Table E-69 MSS intervention, child welfare outcomes

## Multidimensional Treatment Foster Care—Preschoolers

Table E-70 Multidimensional treatment foster care—preschoolers, study characteristics

Table E-71 Multidimensional treatment foster care—preschoolers, population characteristics

Table E-72 Multidimensional treatment foster care—preschoolers, population clinical characteristics

Table E-73 Multidimensional treatment foster care—preschoolers, intervention characteristics

Table E-74 Multidimensional treatment foster care—preschoolers, mental health outcomes

Table E-75 Multidimensional treatment foster care—preschoolers, child welfare outcomes

## New Orleans Intervention

Table E-76 New Orleans intervention, study characteristics

Table E-77 New Orleans intervention, population characteristics

Table E-78 New Orleans intervention, population clinical characteristics

Table E-79 New Orleans intervention, intervention characteristics

Table E-80 New Orleans intervention, child welfare outcomes

## Nurse Home Visiting

Table E-81 Nurse home visiting, study characteristics

Table E-82 Nurse home visiting, population characteristics

Table E-83 Nurse home visiting, population clinical characteristics

Table E-84 Nurse home visiting, intervention characteristics

Table E-85 Nurse home visiting, mental health outcomes

Table E-86 Nurse home visiting, healthy caregiver child relationship outcomes

Table E-87 Nurse home visiting, child welfare outcomes

## Parent-Child Interaction Therapy Adaptation

Table E-88 Parent-child interaction therapy adaptation, study characteristics

Table E-89 Parent-child interaction therapy adaptation, population characteristics

Table E-90 Parent-child interaction therapy adaptation, population clinical characteristics

Table E-91 Parent-child interaction therapy adaptation, intervention characteristics

Table E-92 Parent-child interaction therapy adaptation, mental health outcomes

Table E-93 Parent-child interaction therapy adaptation, healthy caregiver child relationship outcomes

Table E-94 Parent-child interaction therapy adaptation, child welfare outcomes

Table E-95 Parent-child interaction therapy adaptation, treatment retention

## SafeCare

Table E-96 SafeCare, study characteristics

Table E-97 SafeCare, population characteristics

Table E-98 SafeCare, population clinical characteristics

Table E-99 SafeCare, intervention characteristics

Table E-100 SafeCare, child welfare outcomes

## Trauma-Focused Cognitive Behavioral Therapy

Table E-101 Trauma-focused cognitive behavioral therapy, study characteristics

Table E-102 Trauma-focused cognitive behavioral therapy, population characteristics

Table E-103 Trauma-focused cognitive behavioral therapy, population clinical characteristics

Table E-104 Trauma-focused cognitive behavioral therapy, intervention characteristics

Table E-105 Trauma-focused cognitive behavioral therapy, mental health outcomes

Table E-106 Trauma-focused cognitive behavioral therapy, healthy caregiver child relationship outcomes

## Videotape Intervention

Table E-107 Videotape intervention, study characteristics

Table E-108 Videotape intervention, population characteristics

Table E-109 Videotape intervention, population clinical characteristics

Table E-110 Videotape intervention, intervention characteristics

Table E-111 Videotape intervention, mental health outcomes

## References

1 Dozier M, Peloso E, Lindhiem O, et al. Developing evidence-based interventions for foster children: An example of a randomized clinical trial with infants and toddlers. J Soc Issues. 2006;62(4):767-85. ISI:000241562500006.
2 Dozier M, Peloso E, Lewis E, et al. Effects of an attachment-based intervention on the cortisol production of infants and toddlers in foster care. Dev Psychopathol. Summer. 2008;20(3):845-59. [pmid: 18606034].
3 Dozier M, Lindhiem O, Lewis E, et al. Effects of a foster parent training program on young children’s attachment behaviors: Preliminary evidence from a randomized clinical trial. Child Adolesc Soc Work J. Aug. 2009;26(4):321-32. [pmid: 22065891].
4 Lewis-Morrarty E, Dozier M, Bernard K, et al. Cognitive flexibility and theory of mind outcomes among foster children: Preschool follow-up results of a randomized clinical trial. J Adolesc Health. August. 2012;51(2 Suppl):S17-S22. [pmid: 22794528].
5 Bernard K, Dozier M, Bick J, et al. Enhancing attachment organization among maltreated children: results of a randomized clinical trial. Child Dev. Mar. 2012;83(2):623-36. [pmid: 22239483].
6 Dozier M, Bernard K, Ross E, et al. The Effects of an Attachment-Based Intervention on Children’s Expression of Negative Affect in a Challenging Task. unpublished A.
7 Dozier M, Bernard K, Bick J, et al. Normalizing Neglected Children’s Blunted Diurnal Cortisol Rhythms: The Effects of an Early Intervention. unpublished B.
8 Sprang G. The efficacy of a relational treatment for maltreated children and their families. Child Adolesc Ment Health. 2009;14(2):81-8. 2009-06028-005.
9 Moss E, Dubois-Comtois K, Cyr C, et al. Efficacy of a home-visiting intervention aimed at improving maternal sensitivity, child attachment, and behavioral outcomes for maltreated children: a randomized control trial. Dev Psychopathol. Feb. 2011;23(1):195-210. [pmid: 21262048].
10 Bos KJ, Fox N, Zeanah CH, et al. Effects of early psychosocial deprivation on the development of memory and executive function. Front Behav Neurosci. 2009;3:16. [pmid: 19750200].
11 Bos KJ, Zeanah CH Jr, Smyke AT, et al. Stereotypies in children with a history of early institutional care. Arch Pediatr Adolesc Med. May. 2010;164(5):406-11. [pmid: 20439790].
12 Fox NA, Almas AN, Degnan KA, et al. The effects of severe psychosocial deprivation and foster care intervention on cognitive development at 8 years of age: findings from the Bucharest Early Intervention Project. J Child Psychol Psychiatry. Sep. 2011;52(9):919-28. [pmid: 21244422].
13 Ghera MM, Marshall PJ, Fox NA, et al. The effects of foster care intervention on socially deprived institutionalized children’s attention and positive affect: results from the BEIP study. J Child Psychol Psychiatry. Mar. 2009;50(3):246-53. [pmid: 19309327].
14 Johnson DE, Guthrie D, Smyke AT, et al. Growth and associations between auxology, caregiving environment, and cognition in socially deprived Romanian children randomized to foster vs ongoing institutional care. Arch Pediatr Adolesc Med. Jun. 2010;164(6):507-16. [pmid: 20368481].
15 McDermott JM, Westerlund A, Zeanah CH, et al. Early adversity and neural correlates of executive function: Implications for academic adjustment. Dev Cog Neurosci. 2012;2(Suppl 1):S59-S66. 2012-04022-007.
16 McLaughlin KA, Fox NA, Zeanah CH, et al. Adverse rearing environments and neural development in children: the development of frontal electroencephalogram asymmetry. Biol Psychiatry. Dec. 1. 2011;70(11):1008-15. [pmid: 21962332].
17 McLaughlin KA, Zeanah CH, Fox NA, et al. Attachment security as a mechanism linking foster care placement to improved mental health outcomes in previously institutionalized children. J Child Psychol Psychiatry. Jan. 2012;53(1):46-55. [pmid: 21733136].
18 Nelson CA 3rd, Zeanah CH, Fox NA, et al. Cognitive recovery in socially deprived young children: the Bucharest Early Intervention Project. Science. Dec. 21. 2007;318(5858):1937-40. [pmid: 18096809].
19 Smyke AT, Zeanah CH Jr, Fox NA, et al. A new model of foster care for young children: the Bucharest early intervention project. Child Adolesc Psychiatr Clin N Am. Jul. 2009;18(3):721-34. [pmid: 19486847].
20 Windsor J, Benigno JP, Wing CA, et al. Effect of foster care on young children’s language learning. Child Dev. Jul–Aug. 2011;82(4):1040-6. [pmid: 21679171].
21 Zeanah CH, Egger HL, Smyke AT, et al. Institutional rearing and psychiatric disorders in Romanian preschool children. Am J Psychiatry. Jul. 2009;166(7):777-85. [pmid: 19487394].
22 Marshall PJ, Reeb BC, Fox NA, et al. Effects of early intervention on EEG power and coherence in previously institutionalized children in Romania. Dev Psychopathol. Summer. 2008;20(3):861-80. [pmid: 18606035].
23 Cicchetti D, Rogosch FA, Toth SL. Fostering secure attachment in infants in maltreating families through preventive interventions. Dev Psychopathol. Summer. 2006;18(3):623-49. [pmid: 17152394].
24 Toth SL, Maughan A, Manly JT, et al. The relative efficacy of two interventions in altering maltreated preschool children’s representational models: implications for attachment theory. Dev Psychopathol. Fall. 2002;14(4):877-908. [pmid: 12549708].
25 Runyon MK, Deblinger E, Steer RA. Group Cognitive Behavioral Treatment for Parents and Children At-Risk for Physical Abuse: An Initial Study. Child Fam Behav Ther. 2010;32(3):196-218. WOS:000281079800002.
26 Jaberghaderi N, Greenwald R, Rubin A, et al. A comparison of CBT and EMDR for sexually-abused Iranian girls. Clin Psychol Psychother. 2004;11:358-68.
27 Taussig HN, Culhane SE. Impact of a mentoring and skills group program on mental health outcomes for maltreated children in foster care. Arch Pediatr Adolesc Med. Aug. 2010;164(8):739-46. [pmid: 20679165].
28 Taussig HN, Culhane SE, Garrido E, et al. RCT of a Mentoring and Skills Group Program: Placement and Permanency Outcomes for Foster Youth. Pediatrics. Jul. 2012;130(1):e33-9. [pmid: 22689870].
29 Trowell J, Kolvin I, Weeramanthri T, et al. Psychotherapy for sexually abused girls: psychopathological outcome findings and patterns of change. Br J Psychiatry. Mar. 2002;180:234-47. [pmid: 11872516].
30 McGain B, McKinzey RK. The efficacy of group treatment in sexually abused girls. Child Abuse Negl. Sep. 1995;19(9):1157-69. [pmid: 8528821].
31 Linares LO, Montalto D, Li M, et al. A promising parenting intervention in foster care. J Consult Clin Psychol. Feb. 2006;74(1):32-41. [pmid: 16551141].
32 Chamberlain P, Price J, Leve LD, et al. Prevention of behavior problems for children in foster care: outcomes and mediation effects. Prev Sci. Mar. 2008;9(1):17-27. [pmid: 18185995].
33 Price JM, Chamberlain P, Landsverk J, et al. Effects of a foster parent training intervention on placement changes of children in foster care. Child Maltreat. Feb. 2008;13(1):64-75. ISI:000252471700006. [pmid: 18174349].
34 Kim HK, Leve LD. Substance use and delinquency among middle school girls in foster care: a three-year follow-up of a randomized controlled trial. J Consult Clin Psychol. Dec. 2011;79(6):740-50. [pmid: 22004305].
35 Smith DK, Leve LD, Chamberlain P. Preventing internalizing and externalizing problems in girls in foster care as they enter middle school: Impact of an intervention. Prevention Science. Sep. 2011;12(3):269-77. [pmid: 21475990].
36 Fisher PA, Burraston B, Pears K. The early intervention foster care program: permanent placement outcomes from a randomized trial. Child Maltreat. Feb. 2005;10(1):61-71. [pmid: 15611327].
37 Fisher PA, Stoolmiller M, Gunnar MR, et al. Effects of a therapeutic intervention for foster preschoolers on diurnal cortisol activity. Psychoneuroendocrinology. Sep–Nov. 2007;32(8–10):892-905. [pmid: 17656028].
38 Fisher PA, Kim HK. Intervention effects on foster preschoolers’ attachment-related behaviors from a randomized trial. Prev Sci. Jun. 2007;8(2):161-70. [pmid: 17340186].
39 Fisher PA, Stoolmiller M. Intervention effects on foster parent stress: associations with child cortisol levels. Dev Psychopathol. Summer. 2008;20(3):1003-21. [pmid: 18606041].
40 Fisher PA, Kim HK, Pears KC. Effects of multidimensional treatment foster care for preschoolers (MTFC-P) on reducing permanent placement failures among children with placement instability. Child Youth Serv Rev. May. 2009;31(5):541-6. [pmid: 19430545].
41 Fisher PA, Van Ryzin MJ, Gunnar MR. Mitigating HPA axis dysregulation associated with placement changes in foster care. Psychoneuroendocrinology. May. 2011;36(4):531-9. [pmid: 20888698].
42 Bruce J, McDermott JM, Fisher PA, et al. Using behavioral and electrophysiological measures to assess the effects of a preventive intervention: a preliminary study with preschool-aged foster children. Prev Sci. Jun. 2009;10(2):129-40. [pmid: 19030992].
43 Zeanah CH, Larrieu JA, Heller SS, et al. Evaluation of a preventive intervention for maltreated infants and toddlers in foster care. J Am Acad Child Adolesc Psychiatry. 2001:214-21. [pmid: 11211370].
44 MacMillan HL, Thomas BH, Jamieson E, et al. Effectiveness of home visitation by public-health nurses in prevention of the recurrence of child physical abuse and neglect: a randomised controlled trial. Lancet. May. 21–27. 2005;365(9473):1786-93. [pmid: 15910951].
45 Chaffin M, Silovsky JF, Funderburk B, et al. Parent-child interaction therapy with physically abusive parents: efficacy for reducing future abuse reports. J Consult Clin Psychol. Jun. 2004;72(3):500-10. [pmid: 15279533].
46 Chaffin M, Valle LA, Funderburk B, et al. A motivational intervention can improve retention in PCIT for low-motivation child welfare clients. Child Maltreat. Nov. 2009;14(4):356-68. [pmid: 19258303].
47 Chaffin M, Funderburk B, Bard D, et al. A combined motivation and Parent-Child Interaction Therapy package reduces child welfare recidivism in a randomized dismantling field trial. J Consult Clin Psychol. Feb. 2011;79(1):84-95. [pmid: 21171738].
48 Chaffin M, Hecht D, Bard D, et al. A statewide trial of the SafeCare home-based services model with parents in Child Protective Services. Pediatrics. Mar. 2012;129(3):509-15. [pmid: 22351883].
49 Cohen JA, Mannarino AP. A treatment outcome study for sexually abused preschool children: initial findings. J Am Acad Child Adolesc Psychiatry. Jan. 1996;35(1):42-50. [pmid: 8567611].
50 Cohen JA, Deblinger E, Mannarino AP, et al. A multisite, randomized controlled trial for children with sexual abuse-related PTSD symptoms. J Am Acad Child Adolesc Psychiatry. Apr. 2004;43(4):393-402. [pmid: 15187799].
51 Deblinger E, Stauffer LB, Steer RA. Comparative efficacies of supportive and cognitive behavioral group therapies for young children who have been sexually abused and their nonoffending mothers. Child Maltreat. Nov. 2001;6(4):332-43. [pmid: 11675816].
52 Jinich S, Litrownik AJ. Coping with sexual abuse: development and evaluation of a videotape intervention for nonoffending parents. Child Abuse Negl. Feb. 1999;23(2):175-90. [pmid: 10075186].