# Risk of Bias Tables

Table D-1 Risk of bias assessment questions

Abbreviated Criteria in Table | Full Question | Type of Bias Assessed
Similar at baseline: | Were groups similar at baseline? | Selection bias
Fidelity: | Were measures taken to ensure intervention fidelity? | Performance bias
Assessor blinded | Were outcome assessors unaware of which intervention the participants received (i.e., blinded)? | Detection bias
All outcomes included: | Are all prespecified outcomes reported in the results? | Reporting bias
Measures equally applied | Were outcome measures equally applied? | Detection bias
Attrition reported: | Do study authors report either attrition statistic or that all participants who started the study completed the study? | Attrition bias
Attrition >= 30% | What was the overall attrition for the study ≥ 30%? | Attrition bias
Differential attrition >= 15% | Was the differential attrition between groups ≥ 15%? | Attrition bias
Questions for RCTs Only Randomization Adequate | Was randomization adequate? | Selection bias
Allocation concealment | Was the intervention/treatment allocation concealed? | Selection bias
ITT analysis | Did investigators use an ITT analysis? | Attrition bias
Questions for Nonrandomized Trials and Observational Studies Prospective | Is the study design prospective? | Detection bias
Same source population | Were groups recruited from the same source population? | Selection bias
I/E criteria | Were inclusion and exclusion criteria equally applied in both groups? | Selection bias
Control for difference | Were differences between groups taken into account in the statistical analysis? | Confounding

Table D-2 Risk of bias rating summary

| Design | Similar at Baseline | Fidelity | Assessors Blind | All outcomes Included | Measure Equally Applied | Attrition Reported | Attrition >= 30% | Differential Attrition >= 15% | Randomization Adequate | Allocation Concealment | ITT Analysis | Prospective | Same Source Population | I/E Criteria | Control for Differences | Rating
Berliner, 1996^1^ | RCT | Y | Y | U | Y | Y | Y | Y | U | U | U | N | NA | NA | NA | NA | H
Bernard, 2012^2^ | RCT | Y | Y | Y | Y | Y | N | U | U | U | U | U | NA | NA | NA | NA | M
Bos, 2009^3^ | RCT | N | U | U | Y | Y | N | U | U | U | U | N | NA | NA | NA | NA | M
Bos, 2010^4^ | RCT | Y | U | U | Y | Y | Y | N | N | U | U | Y | NA | NA | NA | NA | M
Bruce, 2009^5^ | RCT | U | U | U | Y | Y | N | U | U | U | U | N | NA | NA | NA | NA | M
Celano, 1996^6^ | RCT | Y | Y | Y | Y | Y | Y | Y | Y | U | U | N | NA | NA | NA | NA | H
Chaffin, 2004^7^ | RCT | Y | Y | U | Y | Y | Y | U | U | U | U | Y | NA | NA | NA | NA | M
Chaffin, 2009^8^ | RCT | Y | Y | U | Y | Y | Y | N | N | Y | U | Y | NA | NA | NA | NA | L
Chaffin, 2011^9^ | RCT | Y | Y | U | Y | Y | Y | N | N | Y | U | Y | NA | NA | NA | NA | L
Chaffin, 2012^10^ | RCT | Y | Y | Y | Y | Y | Y | N | N | U | U | N | NA | NA | NA | NA | L
Chamberlain, 2008^11^ | RCT | Y | Y | U | Y | Y | Y | N | U | U | U | N | NA | NA | NA | NA | M
Cicchetti, 2006^12^ | RCT | U | Y | U | Y | Y | Y | N | N | U | U | Y | NA | NA | NA | NA | M
Cohen, 1996^13^ | RCT | U | Y | U | Y | Y | Y | N | U | U | U | N | NA | NA | NA | NA | M
Cohen, 1997^14^ | RCT | N | Y | U | Y | Y | Y | Y | U | Y | Y | N | NA | NA | NA | NA | H
Cohen, 2004^15^ | RCT | Y | Y | Y | Y | Y | Y | N | N | U | U | Y | NA | NA | NA | NA | L
Deblinger, 2001^16^ | RCT | Y | Y | N | Y | Y | Y | N | U | U | U | N | NA | NA | NA | NA | M
Deblinger, 2006^17^ | RCT | U | Y | U | Y | Y | Y | Y | N | U | U | N | NA | NA | NA | NA | H
Dozier, unpublished A18 | RCT | Y | Y | Y | Y | Y | N | U | U | U | U | U | NA | NA | NA | NA | M
Dozier, unpublished B19 | RCT | U | Y | U | Y | Y | N | U | U | U | U | N | NA | NA | NA | NA | M
Dozier, 2006^20^ | RCT | Y | Y | Y | N | Y | N | U | U | U | U | U | NA | NA | NA | NA | M
Dozier, 2008^21^ | RCT | N | Y | Y | Y | Y | N | U | U | U | U | N | NA | NA | NA | NA | M
Dozier, 2009^22^ | RCT | Y | Y | Y | Y | Y | N | U | U | U | U | N | NA | NA | NA | NA | M
Fisher, 2000^23^ | PC | N | U | U | Y | Y | N | U | U | NA | NA | NA | Y | N | N | N | H
Fisher, 2005^24^ | RCT | Y | Y | U | Y | Y | U | U | U | U | U | U | NA | NA | NA | NA | M
Fisher, 2007a25 | RCT | Y | Y | U | Y | Y | U | U | U | U | U | U | NA | NA | NA | NA | M
Fisher, 2007b26 | RCT | Y | U | Y | Y | Y | U | U | U | U | U | U | NA | NA | NA | NA | M
Fisher, 2008^27^ | RCT | Y | Y | Y | Y | Y | U | U | U | U | U | U | NA | NA | NA | NA | M
Fisher, 2009^28^ | RCT | N | Y | U | Y | Y | N | U | U | U | U | U | NA | NA | NA | NA | M
Fisher, 2011a29 | RCT | Y | Y | U | Y | Y | Y | N | U | Y | U | N | NA | NA | NA | NA | M
Fisher, 2011b30 | RCT | U | U | U | Y | U | Y | N | Y | U | U | N | NA | NA | NA | NA | H
Fox, 2011^31^ | RCT | U | U | U | Y | Y | Y | N | N | U | U | N | NA | NA | NA | NA | M
Gershater-Molko, 2002^32^ | CC | U | U | U | Y | Y | NA | NA | NA | NA | NA | NA | N | N | U | N | H
Ghera, 2009^33^ | RCT | Y | U | Y | Y | Y | Y | N | N | U | U | Y | NA | NA | NA | NA | M
Grayston, 1995^34^ | PC | U | U | U | Y | Y | Y | N | Y | NA | NA | NA | Y | Y | Y | N | H
Jaberghaderi, 2004^35^ | RCT | Y | U | Y | Y | Y | Y | N | N | Y | N | N | NA | NA | NA | NA | M
Jinich, 1999^36^ | RCT | Y | Y | Y | Y | Y | Y | U | U | U | Y | N | NA | NA | NA | NA | M
Johnson, 2010^37^ | RCT | Y | U | U | Y | Y | Y | N | N | U | U | N | NA | NA | NA | NA | M
Jouriles, 2010^38^ | RCT | Y | Y | Y | Y | Y | Y | N | Y | Y | U | N | NA | NA | NA | NA | H
Kim, 2011^39^ | RCT | Y | Y | Y | Y | Y | Y | N | N | Y | Y | Y | NA | NA | NA | NA | L
Leathers, 2011^40^ | PC | U | Y | U | Y | Y | Y | Y | Y | NA | NA | NA | Y | Y | U | Y | H
Letarte, 2010^41^ | PC | Y | Y | U | Y | N | Y | N | Y | NA | NA | NA | Y | Y | Y | N | H
Lewis-Morrarty, 2012^42^ | RCT | Y | U | U | Y | U | N | U | U | U | N | N | NA | NA | NA | NA | M
Linares, 2006^43^ | RCT | N | Y | Y | Y | Y | Y | N | N | U | U | Y | NA | NA | NA | NA | L
MacMillain, 2005^44^ | RCT | Y | U | Y | Y | Y | Y | N | N | Y | Y | Y | NA | NA | NA | NA | L
Marshall, 2008^45^ | RCT | Y | N | U | Y | Y | Y | U | U | U | U | Y | NA | NA | NA | NA | M
McDermott, 2012^46^ | RCT | U | U | U | Y | Y | Y | N | N | U | U | N | NA | NA | NA | NA | M
McGain, 1995^47^ | NCT | U | U | U | Y | Y | N | U | U | NA | NA | NA | Y | Y | U | N | M
McLaughlin, 2011^48^ | RCT | Y | U | U | Y | Y | Y | N | N | U | U | N | NA | NA | NA | NA | M
McLaughlin, 2012^49^ | RCT | Y | U | Y | Y | Y | Y | N | N | U | U | Y | NA | NA | NA | NA | M
Meezan, 1998a50 | RCT | U | U | U | Y | Y | Y | Y | Y | U | U | N | NA | NA | NA | NA | H
Meezan, 1998b51 | RCT | U | U | U | Y | Y | Y | Y | Y | U | U | N | NA | NA | NA | NA | H
Moss, 2011^52^ | RCT | Y | Y | Y | Y | Y | Y | N | N | Y | U | N | NA | NA | NA | NA | M
Nelson, 2007^53^ | RCT | Y | U | U | Y | Y | Y | N | N | U | U | Y | NA | NA | NA | NA | M
Nilsen, 2007^54^ | PC | N | U | U | Y | Y | N | U | U | NA | NA | NA | Y | Y | N | N | H
Nolan, 2002^55^ | PC | Y | U | U | Y | Y | Y | N | Y | NA | NA | NA | Y | Y | U | N | H
Price, 2008^56^ | RCT | Y | Y | U | Y | Y | N | U | U | U | U | U | NA | NA | NA | NA | M
Reams, 1994^57^ | RCT | N | U | Y | Y | Y | N | U | U | U | U | U | NA | NA | NA | NA | H
Runyon, 2010^58^ | RCT | N | Y | Y | Y | Y | Y | N | N | Y | Y | N | NA | NA | NA | NA | M
Smith, 2011^59^ | RCT | Y | Y | Y | Y | Y | N | U | U | Y | Y | U | NA | NA | NA | NA | M
Smyke, 2010 60 | RCT | Y | U | Y | Y | Y | Y | N | N | U | U | Y | NA | NA | NA | NA | M
Sprang, 2009^61^ | RCT | Y | Y | N | Y | Y | Y | N | N | U | N | Y | NA | NA | NA | NA | M
Taussig, 2010^62^ | RCT | N | Y | Y | Y | Y | Y | N | N | Y | U | Y | NA | NA | NA | NA | L
Taussig, 2012^63^ | RCT | N | Y | Y | Y | Y | Y | N | N | Y | U | Y | NA | NA | NA | NA | L
Toth, 2002^64^ | RCT | N | Y | Y | Y | Y | Y | N | N | U | U | N | NA | NA | NA | NA | M
Trowell, 2002^65^ | RCT | Y | Y | U | N | Y | Y | N | N | U | U | Y | NA | NA | NA | NA | M
Weikert, 2012^66^ | PC | N | U | U | Y | Y | Y | N | U | NA | NA | NA | Y | Y | N | N | H
Windsor, 2011^67^ | RCT | U | U | U | Y | Y | N | U | U | U | U | Y | NA | NA | NA | NA | M
Zeanah, 2001^68^ | NCC | Y | U | N | Y | Y | N | U | U | NA | NA | NA | N | N | Y | Y | M
Zeanah, 2009^69^ | RCT | Y | U | U | Y | Y | Y | N | N | U | U | Y | NA | NA | NA | NA | M

Abbreviations: CC = case control; H = High risk of bias, M = Medium risk of bias, L = Low risk of bias; N = No, NA = Not Applicable, PC = prospective control; RCT = randomized controlled trial; U = Unknown (not reported or unclear), Y = Yes

Table D-3 Studies rated high risk of bias with primary reason for rating

Study | Design | Primary Reasons for High Risk of Bias Rating
Berliner et al., 1996^1^ | RCT | High overall attrition
Celano et al., 1996^6^ | RCT | High overall attrition, differential attrition
Cohen et al., 1997^14^ | RCT | High overall attrition
Deblinger et al., 2006,^17^ | RCT | High overall attrition
Fisher et al., 2000^23^ | PC | Differences in inclusion criteria
Fisher, 2011b30 | RCT | Differential attrition
Grayston & De Luca, 1995 34 | PC | Differential attrition
Gershater-Molko, 2002^32^ | CC | High potential for differences at baseline
Jouriles, 2010^38^ | RCT | Differential attrition
Leathers et al., 2011^40^ | RCT | High overall attrition, differential attrition
Letarte, 2010^41^ | PC | Differential attrition
Meezan & O’ Keefe, 1998^50^ | RCT | High overall attrition, differential attrition
Meezan & O’ Keefe, 1998^51^ | RCT | High overall attrition, differential attrition
Nilsen, 2007^54^ | PC | Differences in inclusion criteria
Nolan, 2002^55^ | PC | Differential attrition
Reams, 1994 57 | RCT | Differences at baseline

Abbreviations: CC = case control; PC = prospective control; RCT = randomized controlled trial.

## References

1 Berliner L, Saunders BE. Treating fear and anxiety in sexually abused children: results of a controlled 2-year follow-up study. Child Maltreat. 1996;I:194-309.
2 Bernard K, Dozier M, Bick J, et al. Enhancing attachment organization among maltreated children: results of a randomized clinical trial. Child Dev. Mar. 2012;83(2):623-36. [pmid: 22239483].
3 Bos KJ, Fox N, Zeanah CH, et al. Effects of early psychosocial deprivation on the development of memory and executive function. Front Behav Neurosci. 2009;3:16. [pmid: 19750200].
4 Bos KJ, Zeanah CH Jr, Smyke AT, et al. Stereotypies in children with a history of early institutional care. Arch Pediatr Adolesc Med. May. 2010;164(5):406-11. [pmid: 20439790].
5 Bruce J, McDermott JM, Fisher PA, et al. Using behavioral and electrophysiological measures to assess the effects of a preventive intervention: a preliminary study with preschool-aged foster children. Prev Sci. Jun. 2009;10(2):129-40. [pmid: 19030992].
6 Celano M, Hazzard A, Webb C, et al. Treatment of traumagenic beliefs among sexually abused girls and their mothers: an evaluation study. J Abnorm Child Psychol. Feb. 1996;24(1):1-17. [pmid: 8833025].
7 Chaffin M, Silovsky JF, Funderburk B, et al. Parent-child interaction therapy with physically abusive parents: efficacy for reducing future abuse reports. J Consult Clin Psychol. Jun. 2004;72(3):500-10. [pmid: 15279533].
8 Chaffin M, Valle LA, Funderburk B, et al. A motivational intervention can improve retention in PCIT for low-motivation child welfare clients. Child Maltreat. Nov. 2009;14(4):356-68. [pmid: 19258303].
9 Chaffin M, Funderburk B, Bard D, et al. A combined motivation and parent-child interaction therapy package reduces child welfare recidivism in a randomized dismantling field trial. J Consult Clin Psychol. Feb. 2011;79(1):84-95. [pmid: 21171738].
10 Chaffin M, Hecht D, Bard D, et al. A statewide trial of the SafeCare home-based services model with parents in Child Protective Services. Pediatrics. Mar. 2012;129(3):509-15. [pmid: 22351883].
11 Chamberlain P, Price J, Leve LD, et al. Prevention of behavior problems for children in foster care: outcomes and mediation effects. Prev Sci. Mar. 2008;9(1):17-27. [pmid: 18185995].
12 Cicchetti D, Rogosch FA, Toth SL. Fostering secure attachment in infants in maltreating families through preventive interventions. Dev Psychopathol. Summer. 2006;18(3):623-49. [pmid: 17152394].
13 Cohen JA, Mannarino AP. A treatment outcome study for sexually abused preschool children: initial findings. J Am Acad Child Adolesc Psychiatry. Jan. 1996;35(1):42-50. [pmid: 8567611].
14 Cohen JA, Mannarino AP. A treatment study for sexually abused preschool children: outcome during a one-year follow-up. J Am Acad Child Adolesc Psychiatry. Sep. 1997;36(9):1228-35. [pmid: 9291724].
15 Cohen JA, Deblinger E, Mannarino AP, et al. A multisite, randomized controlled trial for children with sexual abuse-related PTSD symptoms. J Am Acad Child Adolesc Psychiatry. Apr. 2004;43(4):393-402. [pmid: 15187799].
16 Deblinger E, Stauffer LB, Steer RA. Comparative efficacies of supportive and cognitive behavioral group therapies for young children who have been sexually abused and their nonoffending mothers. Child Maltreat. Nov. 2001;6(4):332-43. [pmid: 11675816].
17 Deblinger E, Mannarino AP, Cohen JA, et al. A follow-up study of a multisite, randomized, controlled trial for children with sexual abuse-related PTSD symptoms. J Am Acad Child Adolesc Psychiatry. Dec. 2006;45(12):1474-84. [pmid: 17135993].
18 Dozier M, Bernard K, Ross E, et al. The Effects of an Attachment-Based Intervention on Children’s Expression of Negative Affect in a Challenging Task. unpublished A.
19 Dozier M, Bernard K, Bick J, et al. Normalizing Neglected Children’s Blunted Diurnal Cortisol Rhythms: The Effects of an Early Intervention. unpublished B.
20 Dozier M, Peloso E, Lindhiem O, et al. Developing evidence-based interventions for foster children: An example of a randomized clinical trial with infants and toddlers. J Soc Issues. 2006;62(4):767-85. ISI:000241562500006.
21 Dozier M, Peloso E, Lewis E, et al. Effects of an attachment-based intervention on the cortisol production of infants and toddlers in foster care. Dev Psychopathol. Summer. 2008;20(3):845-59. [pmid: 18606034].
22 Dozier M, Lindhiem O, Lewis E, et al. Effects of a foster parent training program on young children’s attachment behaviors: Preliminary evidence from a randomized clinical trial. Child Adolesc Soc Work J. Aug. 2009;26(4):321-32. [pmid: 22065891].
23 Fisher PA, Gunnar MR, Chamberlain P, et al. Preventive intervention for maltreated preschool children: impact on children’s behavior, neuroendocrine activity, and foster parent functioning. J Am Acad Child Adolesc Psychiatry. Nov. 2000;39(11):1356-64. [pmid: 11068890].
24 Fisher PA, Burraston B, Pears K. The early intervention foster care program: permanent placement outcomes from a randomized trial. Child Maltreat. Feb. 2005;10(1):61-71. [pmid: 15611327].
25 Fisher PA, Kim HK. Intervention effects on foster preschoolers’ attachment-related behaviors from a randomized trial. Prev Sci. Jun. 2007;8(2):161-70. [pmid: 17340186].
26 Fisher PA, Stoolmiller M, Gunnar MR, et al. Effects of a therapeutic intervention for foster preschoolers on diurnal cortisol activity. Psychoneuroendocrinology. Sep–Nov. 2007;32(8–10):892-905. [pmid: 17656028].
27 Fisher PA, Stoolmiller M. Intervention effects on foster parent stress: associations with child cortisol levels. Dev Psychopathol. Summer. 2008;20(3):1003-21. [pmid: 18606041].
28 Fisher PA, Kim HK, Pears KC. Effects of multidimensional treatment foster care for preschoolers (MTFC-P) on reducing permanent placement failures among children with placement instability. Child Youth Serv Rev. May. 2009;31(5):541-6. [pmid: 19430545].
29 Fisher PA, Van Ryzin MJ, Gunnar MR. Mitigating HPA axis dysregulation associated with placement changes in foster care. Psychoneuroendocrinology. May. 2011;36(4):531-9. [pmid: 20888698].
30 Fisher PA, Stoolmiller M, Mannering AM, et al. Foster placement disruptions associated with problem behavior: Mitigating a threshold effect. J Consult Clin Psychol. Aug. 2011;79(4):481-7. [pmid: 21787051].
31 Fox NA, Almas AN, Degnan KA, et al. The effects of severe psychosocial deprivation and foster care intervention on cognitive development at 8 years of age: findings from the Bucharest Early Intervention Project. J Child Psychol Psychiatry. Sep. 2011;52(9):919-28. [pmid: 21244422].
32 Gershater-Molko RM, Lutzker JR, Wesch D. Using recidivism data to evaluate project safecare: teaching bonding, safety, and health care skills to parents. Child Maltreat. Aug. 2002;7(3):277-85. [pmid: 12139194].
33 Ghera MM, Marshall PJ, Fox NA, et al. The effects of foster care intervention on socially deprived institutionalized children’s attention and positive affect: results from the BEIP study. J Child Psychol Psychiatry. Mar. 2009;50(3):246-53. [pmid: 19309327].
34 Grayston AD, De Luca RV. Group therapy for boys who have experienced sexual abuse: Is it the treatment of choice? Journal of Child &. Adolescent Group Therapy. 1995;5(2):57-82. 1995-44671-001.
35 Jaberghaderi N, Greenwald R, Rubin A, et al. A comparison of CBT and EMDR for Sexually Abused Iranian girls. Clin Psychol Psychother. 2004;11:358-68.
36 Jinich S, Litrownik AJ. Coping with sexual abuse: development and evaluation of a videotape intervention for nonoffending parents. Child Abuse Negl. Feb. 1999;23(2):175-90. [pmid: 10075186].
37 Johnson DE, Guthrie D, Smyke AT, et al. Growth and associations between auxology, caregiving environment, and cognition in socially deprived Romanian children randomized to foster vs ongoing institutional care. Arch Pediatr Adolesc Med. Jun. 2010;164(6):507-16. [pmid: 20368481].
38 Jouriles EN, McDonald R, Rosenfield D, et al. Improving parenting in families referred for child maltreatment: a randomized controlled trial examining effects of Project Support. J Fam Psychol. Jun. 2010;24(3):328-38. [pmid: 20545406].
39 Kim HK, Leve LD. Substance use and delinquency among middle school girls in foster care: a three-year follow-up of a randomized controlled trial. J Consult Clin Psychol. Dec. 2011;79(6):740-50. [pmid: 22004305].
40 Leathers SJ, Spielfogel JE, McMeel LS, et al. Use of a parent management training intervention with urban foster parents: A pilot study. Child Youth Serv Rev. 2011;33(7):1270-9. 2011-05731-001. [pmid: 21686093].
41 Letarte MJ, Normandeau S, Allard J. Effectiveness of a parent training program “Incredible Years” in a child protection service. Child Abuse Negl. 2010:253-61. [pmid: 20356626].
42 Lewis-Morrarty E, Dozier M, Bernard K, et al. Cognitive flexibility and theory of mind outcomes among foster children: Preschool follow-up results of a randomized clinical trial. J Adolesc Health. August. 2012;51(2 Suppl):S17-S22. [pmid: 22794528].
43 Linares LO, Montalto D, Li M, et al. A promising parenting intervention in foster care. J Consult Clin Psychol. Feb. 2006;74(1):32-41. [pmid: 16551141].
44 MacMillan HL, Thomas BH, Jamieson E, et al. Effectiveness of home visitation by public-health nurses in prevention of the recurrence of child physical abuse and neglect: a randomised controlled trial. Lancet. May. 21–27. 2005;365(9473):1786-93. [pmid: 15910951].
45 Marshall PJ, Reeb BC, Fox NA, et al. Effects of early intervention on EEG power and coherence in previously institutionalized children in Romania. Dev Psychopathol. Summer. 2008;20(3):861-80. [pmid: 18606035].
46 McDermott JM, Westerlund A, Zeanah CH, et al. Early adversity and neural correlates of executive function: Implications for academic adjustment. Dev Cog Neurosci. 2012;2(Suppl 1):S59-S66. 2012-04022-007.
47 McGain B, McKinzey RK. The efficacy of group treatment in sexually abused girls. Child Abuse Negl. Sep. 1995;19(9):1157-69. [pmid: 8528821].
48 McLaughlin KA, Fox NA, Zeanah CH, et al. Adverse rearing environments and neural development in children: the development of frontal electroencephalogram asymmetry. Biol Psychiatry. Dec. 1. 2011;70(11):1008-15. [pmid: 21962332].
49 McLaughlin KA, Zeanah CH, Fox NA, et al. Attachment security as a mechanism linking foster care placement to improved mental health outcomes in previously institutionalized children. J Child Psychol Psychiatry. Jan. 2012;53(1):46-55. [pmid: 21733136].
50 Meezan W, O’Keefe M. Multifamily group therapy: Impact on family functioning and child behavior. J Contemp Hum Serv. Jan–Feb. 1998;79(1):32-44. ISI:000071455500007.
51 Meezan W, O’Keefe M. Evaluating the effectiveness of multifamily group therapy in child abuse and neglect. Res Soc Work Pract. 1998;8:330-53.
52 Moss E, Dubois-Comtois K, Cyr C, et al. Efficacy of a home-visiting intervention aimed at improving maternal sensitivity, child attachment, and behavioral outcomes for maltreated children: a randomized control trial. Dev Psychopathol. Feb. 2011;23(1):195-210. [pmid: 21262048].
53 Nelson CA 3rd, Zeanah CH, Fox NA, et al. Cognitive recovery in socially deprived young children: the Bucharest Early Intervention Project. Science. Dec. 21. 2007;318(5858):1937-40. [pmid: 18096809].
54 Nilsen W. Fostering futures: A preventive intervention program for school-age children in foster care. Clinical Child Psychology and Psychiatry. 2007;12(1):45-63. 2007-02365-004. [pmid: 17378079].
55 Nolan M, Carr A, Fitzpartrick C, et al. A comparison of two programmes for victims of child sexual abuse: A treatment outcome study. Child Abuse Review. 2002;11(2):103-23. 2002-02985-003.
56 Price JM, Chamberlain P, Landsverk J, et al. Effects of a foster parent training intervention on placement changes of children in foster care. Child Maltreat. Feb. 2008;13(1):64-75. ISI:000252471700006. [pmid: 18174349].
57 Reams R, Friedrich W. The efficacy of time-limited play therapy with maltreated preschoolers. J Clin Psychol. Nov. 1994;50(6):889-99. [pmid: 7896925].
58 Runyon MK, Deblinger E, Steer RA. Group Cognitive Behavioral Treatment for Parents and Children At-Risk for Physical Abuse: An Initial Study. Child Fam Behav Ther. 2010;32(3):196-218. WOS:000281079800002.
59 Smith DK, Leve LD, Chamberlain P. Preventing internalizing and externalizing problems in girls in foster care as they enter middle school: Impact of an intervention. Prevention Science. Sep. 2011;12(3):269-77. [pmid: 21475990].
60 Smyke AT, Zeanah CH, Fox NA, et al. Placement in foster care enhances quality of attachment among young institutionalized children. Child Dev. Jan–Feb. 2010;81(1):212-23. [pmid: 20331663].
61 Sprang G. The efficacy of a relational treatment for maltreated children and their families. Child Adolesc Ment Health. 2009;14(2):81-8. 2009-06028-005.
62 Taussig HN, Culhane SE. Impact of a mentoring and skills group program on mental health outcomes for maltreated children in foster care. Arch Pediatr Adolesc Med. Aug. 2010;164(8):739-46. [pmid: 20679165].
63 Taussig HN, Culhane SE, Garrido E, et al. RCT of a Mentoring and Skills Group Program: Placement and Permanency Outcomes for Foster Youth. Pediatrics. Jul. 2012;130(1):e33-9. [pmid: 22689870].
64 Toth SL, Maughan A, Manly JT, et al. The relative efficacy of two interventions in altering maltreated preschool children’s representational models: implications for attachment theory. Dev Psychopathol. Fall. 2002;14(4):877-908. [pmid: 12549708].
65 Trowell J, Kolvin I, Weeramanthri T, et al. Psychotherapy for sexually abused girls: psychopathological outcome findings and patterns of change. Br J Psychiatry. Mar. 2002;180:234-47. [pmid: 11872516].
66 Weikert P, Keene R, Bavolek SJ. The Florida Study: A Comparative Examination of the Effectiveness of the Nurturing Parenting Programs®. 2012. Available at: http://nurturingparenting.com/images/cmsfiles/the_florida_studywithappendicesabc.pdf. Accessed July 23, 2012.
67 Windsor J, Benigno JP, Wing CA, et al. Effect of foster care on young children’s language learning. Child Dev. Jul–Aug. 2011;82(4):1040-6. [pmid: 21679171].
68 Zeanah CH, Larrieu JA, Heller SS, et al. Evaluation of a preventive intervention for maltreated infants and toddlers in foster care. J Am Acad Child Adolesc Psychiatry. 2001:214-21. [pmid: 11211370].
69 Zeanah CH, Egger HL, Smyke AT, et al. Institutional rearing and psychiatric disorders in Romanian preschool children. Am J Psychiatry. Jul. 2009;166(7):777-85. [pmid: 19487394].