# Full Text Review Excludes

## Wrong Publication Type (N=100)

1 Al Eissa M, Almuneef M. Child abuse and neglect in Saudi Arabia: journey of recognition to implementation of national prevention strategies. Child Abuse Negl. Jan. 2010;34(1):28-33. [pmid: 20092895].
2 Bai Y, Wells R, Hillemeier MM. Coordination between child welfare agencies and mental health service providers, children’s service use, and outcomes. Child Abuse Negl. Jun. 2009;33(6):372-81. [pmid: 19473702].
3 Baumann BL, Kolko DJ. A comparison of abusive and nonabusive mothers of abused children. Child Maltreat. Nov. 2002;7(4):369-76. [pmid: 12408248].
4 Berlin M, Vinnerljung B, Hjern A. School performance in primary school and psychosocial problems in young adulthood among care leavers from long term foster care. Child Youth Serv Rev. Dec. 2011;33(12):2489-97. WOS:000298122800012.
5 Berrick JD, Young EW, Cohen E, et al. ‘I am the face of success’: Peer mentors in child welfare. Child Fam Soc Work. 2011;16(2):179-91. 2011-05923-006.
6 Blau GM, Whewell MC, Gullotta TP, et al. The prevention and treatment of child abuse in households of substance abusers: a research demonstration progress report. Child Welfare. Jan–Feb. 1994;73(1):83-94. [pmid: 8299411].
7 Bos K, Zeanah CH, Fox NA, et al. Psychiatric outcomes in young children with a history of institutionalization. Harv Rev Psychiatry. Jan–Feb. 2011;19(1):15-24. [pmid: 21250893].
8 Brent DA, Greenhill LL, Compton S, et al. The Treatment of Adolescent Suicide Attempters Study (TASA): Predictors of Suicidal Events in an Open Treatment Trial. J Am Acad Child Adolesc Psychiatry. Oct. 2009;48(10):987-96. WOS:000270196600005. [pmid: 19730274].
9 Brown EJ. Clinical characteristics and efficacious treatment of posttraumatic stress disorder in children and adolescents. Pediatr Ann. Feb. 2005;34(2):138-46. WOS:000226946200009. [pmid: 15768690].
10 Brown EJ. Correlates and treatment of stress disorder in children and adolescents. Psychiatr Ann. 2005;35(9):759-65. 2006-04163-007.
11 Brown GW, Malone P. Child head injuries: review of pattern from abusive and unintentional causes resulting in hospitalization. Alaska Med. Jan–Mar. 2003;45(1):9-13. [pmid: 12722522].
12 Carr A. Evidence-based practice in family therapy and systemic consultation: I: Child-focused problems. J Fam Ther. 2000;22(1):29-60. 2000-03019-003.
13 Chamberlain P, Brown CH, Saldana L. Observational measure of implementation progress in community based settings: The Stages of implementation completion (SIC). Implementation Science. Oct. 2011;6. WOS:000296497500001.
14 Chamberlain P, Price J, Reid J, et al. Cascading implementation of a foster and kinship parent intervention. Child Welfare. 2008;87(5):27-48. [pmid: 19402358].
15 Champion JD. Effect of abuse on self-perception of rural Mexican-American and non-Hispanic white adolescents. Arch Psychiatr Nurs. Feb. 1999;13(1):12-8. [pmid: 10069098].
16 Champion JD. Context of sexual risk behaviour among abused ethnic minority adolescent women. Int Nurs Rev. Mar. 2011;58(1):61-7. [pmid: 21281295].
17 Chung EK, Webb D, Clampet-Lundquist S, et al. A comparison of elevated blood lead levels among children living in foster care, their siblings, and the general population. Pediatrics. May. 2001;107(5):E81. [pmid: 11331731].
18 Cicchetti D, Curtis WJ. An event-related potential study of the processing of affective facial expressions in young children who experienced maltreatment during the first year of life. Dev Psychopathol. 2005;17(3):641-77. 2005-15937-005. [pmid: 16262986].
19 Cicchetti D, Rogosch FA, Toth SL. The effects of child maltreatment and polymorphisms of the serotonin transporter and dopamine D4 receptor genes on infant attachment and intervention efficacy. Dev Psychopathol. 2011;23(2):357-72. 2011-09487-002.
20 Cohen J, Mannarino AP. Disseminating and implementing trauma-focused CBT in community settings. Trauma Violence & Abuse. Oct. 2008;9(4):214-26. WOS:000259548100002.
21 Cohen JA. Pharmacologic treatments for childhood PTSD. Trauma, Violence, & Abuse: A Review Journal. 2001;2(2):155-71.
22 Cohen JA, Mannarino AP. Factors that mediate treatment outcome of sexually abused preschool children. J Am Acad Child Adolesc Psychiatry. Oct. 1996;35(10):1402-10. [pmid: 8885595].
23 Cohen JA, Mannarino AP, Murray LK, et al. Psychosocial interventions for maltreated and violence-exposed children. Journal of Social Issues. 2006;62(4):737-66. WOS:000241562500005.
24 Cohen JA, Mannarino AP, Zhitova AC, et al. Treating child abuse-related posttraumatic stress and comorbid substance abuse in adolescents. Child Abuse Negl. 2003;27(12):1345-65. 2003-10881-001. [pmid: 14644054].
25 Coleman-Cowger VH, Green BA, Clark TT. The impact of mental health issues, substance use, and exposure to victimization on pregnancy rates among a sample of youth with past-year foster care placement. Child Youth Serv Rev. Nov. 2011;33(11):2207-12. 2011-16608-001.
26 Coren E, Hossain R, Pardo Pardo J, et al. Interventions for promoting reintegration and reducing harmful behaviour and lifestyles in street-connected children and young people. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2012.
27 Dixon J. Obstacles to participation in education, employment and training for young people leaving care. Social Work and Social Sciences Review. 2007;13(2):18-34. 2008-14156-003.
28 Dorahy MJ, Corry M, Shannon M, et al. Complex PTSD, interpersonal trauma and relational consequences: findings from a treatment-receiving Northern Irish sample. J Affect Disord. Jan. 2009;112(1–3):71-80. [pmid: 18511130].
29 Dowdell EB, Cavanaugh DJ. Caregivers of victimized children: differences between biological parents and foster caregivers. J Psychosoc Nurs Ment Health Serv. Jun. 2009;47(6):28-36. [pmid: 19585801].
30 Dozier M, Bernard K, Bick J. Intervening with foster parents to enhance biobehavioral outcomes among infants and toddlers. Zero to Three Bulletin. 2011.
31 Dozier M, Bick J, Bernard K. Attachment-based treatment for young, vulnerable children. Osofsky J, editor. Young children and trauma: Intervention and treatment. New York, NY. Guilford. 2011.
32 Dozier M, Rutter M. Attachment issues in foster care and adoption. Cassidy J, Shaver PR, editors. Handbook of attachment theory and research. New York, NY. Guilford. 2008.
33 Drake B, Jonson-Reid M, Sapokaite L. Rereporting of child maltreatment: Does participation in other public sector services moderate the likelihood of a second maltreatment report?. Child Abuse Negl. 2006;30(11):1201-26. 2006-22429-006. [pmid: 17112587].
34 Drury SS, Theall KP, Smyke AT, et al. Modification of depression by COMT val158met polymorphism in children exposed to early severe psychosocial deprivation. Child Abuse Negl. Jun. 2010;34(6):387-95. [pmid: 20403637].
35 Fernandez E. Unravelling emotional, behavioural and educational outcomes in a longitudinal study of children in foster-care. Br J Soc Work. 2008;38(7):1283-301. 2008-15974-002.
36 Finkelhor D, Berliner L. Research on the treatment of sexually abused children: a review and recommendations. J Am Acad Child Adolesc Psychiatry. Nov. 1995;34(11):1408-23. [pmid: 8543508].
37 Fisher PA, Gunnar MR, Dozier M, et al. Effects of therapeutic interventions for foster children on behavioral problems, caregiver attachment, and stress regulatory neural systems. Ann N Y Acad Sci. Dec. 2006;1094:215-25. [pmid: 17347353].
38 Fluke JD, Shusterman GR, Hollinshead DM, et al. Longitudinal analysis of repeated child abuse reporting and victimization: multistate analysis of associated factors. Child Maltreat. Feb. 2008;13(1):76-88. [pmid: 18174350].
39 Frazier KN, West-Olatunji CA, Juste SS, et al. Transgenerational trauma and child sexual abuse: Reconceptualizing cases involving young survivors of CSA. J Ment Health Counsel. 2009;31(1):22-33. 2009-00040-003.
40 Garrido EF, Taussig HN, Culhane SE, et al. Attention problems mediate the association between severity of physical abuse and aggressive behavior in a sample of maltreated early adolescents. J Early Adolesc. 2011;31(5):714-34. 2011-21178-006. First Author & Affiliation: Garrido, Edward F. [pmid: 21966081].
41 Hahn RA, Mercy J, Bilukha O, et al. Assessing home visiting programs to prevent child abuse: taking silver and bronze along with gold. Child Abuse Negl. Mar. 2005;29(3):215-8. author reply 41–9. [pmid: 15820536].
42 Hall DK, Mathews F, Pearce J. Factors associated with sexual behavior problems in young sexually abused children. Child Abuse Negl. Oct. 1998;22(10):1045-63. [pmid: 9793727].
43 Harmon RJ, Riggs PD. Clonidine for posttraumatic stress disorder in preschool children. J Am Acad Child Adolesc Psychiatry. Sep. 1996;35(9):1247-9. [pmid: 8824068].
44 Hecht D, Silovsky J, Chaffin M, et al. SafeCare: An evidence-based approach to prevent child neglect. The APSAC Advisor. 2008:14-7.
45 Hiebert-Murphy D, De Luca RV, Runtz M. Group treatment for sexually abused girls: Evaluating outcome. Fam Soc. 1992;73:205-13.
46 Hill CM, Watkins J. Statutory health assessments for looked-after children: what do they achieve?. Child Care Health Dev. Jan. 2003;29(1):3-13. [pmid: 12534562].
47 Hoier TS. The course of treatment of a sexually abused child: A single-case study. Behavioral Assessment. 1991;13:385-98.
48 Jonson-Reid M. Exploring the relationship between child welfare intervention and juvenile corrections involvement. Am J Orthopsychiatry. Oct. 2002;72(4):559-76. [pmid: 15792041].
49 Kaplan SJ, Pelcovitz D, Labruna V. Child and adolescent abuse and neglect research: a review of the past 10 years. Part I: Physical and emotional abuse and neglect. J Am Acad Child Adolesc Psychiatry. Oct. 1999;38(10):1214-22. [pmid: 10517053].
50 Kinard EM. Services for maltreated children: variations by maltreatment characteristics. Child Welfare. Jul–Aug. 2002;81(4):617-45. [pmid: 12109603].
51 Kliman G. Methods for Maximizing Good Effects of Foster Care: Evidence-Based Strategies to Prevent Discontinuities of Foster Care and Raise IQ. Inter J Appl Psychoanalyt Stud. 2006;3(1):4-16. 2006-23409-002.
52 Koenen KC, Moffitt TE, Caspi A, et al. Domestic violence is associated with environmental suppression of IQ in young children. Dev Psychopathol. Spring. 2003;15(2):297-311. [pmid: 12931829].
53 Kolko DJ, Baumann BL, Caldwell N. Child abuse victims’ involvement in community agency treatment: service correlates, short-term outcomes, and relationship to reabuse. Child Maltreat. Nov. 2003;8(4):273-87. [pmid: 14604175].
54 Lagerberg D. Secondary prevention in child health: effects of psychological intervention, particularly home visitation, on children’s development and other outcome variables. Acta Paediatr Suppl. Sep. 2000;89(434):43-52. [pmid: 11055317].
55 Lee B, Barth RP. Residential education: An emerging resource for improving educational outcomes for youth in foster care?. Child Youth Serv Rev. 2009;31(1):155-60. 2008-17864-020.
56 Lewis E, Dozier M, Knights M, et al. Intervening with foster infants’ foster parents: Attachment and biobehavioral catch-up. Lee RE, Whiting J, editors. Handbook of relational therapy for foster children and their families. Washington, DC. Child Welfare League of America. 2008:269-92.
57 Libby AM, Orton HD, Barth RP, et al. Alcohol, drug, and mental health specialty treatment services and race/ethnicity: a national study of children and families involved with child welfare. Am J Public Health. Apr. 2006;96(4):628-31. [pmid: 16507729].
58 Lindell C, Svedin CG. Mental health services provided for physically abused children in Sweden. A 4-year follow-up of child and adolescent psychiatric charts. Nord J Psychiatry. 2005;59(3):179-85. [pmid: 16195117].
59 Lush D, Boston M, Grainger E. Evaluation of psychoanalytic psychotherapy with children: Therapists’ assessments and predictions. Psychoanal Psychother. 1991;5(3):191-234. 1992-10102-001.
60 MacIntyre D, Carr A, Lawlor M, et al. Development of the Stay Safe programme. Child Abuse Review. 2000;9(3):200-16. 2000-12235-003.
61 May JC. Family attachment narrative therapy: Healing the experience of early childhood maltreatment. J Marital Fam Ther. 2005;31(3):221-37. 2007-08699-004. [pmid: 16094814].
62 McDiarmid MD, Bagner DM. Parent-Child Interaction Therapy for children with disruptive behavior and developmental disabilities. Educ Treat Children. 2005;28(2):130-42.
63 McFarlane JM, Groff JY, O’Brien JA, et al. Behaviors of children who are exposed and not exposed to intimate partner violence: an analysis of 330 black, white, and Hispanic children. Pediatrics. Sep. 2003;112(3 Pt 1):e202-7. [pmid: 12949313].
64 McGlade A, Ware R, Crawford M. Child protection outcomes for infants of substance-using mothers: a matched-cohort study. Pediatrics. Jul. 2009;124(1):285-93. [pmid: 19564311].
65 Minnis H, Everett K, Pelosi AJ, et al. Children in foster care: mental health, service use and costs. Eur Child Adolesc Psychiatry. 2006:63-70. [pmid: 16523249].
66 Moore KJ, Chamberlain P. Treatment foster care: cohort development of community-based models for adolescents with severe emotional and behavioral disorders. J Emot Behav Disord. 1994;2:22-30.
67 Murray MM, Southerland D, Farmer EM, et al. Enhancing and adapting treatment foster care: Lessons learned in trying to change practice. J Child Fam Stud. 2010;19(4):393-403. 2010-14062-002. [pmid: 20664709].
68 Nash J, Flynn RJ. Foster-parent training and foster-child outcomes: An exploratory cross-sectional analysis. Vulnerable Child Youth Stud. 2009;4(2):128-34. 2009-12497-005.
69 Noll JG, Shenk CE, Yeh MT, et al. Receptive language and educational attainment for sexually abused females. Pediatrics. Sep. 2010;126(3):e615-22. [pmid: 20696731].
70 Nurcombe B, Wooding S, Marrington P, et al. Child sexual abuse II: treatment. Aust N Z J Psychiatry. Feb. 2000;34(1):92-7. [pmid: 11185951].
71 Oates RK, Bross DC. What have we learned about treating child physical abuse? A literature review of the last decade. Child Abuse Negl. Apr. 1995;19(4):463-73. [pmid: 7606524].
72 Oates RK, O’Toole BI, Lynch DL, et al. Stability and change in outcomes for sexually abused children. J Am Acad Child Adolesc Psychiatry. Sep. 1994;33(7):945-53. [pmid: 7961349].
73 O’Donohue WT, Elliott AN. Treatment of the sexually abused child: a review. J Clin Child Psychol. 1992;21:218-28.
74 Penell J, Burford G. Family Group Decision Making: Protecting children and women. Child Welfare. 2000;79(2):131-58. [pmid: 10732256].
75 Disseminating PCIT to child maltreatment agencies: A snapshot in time. 2006. PCIT citation #17.
76 Pretorius G, Pfeifer N. Group art therapy with sexually abused girls. S Afr J Psychol. 2010;40(1):63-73. 2010-16557-008.
77 Price A, Wicheterman L. Shared Family Care: Fostering the whole family to promote safety and stability. J Fam Soc Work. 2003;7(2):35-54.
78 Racusin R, Maerlender AC Jr, Sengupta A, et al. Psychosocial treatment of children in foster care: a review. Community Ment Health J. Apr. 2005;41(2):199-221. [pmid: 15974499].
79 Raghunandan S, Leschied A. The effectiveness of kinship services with children exposed to partner violence: Exploring a dual victim treatment approach. Fam Soc. 2010;91(1):52-9. 2010-17928-009.
80 Rubin DM, Alessandrini EA, Feudtner C, et al. Placement stability and mental health costs for children in foster care. Pediatrics. May. 2004;113(5):1336-41. [pmid: 15121950].
81 Russell M, Gockel A, Harris B. Parent perspectives on intensive intervention for child maltreatment. Child Adolesc Social Work J. 2007;24(2):101-20. 2008-00105-001.
82 Sanders MR. Triple P – Positive Parenting Program as a Public Health Approach to Strengthening Parenting. J Fam Psychol. 2008;22:506-17. [pmid: 18729665].
83 Schewe PA. Direct service recommendations for children and caregivers exposed to community and domestic violence. Best Pract Ment Health. 2008;4(1):31-47. 2008-01658-004.
84 Sinclair I, Wilson K. Matches and Mismatches: The Contribution of Carers and Children to the Success of Foster Placements. Br J Soc Work. 2003;33(7):871-84. 2003-09120-002.
85 Siqueira AC, Spath R, Dell’Aglio DD, et al. Multidimensional life satisfaction, stressful events and social support network of Brazilian children in out-of-home care. Child Fam Soc Work. 2011;16(1):111-20. 2011-00911-012.
86 Smyke AT, Zeanah CH Jr, Fox NA, et al. A new model of foster care for young children: the Bucharest early intervention project. Child Adolesc Psychiatr Clin N Am. Jul. 2009;18(3):721-34. [pmid: 19486847].
87 Sturkie K. Group treatment for sexually abused children: Clinical wisdom and empirical findings. Child Adolesc Psychiatr Clin N Am. 1994;3:813-29.
88 Sunseri PA. Children Referred to Residential Care: Reducing Multiple Placements, Managing Costs and Improving Treatment Outcomes. Resid Treat Child Youth. 2005;22(3):55-66. 2005-12490-005.
89 Swenson CC, Brown EJ. Cognitive behavioral group treatment for physically abused children. Cogn Behav Pract. 1999;6(3):212-20. 2002-01098-003.
90 Taft AJ, Small R, Hegarty KL, et al. MOSAIC (MOthers’ Advocates In the Community): protocol and sample description of a cluster randomised trial of mentor mother support to reduce intimate partner violence among pregnant or recent mothers. BMC public health. 2009:159.
91 Taussig HN, Culhane SE. Emotional maltreatment and psychosocial functioning in preadolescent youth placed in out-of-home care. J Aggress Maltreat Trauma. 2010;19(1):52-74. 2010-07562-003. [pmid: 20107619].
92 Taussig HN, Garrido EF, Crawford G. Use of a web-based data system to conduct a randomized controlled trial on an intervention for children placed in out-of-home care. Soc Work Res. 2009;33(1):55-60. 2009-05601-006. [pmid: 20186288].
93 Toth SL, Manly JT, Nilsen WJ. From research to practice: Lessons learned. J Appl Dev Psychol. 2008;29(4):317-25. 2008-09340-008.
94 Turner W, Macdonald GM, Dennis JA. Cognitive-behavioural training interventions for assisting foster carers in the management of difficult behaviour. Cochrane Database Syst Rev. 2005;(2):CD003760. [pmid: 15846680].
95 Unrau YA. Predicting use of child welfare services after intensive family preservation services. Res Soc Work Pract. 1997;7(2):202-15. 1997-03553-004.
96 Valentino K, Cicchetti D, Toth SL, et al. Mother-child play and emerging social behaviors among infants from maltreating families. Dev Psychol. 2006;42(3):474-85. 2006-07128-008. [pmid: 16756439].
97 Valentino K, Cicchetti D, Toth SL, et al. Mother–child play and maltreatment: A longitudinal analysis of emerging social behavior from infancy to toddlerhood. Dev Psychol. 2011;47(5):1280-94. 2011-14088-001. [pmid: 21744951].
98 van Santen E. Predictors of exit type and length of stay in non-kinship family foster care—The German experience. Child Youth Serv Rev. 2010;32(10):1211-22. 2010-17145-002.
99 Wanlass J, Moreno JK, Thomson HM. Group Therapy for Abused and Neglected Youth: Therapeutic and Child Advocacy Challenges. J Special Group Work. 2006;31(4):311-26. 2006-21869-003.
100 Zeanah CH, Nelson CA, Fox NA, et al. Designing research to study the effects of institutionalization on brain and behavioral development: The Bucharest Early Intervention Project. Dev Psychopathol. 2003;15(4):885-907. 2003-10921-004. [pmid: 14984131].

## Wrong Population (N=203)

1 Aber JL, Brooks-Gunn J, Maynard RA. Effects of welfare reform on teenage parents and their children. Future Child. Summer-Fall. 1995;5(2):53-71. [pmid: 8528688].
2 Adler-Tapia R, Settle C. Evidence of the Efficacy of EMDR With Children and Adolescents in Individual Psychotherapy: A Review of the Research Published in Peer-Reviewed Journals. J EMDR Pract Res. 2009;3(4):232-47.
3 Ahmad A, Larsson B, Sundelin-Wahlsten V. EMDR treatment for children with PTSD: results of a randomized controlled trial. Nord J Psychiatry. 2007;61(5):349-54. [pmid: 17990196].
4 Arnold EM, Kirk RS, Roberts AC, et al. Treatment of incarcerated, sexually-abused adolescent females: an outcome study. J Child Sex Abus. 2003;12(1):123-39. [pmid: 16221662].
5 Asarnow JR, Emslie G, Clarke G, et al. Treatment of Selective Serotonin Reuptake Inhibitor-Resistant Depression in Adolescents: Predictors and Moderators of Treatment Response. J Am Acad Child Adolesc Psychiatry. Mar. 2009;48(3):330-9. WOS:000263742100012. [pmid: 19182688].
6 Asarnow JR, Porta G, Spirito A, et al. Suicide Attempts and Nonsuicidal Self-Injury in the Treatment of Resistant Depression in Adolescents: Findings from the TORDIA Study. J Am Acad Child Adolesc Psychiatry. Aug. 2011;50(8):772-81. WOS:000293427800008. [pmid: 21784297].
7 Avinger KA, Jones RA. Group treatment of sexually abused adolescent girls: A review of outcomes studies. Am J Fam Ther. 2007;35:315-26.
8 Bagley C, LaChance M. Evaluation of a family-based programme for the treatment of child sexual abuse. Child Fam Soc Work. 2000;5:205-13.
9 Bair-Merritt MH, Jennings JM, Chen R, et al. Reducing maternal intimate partner violence after the birth of a child: a randomized controlled trial of the Hawaii Healthy Start Home Visitation Program. Arch Pediatr Adolesc Med. Jan. 2010;164(1):16-23. [pmid: 20048237].
10 Barbe RP, Bridge JA, Birmaher B, et al. Lifetime history of sexual abuse, clinical presentation, and outcome in a clinical trial for adolescent depression. J Clin Psychiatry. Jan. 2004;65(1):77-83. [pmid: 14744173].
11 Barkauskas VH, Low LK, Pimlott S. Health outcomes of incarcerated pregnant women and their infants in a community-based program. J Midwifery Womens Health. Sep–Oct. 2002;47(5):371-9. [pmid: 12361349].
12 Barth RP, Yeaton J, Winderfelt N. Psychoeducational groups with foster parents of sexually abused children. Child Adolesc Social Work J. 1994;11(5):405-24.
13 Barton K, Baglio CS, Braverman MT. Stress reduction in child-abusing families: global and specific measures. Psychol Rep. Aug. 1994;75(1 Pt 1):287-304. [pmid: 7984740].
14 Baydar N, Reid MJ, Webster-Stratton C. The role of mental health factors and program engagement in the effectiveness of a preventive parenting program for Head Start mothers. Child Dev. Sep–Oct. 2003;74(5):1433-53. [pmid: 14552407].
15 Beauchaine TP, Webster-Stratton C, Reid MJ. Mediators, moderators, and predictors of 1-year outcomes among children treated for early-onset conduct problems: A latent growth curve analysis. J Consult Clin Psychol. Jun. 2005;73(3):371-88. WOS:000230036200001. [pmid: 15982136].
16 Becker-Weidman A. Treatment for Children with Trauma-Attachment Disorders: Dyadic Developmental Psychotherapy. Child Adolesc Social Work J. 2006;23(2):147-71. 2006-12239-003.
17 Berkowitz SJ, Stover CS, Marans SR. The Child and Family Traumatic Stress Intervention: Secondary prevention for youth at risk of developing PTSD. J Child Psychol Psychiatry. 2011;52(6):676-85. 2011-10499-012. [pmid: 20868370].
18 Biehal N, Ellison S, Sinclair I. Intensive fostering: An independent evaluation of MTFC in an English setting. Child Youth Serv Rev. 2011;33(10):2043-9. 2011-12157-001.
19 Bodenmann G, Cina A, Ledermann T, et al. The efficacy of the Triple P-Positive Parenting Program in improving parenting and child behavior: a comparison with two other treatment conditions. Behav Res Ther. Apr. 2008;46(4):411-27. [pmid: 18313033].
20 Boggs SR, Eyberg SM, Edwards DL, et al. Outcomes of Parent-Child Interaction Therapy: A comparison of treatment completers and study dropouts one to three years later. Child and Family Behavior Therapy. 2004;26(4):1-22.
21 Bor W, Sanders MR, Markie-Dadds C. The effects of the Triple P-Positive Parenting Program on preschool children with co-occurring disruptive behavior and attentional/hyperactive difficulties. J Abnorm Child Psychol. Dec. 2002;30(6):571-87. [pmid: 12481972].
22 Bratton SC, Ray D, Rhine T, et al. The efficacy of play therapy with children: A meta-analytic review of treatment outcomes. Prof Psychol Res Pr. 2005;36:376-90.
23 Brayden RM, Altemeier WA, Dietrich MS, et al. A prospective study of secondary prevention of child maltreatment. J Pediatr. Apr. 1993;122(4):511-6. [pmid: 8463893].
24 Brown KJ, Block AJ. Evaluation of Project Chrysalis: A school-based intervention to reduce negative consequences of abuse. J Early Adolesc. 2001;21(3):325-53.
25 Bugental DB, Ellerson PC, Lin EK, et al. A cognitive approach to child abuse prevention. J Fam Psychol. Sep. 2002;16(3):243-58. [pmid: 12238408].
26 Bywater T, Hutchings J, Linck P, et al. Incredible Years parent training support for foster carers in Wales: a multi-centre feasibility study. Child Care Health Dev. Mar. 2011;37(2):233-43. [pmid: 20854449].
27 Capaldi DM, Chamberlain P, Fetrow RA, et al. Conducting ecologically valid prevention research: recruiting and retaining a “whole village” in multimethod, multiagent studies. Am J Community Psychol. Aug. 1997;25(4):471-92. [pmid: 9338955].
28 Carta J, Burke Lefever J, Bigelow K, et al. Preventing child maltreatment through cellular-phone technology-based parenting program. Final report prepared for the Centers for Disease Control and Prevention. 2011.
29 Cary CE, McMillen JC. The data behind the dissemination: A systematic review of trauma-focused cognitive behavioral therapy for use with children and youth. Child Youth Serv Rev. Apr. 2012;34(4):748-57. WOS:000301912600020.
30 Casanueva C, Martin SL, Runyan DK, et al. Parenting services for mothers involved with child protective services: Do they change maternal parenting and spanking behaviors with young children?. Child Youth Serv Rev. Aug. 2008;30(8):861-78. WOS:000258023500002.
31 Cepukiene V, Pakrosnis R. The outcome of Solution-Focused Brief Therapy among foster care adolescents: The changes of behavior and perceived somatic and cognitive difficulties. Child Youth Serv Rev. 2011;33(6):791-7. 2011-08059-002.
32 Chaffin M, Bonner BL, Hill RF. Family preservation and family support programs: child maltreatment outcomes across client risk levels and program types. Child Abuse Negl. Oct. 2001;25(10):1269-89. [pmid: 11720379].
33 Chamberlain P. Emhanced social services and stipends for foster parents: effects on retention rates and outcomes for children. Child Welfare. 1992;71(5):387-401. [pmid: 1521497].
34 Chamberlain P, Reid JB. Using a Specialized Foster Care Community Treatment Model for Children and Adolescents Leaving the State Mental Hospital. J Community Psychol. 1991;19:266-76.
35 Champion JD, Collins JL. Comparison of a theory-based (AIDS Risk Reduction Model) cognitive behavioral intervention versus enhanced counseling for abused ethnic minority adolescent women on infection with sexually transmitted infection: Results of a randomized controlled trial. Int J Nurs Stud. Feb. 2012;49(2):138-50. WOS:000300859900003. [pmid: 21937041].
36 Clark HB, Prange M. Improving adjustment outcomes for foster children with emotional and behavioral disorders: early findings from a controlled study on individualized services. J Emot Behav Disord. 1994;2:207-18.
37 Clark KD, Tepper D, Jenny C. Effect of a screening profile on the diagnosis of nonaccidental burns in children. Pediatr Emerg Care. Aug. 1997;13(4):259-61. [pmid: 9291513].
38 Clendenon-Wallen J. The use of music therapy to influence the self-confidence and self-esteem of adolescents who are sexually abused. Music Therapy Perspectives. 1991;9:73-81.
39 Cloitre M, Stovall-McClough KC, Miranda R, et al. Therapeutic alliance, negative mood regulation, and treatment outcome in child abuse-related posttraumatic stress disorder. J Consult Clin Psychol. Jun. 2004;72(3):411-6. [pmid: 15279525].
40 Cohen JA, Mannarino AP. Interventions for sexually abused children: Initial treatment outcome findings. Child Maltreatment. 1998;3(1):17-26. 1997-39106-002.
41 Cohen JA, Mannarino AP, Iyengar S. Community treatment of posttraumatic stress disorder for children exposed to intimate partner violence: a randomized controlled trial. Arch Pediatr Adolesc Med. Jan. 2011;165(1):16-21. [pmid: 21199975].
42 Cohen JA, Mannarino AP, Knudsen K. Treating childhood traumatic grief: a pilot study. J Am Acad Child Adolesc Psychiatry. Oct. 2004;43(10):1225-33. [pmid: 15381889].
43 Cohen JA, Mannarino AP, Knudsen K. Treating sexually abused children: 1 year follow-up of a randomized controlled trial. Child Abuse Negl. Feb. 2005;29(2):135-45. [pmid: 15734179].
44 Cohen JA, Mannarino AP, Perel JM, et al. A pilot randomized controlled trial of combined trauma-focused CBT and sertraline for childhood PTSD symptoms. J Am Acad Child Adolesc Psychiatry. Jul. 2007;46(7):811-9. WOS:000247442600005. [pmid: 17581445].
45 Conley A, Duerr Berrick J. Community-based child abuse prevention: outcomes associated with a differential response program in California. Child Maltreat. Nov. 2010;15(4):282-92. [pmid: 20647255].
46 Constantino JN, Hashemi N, Solis E, et al. Supplementation of urban home visitation with a series of group meetings for parents and infants: results of a “real-world” randomized, controlled trial. Child Abuse Negl. Dec. 2001;25(12):1571-81. [pmid: 11814156].
47 Cowen PS. Effectiveness of a Parent Education Intervention for At-Risk Families JSPN. 2001;6(2):73-82.
48 Crooks CV, Scott K, Ellis W, et al. Impact of a universal school-based violence prevention program on violent delinquency: Distinctive benefits for youth with maltreatment histories. Child Abuse Negl. Jun. 2011;35(6):393-400. WOS:000292351200002. [pmid: 21652072].
49 Dakof GA, Cohen JB, Henderson CE, et al. A randomized pilot study of the Engaging Moms Program for family drug court. J Subst Abuse Treat. Apr. 2010;38(3):263-74. [pmid: 20116961].
50 Davis MK, Gidycz CA. Child sexual abuse prevention programs: a meta-analysis. J Clin Child Psychol. Jun. 2000;29(2):257-65. [pmid: 10802834].
51 De Luca RV, Boyes DA, Grayston AD, et al. Sexual abuse: Effects of group therapy on pre-adolescent girls. Child Abuse Review. 1995;4(4):263-77. 1999-00594-002.
52 Deblinger E, McLeer SV, Henry D. Cognitive behavioral treatment for sexually abused children suffering post-traumatic stress: preliminary findings. J Am Acad Child Adolesc Psychiatry. Sep. 1990;29(5):747-52. [pmid: 2228928].
53 Donkoh C, Underhill K, Montgomery P. Independent living programmes for improving outcomes for young people leaving the care system. Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2006.
54 Dubowitz H, Feigelman S, Lane W, et al. Pediatric primary care to help prevent child maltreatment: the Safe Environment for Every Kid (SEEK) Model. Pediatrics. Mar. 2009;123(3):858-64. [pmid: 19255014].
55 Duggan A, Caldera D, Rodriguez K, et al. Impact of a statewide home visiting program to prevent child abuse. Child Abuse Negl. Aug. 2007;31(8):801-27. [pmid: 17822764].
56 Duggan A, Fuddy L, Burrell L, et al. Randomized trial of a statewide home visiting program to prevent child abuse: impact in reducing parental risk factors. Child Abuse Negl. Jun. 2004;28(6):623-43. [pmid: 15193852].
57 Duggan A, Fuddy L, McFarlane E, et al. Evaluating a statewide home visiting program to prevent child abuse in at-risk families of newborns: fathers’ participation and outcomes. Child Maltreat. Feb. 2004;9(1):3-17. [pmid: 14870994].
58 Dumas JE, Begle AM, French B, et al. Effects of monetary incentives on engagement in the PACE parenting program. J Clin Child Adolesc Psychol. 2010;39(3):302-13. [pmid: 20419572].
59 Eckenrode J, Zielinski D, Smith E, et al. Child maltreatment and the early onset of problem behaviors: can a program of nurse home visitation break the link?. Dev Psychopathol. Fall. 2001;13(4):873-90. [pmid: 11771912].
60 Enebrink P, Gustafsson E, Lauren EM, et al. Medical and psychological methods for preventing sexual offences against children (Structured abstract). Stockholm. Swedish Council on Technology Assessment in Health Care (SBU): Swedish Council on Technology Assessment in Health Care (SBU). 2011.
61 Everson-Hock ES, Jones R, Guillaume L, et al. Supporting the transition of looked-after young people to independent living: a systematic review of interventions and adult outcomes. Child Care Health Dev. Nov. 2011;37(6):767-79. [pmid: 22007976].
62 Farmer EM, Burns BJ, Wagner HR, et al. Enhancing “usual practice” treatment foster care: findings from a randomized trial on improving youths’ outcomes. Psychiatr Serv. Jun. 2010;61(6):555-61. [pmid: 20513677].
63 Farrell AF, Britner PA, Guzzardo M, et al. Supportive housing for families in child welfare: Client characteristics and their outcomes at discharge. Child Youth Serv Rev. 2010;32(2):145-54. 2009-23596-002.
64 Fein DJ, Lee WS. The impacts of welfare reform on child maltreatment in Delaware. Child Youth Serv Rev. 2003;25(1–2):83-111. 2003-01488-004.
65 Feldman MA. Parenting education for parents with intellectual disabilities: a review of outcome studies. Res Dev Disabil. Jul–Aug. 1994;15(4):299-332. [pmid: 7972968].
66 Fraser JA, Armstrong KL, Morris JP, et al. Home visiting intervention for vulnerable families with newborns: follow-up results of a randomized controlled trial. Child Abuse Negl. Nov. 2000;24(11):1399-429. [pmid: 11128173].
67 Fraser MW, Walton E, Lewis RE, et al. An Experiment in Family Reunification: Correlates of Outcomes at 1-Year Follow-Up. Child Youth Serv Rev. 1996;18:335-61.
68 Gaudin JM Jr, Wodarski JS, Arkinson MK, et al. Remedying child neglect: effectiveness of social network interventions. J Appl Soc Sci. 1990–1991;15(1):97-123.
69 Geeraert L, Van den Noortgate W, Grietens H, et al. The effects of early prevention programs for families with young children at risk for physical child abuse and neglect: a meta-analysis. Child Maltreat. Aug. 2004;9(3):277-91. [pmid: 15245680].
70 Ghosh Ippen C, Harris WW, Van Horn P, et al. Traumatic and stressful events in early childhood: can treatment help those at highest risk?. Child Abuse Negl. 2011:504-13. [pmid: 21816474].
71 Goldhaber-Fiebert JD, Snowden LR, Wulczyn F, et al. Economic evaluation research in the context of Child Welfare policy: A structured literature review and recommendations. Child Abuse Negl. Sep. 2011;35(9):722-40. WOS:000295946000007. [pmid: 21944552].
72 Graham-Bermann SA, Lynch S, Banyard V, et al. Community-based intervention for children exposed to intimate partner violence: an efficacy trial. J Consult Clin Psychol. Apr. 2007;75(2):199-209. [pmid: 17469878].
73 Haack MR, Burda-Cohee C, Alemi F, et al. Facilitating Self-Management of Substance Use Disorders with Online Counseling: The Intervention and Study Design. J Addict Nurs. 2005;16(1–2):41-6. 2005-04783-007. [pmid: 22187519].
74 Hahn RA, Bilukha O, Lowy J, et al. The effectiveness of therapeutic foster care for the prevention of violence: a systematic review. Am J Prev Med. Feb. 2005;28(2 Suppl 1):72-90. [pmid: 15698748].
75 Hahn RA, Lowy J, Bilukha O, et al. Therapeutic foster care for the prevention of violence: a report on recommendations of the Task Force on Community Preventive Services. MMWR Recomm Rep. Jul. 2. 2004;53(RR-10):1-8. [pmid: 15229410].
76 Hamama L, Hamama-Raz Y, Dagan K, et al. A preliminary study of group intervention along with basic canine training among traumatized teenagers: A 3-month longitudinal study. Child Youth Serv Rev. Oct. 2011;33(10):1975-80. WOS:000295435600025.
77 Hess PM, McGowan BG, Botsko M. A preventive services program model for preserving and supporting families over time. Child Welfare. May–Jun. 2000;79(3):227-65. [pmid: 10813083].
78 Hides L, Baker A, Kavanagh D, et al. Psychological interventions for co-occurring depression and substance misuse. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2011.
79 Hill HD, Morris P. Welfare policies and very young children: experimental data on stage-environment fit. Dev Psychol. Nov. 2008;44(6):1557-71. [pmid: 18999322].
80 Hill JM, Vernig PM, Lee JK, et al. The development of a brief acceptance and mindfulness-based program aimed at reducing sexual revictimization among college women with a history of childhood sexual abuse. J Clin Psychol. Sep. 2011;67(9):969-80. [pmid: 21544818].
81 Holden EW, O’Connell SR, Liao Q, et al. Outcomes of a randomized trial of continuum of care services for children in a child welfare system. Child Welfare. Nov–Dec. 2007;86(6):89-114. [pmid: 18456984].
82 Holland P, Gorey KM, Lindsay A. Prevention of Mental Health and Behavior Problems Among Sexually Abused Aboriginal Children in Care. Child Adolesc Social Work J. 2004;21(2):109-15. 2004-13217-002.
83 Horwitz SM, Chamberlain P, Landsverk J, et al. Improving the Mental Health of Children in Child Welfare Through the Implementation of Evidence-Based Parenting Interventions. Administration and Policy in Mental Health and Mental Health Services Research. Mar. 2010;37(1–2):27-39. WOS:000278110200004. [pmid: 20143150].
84 Hunter AL, Minnis H, Wilson P. Altered stress responses in children exposed to early adversity: A systematic review of salivary cortisol studies. Stress-the International Journal on the Biology of Stress. Nov. 2011;14(6):614-26. WOS:000295891600005.
85 Hurlburt MS, Nguyen K, Reid MJ, et al. Efficacy of Incredible Years group parent program with families in Head Start with a child maltreatment history. Child Abuse Negl. Under review.
86 Hyde C, Bentovim A, Monck E. Some clinical and methodological implications of a treatment outcome study of sexually abused children. Child Abuse Negl. Nov. 1995;19(11):1387-99. [pmid: 8591095].
87 Iwaniec D. Evaluating parent training for emotionally abusive and neglectful parents: comparing individual versus individual and group intervention. Res Soc Work Pract. 1997;7:329-49.
88 Jansson LM, Svikis DS, Beilenson P. Effectiveness of child case management services for offspring of drug-dependent women. Subst Use Misuse. Dec. 2003;38(14):1933-52. [pmid: 14677776].
89 Jarero I, Artigas L, Hartung J. EMDR Integrative Group Treatment Protocol: A Postdisaster Trauma Intervention for Children and Adults. Traumatology. June. 1. 2006. 2006;12(2):121-9.
90 Johnson M, Stone S, Lou C, et al. Assessing parent education programs for families involved with child welfare services: evidence and implications. J Evid Based Soc Work. 2008;5(1–2):191-236. [pmid: 19064449].
91 Jones N, Pelissier B, Klein-Saffran J. Predicting sex offender treatment entry among individuals convicted of sexual offense crimes. Sex Abuse. Jan. 2006;18(1):83-98. [pmid: 16763760].
92 Jouriles EN, McDonald R, Rosenfield D, et al. Reducing conduct problems among children exposed to intimate partner violence: a randomized clinical trial examining effects of Project Support. J Consult Clin Psychol. Aug. 2009;77(4):705-17. [pmid: 19634963].
93 Kar N. Cognitive behavioral therapy for the treatment of post-traumatic stress disorder: a review. Neuropsychiatr Dis Treat. 2011;7:167-81. WOS:000294955100019. [pmid: 21552319].
94 Kessler RC, Pecora PJ, Williams J, et al. Effects of enhanced foster care on the long-term physical and mental health of foster care alumni. Arch Gen Psychiatry. Jun. 2008;65(6):625-33. [pmid: 18519820].
95 King NJ, Tonge BJ, Mullen P, et al. Treating sexually abused children with posttraumatic stress symptoms: a randomized clinical trial. J Am Acad Child Adolesc Psychiatry. Nov. 2000;39(11):1347-55. [pmid: 11068889].
96 Kolko DJ, Iselin AMR, Gully KJ. Evaluation of the sustainability and clinical outcome of Alternatives for Families: A Cognitive-Behavioral Therapy (AF-CBT) in a child protection center. Child Abuse Negl. Feb. 2011;35(2):105-16. WOS:000288884600004. [pmid: 21354619].
97 Kumpfer KL, Whiteside HO, Greene JA, et al. Effectiveness outcomes of four age versions of the Strengthening Families Program in statewide field sites. Group Dynamics: Theory, Research, and Practice. 2010;14(3):211-29. 2010-18447-003.
98 Landsman MJ, Groza V, Tyler M, et al. Outcomes of family-centered residential treatment. Child Welfare. May–Jun. 2001;80(3):351-79. [pmid: 11380046].
99 Lanktree CB, Briere J. Outcome of therapy for sexually abused children: a repeated measures study. Child Abuse Negl. Sep. 1995;19(9):1145-55. [pmid: 8528820].
100 LeCroy CW, Krysik J. Randomized trial of the healthy families Arizona home visiting program. Child Youth Serv Rev. Oct. 2011;33(10):1761-6. WOS:000295435600001.
101 Lee BR, Thompson R. Comparing outcomes for youth in treatment foster care and family-style group care. Child Youth Serv Rev. Jul. 2008;30(7):746-57. WOS:000257648300006. [pmid: 19122763].
102 Leung C, Sanders MR, Leung S, et al. An outcome evaluation of the implementation of the Triple P-Positive Parenting Program in Hong Kong. Fam Process. Winter. 2003;42(4):531-44. [pmid: 14979223].
103 Leve LD, Chamberlain P. A randomized evaluation of multidimensional treatment foster care: Effects on school attendance and homework completion in juvenile justice girls. Res Soc Work Pract. 2007;17(6):657-63. 2007-15761-001. [pmid: 18159224].
104 Lewis CC, Simons AD, Nguyen LJ, et al. Impact of childhood trauma on treatment outcome in the Treatment for Adolescents with Depression Study (TADS). J Am Acad Child Adolesc Psychiatry. Feb. 2010;49(2):132-40. [pmid: 20215935].
105 Lewis RE. The effectiveness of Families First services: An experimental study. Child Youth Serv Rev. 2005;27(5):499-509. 2005-02983-003.
106 Lewis RE, Walton E, Fraser MW. Examining family reunification services: A process analysis of a successful experiment. Res Soc Work Pract. 1995;5(3):259-82. 1995-45084-001.
107 Lieberman AF, Ghosh Ippen C, Van Horn P. Child-parent psychotherapy: 6-month follow-up of a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. Aug. 2006;45(8):913-8. [pmid: 16865033].
108 Lieberman AF, Van Horn P, Ippen CG. Toward evidence-based treatment: child-parent psychotherapy with preschoolers exposed to marital violence. J Am Acad Child Adolesc Psychiatry. Dec. 2005;44(12):1241-8. [pmid: 16292115].
109 Love SM, Koob JJ, Hill LE. The effects of using community mental health practitioners to treat foster children: Implications for child welfare planners. The Scientific Review of Mental Health Practice: Objective Investigations of Controversial and Unorthodox Claims in Clinical Psychology, Psychiatry, and Social Work. 2008;6(1):31-9. 2009-01771-003.
110 Luthar SS, Suchman NE, Altomare M. Relational Psychotherapy Mothers’ Group: A randomized clinical trial for substance abusing mothers. Dev Psychopathol. 2007;19(1):243-61. 2007-02084-013. [pmid: 17241493].
111 Macdonald G, Turner W. An experiment in helping foster-carers manage challenging behavior. Br J Soc Work. 2005;35:1265-82.
112 Magura S, Laudet A, Kang SY, et al. Effectiveness of comprehensive services for crack-dependent mothers with newborns and young children. J Psychoactive Drugs. Oct–Dec. 1999;31(4):321-38. [pmid: 10681100].
113 Mandeville-Norden R, Beech A, Hayes E. Examining the effectiveness of a UK community-based sexual offender treatment programme for child abusers. Psychology, Crime & Law. 2008;14(6):493-512. 2008-18929-002.
114 Marcelle DR, Melzer-Lange MD. Project UJIMA working together to make things right. WMJ. 2001;100(2):22-5. [pmid: 11419365].
115 Marcenko MO, Spence M. Home visitation services for at-risk pregnant and postpartum women: a randomized trial. Am J Orthopsychiatry. Jul. 1994;64(3):468-78. [pmid: 7977669].
116 Martin AJ, Sanders MR. Balancing work and family: A controlled evaluation of the Triple-P Positive Parenting Program as a work-site intervention. Child and Adolescent Mental Health. 2003:84161-169.
117 Matsuura N. Youth corrections in Japan: Family-like setting for delinquents with the experiences of child maltreatment. Child Youth Ser. 2011;32(4):281-5. 2011-30022-003. First Author & Affiliation: Matsuura, Naomi.
118 May M, Housley W. The effects of group counselling on the self-esteem of sexually abused female adolescents. Guidance and Counselling. 1996;11:38-42.
119 McDonald R, Dodson MC, Rosenfield D, et al. Effects of a Parenting Intervention on Features of Psychopathy in Children. J Abnorm Child Psychol. Oct. 2011;39(7):1013-23. WOS:000294265100009. [pmid: 21553346].
120 McDonald R, Jouriles EN, Skopp NA. Reducing conduct problems among children brought to women’s shelters: intervention effects 24 months following termination of services. J Fam Psychol. Mar. 2006;20(1):127-36. [pmid: 16569097].
121 McFarlane JM, Groff JY, O’Brien JA, et al. Behaviors of children following a randomized controlled treatment program for their abused mothers. Issues Compr Pediatr Nurs. Oct–Dec. 2005;28(4):195-211. [pmid: 16356894].
122 McMillen JC, Tucker J. The status of older adolescents at exit from out-of-home care. Child Welfare. May–Jun. 1999;78(3):339-60. [pmid: 10335595].
123 McPherson P, Scribano P, Stevens J. Barriers to successful treatment completion in child sexual abuse survivors. J Interpers Violence. Jan. 2012;27(1):23-39. [pmid: 21859762].
124 Mikton C, Butchart A. Child maltreatment prevention: a systematic review of reviews. Bull World Health Organ. May. 2009;87(5):353-61. [pmid: 19551253].
125 Minnis H, Pelosi AJ, Knapp M, et al. Mental health and foster carer training. Arch Dis Child. Apr. 2001;84(4):302-6. [pmid: 11259226].
126 Morris E, Suarez L, Reid JC. Behavioral Outcomes of Home-Based Services for Children and Adolescents With Serious Emotional Disorders. Family Preservation Journal. 1997;3:21-32.
127 Mullins SM, Suarez M, Ondersma SJ, et al. The impact of motivational interviewing on substance abuse treatment retention: a randomized control trial of women involved with child welfare. J Subst Abuse Treat. Jul. 2004;27(1):51-8. [pmid: 15223094].
128 Mundorf ES, Paivio SC. Narrative quality and disturbance pre- and post-emotion-focused therapy for child abuse trauma. J Trauma Stress. 2011;24(6):643-50. 2011-29848-004. First Author & Affiliation: Mundorf, Elisabeth S. [pmid: 22144230].
129 Najavits LM, Gallop RJ, Weiss RD. Seeking safety therapy for adolescent girls with PTSD and substance use disorder: a randomized controlled trial. J Behav Health Serv Res. Oct. 2006;33(4):453-63. [pmid: 16858633].
130 Nelson KE, Nash JK. The effectiveness of aftercare services for African American families in an intensive family preservation program. Res Soc Work Pract. 2008;18(3):189-97. 2008-05059-002.
131 Newton AS, Zou B, Hamm MP, et al. Improving child protection in the emergency department: a systematic review of professional interventions for health care providers. Acad Emerg Med. Feb. 2010;17(2):117-25. [pmid: 20370740].
132 Nitkowski D, Petermann F, Büttner P, et al. Behavior modification of aggressive children in child welfare: Evaluation of a combined intervention program. Behav Modif. 2009;33(4):474-92. 2009-11761-004. [pmid: 19571325].
133 Olds D, Henderson CR Jr, Kitzman H, et al. Effects of prenatal and infancy nurse home visitation on surveillance of child maltreatment. Pediatrics. Mar. 1995;95(3):365-72. [pmid: 7862474].
134 Olds DL, Kitzman HJ, Cole RE, et al. Enduring effects of prenatal and infancy home visiting by nurses on maternal life course and government spending: follow-up of a randomized trial among children at age 12 years. Arch Pediatr Adolesc Med. May. 2010;164(5):419-24. [pmid: 20439792].
135 Ornelas LA, Silverstein DN, Tan S. Effectively addressing mental health issues in permanency-focused child welfare practice. Child Welfare: J Pol Pract Progr. 2007;86(5):93-112. 2008-02808-006.
136 Ortega G, Castella C, Martin-Cantera C, et al. Passive smoking in babies: the BIBE study (Brief Intervention in babies. Effectiveness). BMC Public Health. 2010;10:772. [pmid: 21171981].
137 Osofsky JD, Rovaris M, Hammer JH, et al. Working with Police to Help Children Exposed to Violence. J Community Psychol. 2004;32(5):593-606. 2004-17930-007.
138 Osterling KL, Hines AM. Mentoring adolescent foster youth: Promoting resilience during developmental transitions. Child Fam Soc Work. 2006;11(3):242-53. 2006-08843-007.
139 Pacifici C, White L, Cummings K, et al. Vstreet.com: A Web-Based Community for At-Risk Teens. Child Welfare: J Pol Pract Progr. 2005;84(1):25-46. 2005-00971-002.
140 Parker JS, Stewart GS, Gantt C. Research and intervention with adolescents exposed to domestic violence. Family Therapy. 2006;33(1):45-52. 2006-07937-004.
141 Powell L, Cheshire A. A preliminary evaluation of a massage program for children who have been sexually abused and their nonabusing mothers. J Child Sex Abuse. 2010;19(2):141-55. 2010-07579-003.
142 Puckering C, Rogers J, Mills M, et al. Process and evaluation of a group intervention for mothers with parenting difficulties. Child Abuse Review. 1994;3(4):299-310. 1999-00598-003.
143 Raider MC, Steele W. Structured sensory therapy (SITCAP-ART) for traumatized adjudicated adolescents in residential treatment. National Social Science Association Journal. 2008;32(1):111-21.
144 Raider MC, Steele W, Dellilo-Storey M, et al. Structured sensory therapy (SITCAP-ART) for traumatized adjudicated adolescents in residential treatment. Residential Treatment for Children and Youth. 2008;25(2):167-85.
145 Reid MJ, Webster-Stratton C, Beauchaine TP. Parent training in head start: a comparison of program response among African American, Asian American, Caucasian, and Hispanic mothers. Prev Sci. Dec. 2001;2(4):209-27. [pmid: 11833925].
146 Reynolds AJ, Robertson DL. School-based early intervention and later child maltreatment in the Chicago Longitudinal Study. Child Dev. Jan–Feb. 2003;74(1):3-26. [pmid: 12625433].
147 Reynolds AJ, Temple JA, Ou SR. School-based early intervention and child well-being in the Chicago Longitudinal Study. Child Welfare. Sep–Oct. 2003;82(5):633-56. [pmid: 14524429].
148 Reynolds AJ, Temple JA, White BA, et al. Age 26 cost-benefit analysis of the Child-Parent Center Early Education Program (Provisional abstract). Child Dev. 2011:379-404. [pmid: 21291448].
149 Rispens J, Aleman A, Goudena PP. Prevention of child sexual abuse victimization: a meta-analysis of school programs. Child Abuse Negl. Oct. 1997;21(10):975-87. [pmid: 9330798].
150 Rivard J, McCorkle D, Duncan M, et al. Implementing a Trauma Recovery Framework for Youths in Residential Treatment. Child and Adolescent Social Work Journal. 2004;21(5):529-50.
151 Rivard JC, Bloom SL, McCorkle D, et al. Preliminary results of a study examining the implementation and effects of a trauma recovery framework for youths in residential treatment. Therapeutic Communities. 2005;26(1):83-96.
152 Robst J, Armstrong M, Dollard N. Comparing outcomes for youth served in treatment foster care and treatment group care. J Child Fam Stud. 2011;20(5):696-705. 2011-23399-016. First Author & Affiliation: Robst, John.
153 Roby JL, Shaw SA. Evaluation of a community-based orphan care program in Uganda. Fam Soc. 2008;89(1):119-28. 2009-01746-015.
154 Rodenburg R, Benjamin A, de Roos C, et al. Efficacy of EMDR in children: a meta-analysis. Clin Psychol Rev. Nov. 2009;29(7):599-606. [pmid: 19616353].
155 Rosenthal JA, Glass GV. Comparative impacts of alternatives to adolescent placement. J Soc Serv Res. 1990;13(3):19-37. 1990-28900-001.
156 Rubin A, Bischofshausen S, Conroy Moore K, et al. The effectiveness of EMDR in a child guidance center. Res Soc Work Pract. 2001;11(4):435-57.
157 Ryan JP. Dependent Youth in Juvenile Justice: Do Positive Peer Culture Programs Work for Victims of Child Maltreatment?. Res Soc Work Pract. 2006;16(5):511-9. 2006-10830-005.
158 Ryan JP, Davis RK, Yang H. Reintegration services and the likelihood of adult imprisonment: A longitudinal study of adjudicated delinquents. Res Soc Work Pract. 2001;11(3):321-37. 2002-02384-003.
159 Saewyc EM, Edinburgh LD. Restoring healthy developmental trajectories for sexually exploited young runaway girls: fostering protective factors and reducing risk behaviors. J Adolesc Health. Feb. 2010;46(2):180-8. [pmid: 20113924].
160 Sanders MR, Pidgeon AM, Gravestock F, et al. Does parental attributional retraining and anger management enhance the effects of the Triple P-Positive Parenting Program with parents at risk of child maltreatment?. Behavior Therapy. 2004;35(3):513-35. 2004-19328-004.
161 Saxe GN, Ellis BH, Fogler J, et al. Comprehensive Care for Traumatized Children. Psychiatr Ann. 2005;35(5):443-8. 2005-05449-009.
162 Schuhmann EM, Foote RC, Eyberg SM, et al. Efficacy of parent-child interaction therapy: interim report of a randomized trial with short-term maintenance. J Clin Child Psychol. Mar. 1998;27(1):34-45. [pmid: 9561935].
163 Schultz PN, Remick-Barlow GA, Robbins L. Equine-assisted psychotherapy: A mental health promotion/intervention modality for children who have experienced intra-family violence. Health Soc Care Community. 2007;15(3):265-71. 2007-08684-010. [pmid: 17444990].
164 Sieracki JH, Leon SC, Miller SA, et al. Individual and provider effects on mental health outcomes in child welfare: A three level growth curve approach. Child Youth Serv Rev. 2008;30(7):800-8. 2008-07714-011.
165 Silovsky JF, Bard D, Chaffin M, et al. Prevention of child maltreatment in high-risk rural families: A randomized clinical trial with child welfare outcomes. Child Youth Serv Rev. 2011;33(8):1435-44.
166 Smith DK. Risk, Reinforcement, Retention in Treatment, and Reoffending for Boys and Girls in Multidimensional Treatment Foster Care. J Emot Behav Disord. 2004;12(1):38-48. 2004-12133-005.
167 Smith DK, Chamberlain P, Eddy JM. Preliminary support for multidimensional treatment foster care in reducing substance use in delinquent boys. J Child Adolesc Subst Abuse. 2010;19(4):343-58. 2010-17612-006. [pmid: 20953309].
168 Solhkhah R, Passman CL, Lavezzi G, et al. Effectiveness of a children’s home and community-based services waiver program. Psychiatric Quarterly. 2007;78(3):211-8. 2008-02137-006. [pmid: 17562179].
169 Spinhoven P, Slee N, Garnefski N, et al. Childhood sexual abuse differentially predicts outcome of cognitive-behavioral therapy for deliberate self-harm. J Nerv Ment Dis. Jun. 2009;197(6):455-7. [pmid: 19525747].
170 Steele M, Murphy A, Steele H. Identifying therapeutic action in an attachment-centered intervention with high risk families. Clin Soc Work J. 2010;38(1):61-72. 2010-03016-007.
171 Stein BD, Jaycox LH, Kataoka SH, et al. A mental health intervention for schoolchildren exposed to violence: a randomized controlled trial. JAMA. Aug. 6. 2003;290(5):603-11. [pmid: 12902363].
172 Stevens JR, Kymissis PI, Baker AJL. Elevated prolactin levels in male youths treated with risperidone and quetiapine. J Child Adolesc Psychopharmacol. 2005;15(6):893-900. 2006-00620-008. [pmid: 16379509].
173 Stewart J, Galvin J, Froude EH, et al. Evaluation of the Australian adaptation of the Keeping It Together (KIT-Australia) information package with carers of children with special needs. Aust Occup Ther J. 2010;57(4):268-75. 2010-15345-009. [pmid: 20854602].
174 Strozier A, McGrew L, Krisman K, et al. Kinship care connection: A school-based intervention for kinship caregivers and the children in their care. Child Youth Serv Rev. 2005;27(9):1011-29. 2005-08017-003.
175 Sullivan CM, Bybee DI, Allen NE. Findings from a community-based program for battered women and their children. J Interpers Violence. 2002;17(9):915-36. 2002-18015-001.
176 Sullivan M, Egan M, Gooch M. Conjoint Interventions for Adult Victims and Children of Domestic Violence: A Program Evaluation. Res Soc Work Pract. 2004;14(3):163-70. 2004-13419-003.
177 Sullivan PM, Scanlan JM, Brookhouser PE, et al. The effects of psychotherapy on behavior problems of sexually abused deaf children. Child Abuse Negl. 1992;16(2):297-307. [pmid: 1559177].
178 Swenson CC, Schaeffer CM, Henggeler SW, et al. Multisystemic Therapy for Child Abuse and Neglect: a randomized effectiveness trial. J Fam Psychol. Aug. 2010;24(4):497-507. [pmid: 20731496].
179 Taylor JE, Harvey ST. Effects of psychotherapy with people who have been sexually assaulted: A meta-analysis. Aggress Violent Behav. 2009;14:273-85.
180 Taylor TL, Chemtob CM. Efficacy of treatment for child and adolescent traumatic stress. Arch Pediatr Adolesc Med. Aug. 2004;158(8):786-91. [pmid: 15289252].
181 Tener D, Lang-Franco N, Ofir S, et al. The use of medical clowns as a psychological distress buffer during anogenital examination of sexually abused children. J Loss Trauma. 2012;17(1):12-22. 2012-00190-002. First Author & Affiliation: Tener, Dafna.
182 Thomas R, Zimmer-Gembeck MJ. Accumulating evidence for parent-child interaction therapy in the prevention of child maltreatment. Child Dev. Jan–Feb. 2011;82(1):177-92. [pmid: 21291436].
183 Timmer SG, Zebell NM, Culver MA, et al. Efficacy of Adjunct In-Home Coaching to Improve Outcomes in Parent—Child Interaction Therapy. Res Soc Work Pract. January. 1. 2010. 2010;20(1):36-45.
184 Tourigny M, Hebert M. Comparison of open versus closed group interventions for sexually abused adolescent girls. Violence Vict. 2007;22(3):334-49. [pmid: 17619638].
185 Tourigny M, Hebert M, Daigneault I, et al. Efficacy of a group therapy for sexually abused adolescent girls. J Child Sex Abus. 2005;14(4):71-93. [pmid: 16354649].
186 Turner KM, Sanders MR. Help when it’s needed first: a controlled evaluation of brief, preventive behavioral family intervention in a primary care setting. Behav Ther. Jun. 2006;37(2):131-42. [pmid: 16942967].
187 Tyndall-Lind A, Landreth GL, Giordano MA. Intensive group play therapy with child witnesses of domestic violence. Int J Play Ther. 2001;10(1):53-83. 2001-05142-003.
188 Van Puyenbroeck H, Loots G, Grietens H, et al. Intensive family preservation services in Flanders: An outcome study. Child Fam Soc Work. 2009;14(2):222-32. 2009-04831-010.
189 Vorhies V, Glover CM, Davis K, et al. Improving outcomes for pregnant and parenting foster care youth with severe mental illness: an evaluation of a transitional living program. Psychiatr Rehabil J. Fall. 2009;33(2):115-24. [pmid: 19808207].
190 Wadaa NN, Zaharim NM, Alqashan HF. The Use of EMDR in Treatment of Traumatized Iraqi Children. Domes. 2010;19(1):26-36.
191 Walton E. In-home family-focused reunification: A six-year follow-up of a successful experiment. Soc Work Res. 1998;22(4):205-14. 2000-05214-002.
192 Walton E, Fraser MW, Lewis RE, et al. In-home family-focused reunification: an experimental study. Child Welfare. Sep–Oct. 1993;72(5):473-87. [pmid: 8404251].
193 Webster-Stratton C. Preventing conduct problems in Head Start children: strengthening parenting competencies. J Consult Clin Psychol. Oct. 1998;66(5):715-30. [pmid: 9803690].
194 Webster-Stratton C, Reid MJ, Hammond M. Preventing conduct problems, promoting social competence: a parent and teacher training partnership in head start. J Clin Child Psychol. Sep. 2001;30(3):283-302. [pmid: 11501247].
195 Weiner DA, Schneider A, Lyons JS. Evidence-based treatments for trauma among culturally diverse foster care youth: Treatment retention and outcomes. Child Youth Serv Rev. 2009;31(11):1199-205. 2009-17740-001.
196 Werner S, Edwards M, Baum NT. Family quality of life before and after out-of-home placement of a family member with an intellectual disability. J Policy Pract Intellect Disabil. 2009;6(1):32-9. 2009-04068-007.
197 Wesch D, Lutzker JR. A comprehensive 5-year evaluation of Project 12-Ways: An ecobehavioral program for treating and preventing child abuse and neglect. J Fam Violence. 1991;6(1):17-35. 1991-25102-001.
198 Westermark PK, Hansson K, Olsson M. Multidimensional treatment foster care (MTFC): Results from an independent replication. J Fam Ther. 2011;33(1):20-41. 2011-00923-003.
199 Williams NJ, Sherr ME. Children’s psychosocial rehabilitation: Clinical outcomes for youth with serious emotional disturbance living in foster care. Child Adolesc Social Work J. 2009;26(3):225-34. 2009-08407-004.
200 Wilson SA, Becker LA, Tinker RH. Eye movement desensitization and reprocessing (EMDR) treatment for psychologically traumatized individuals. J Consult Clin Psychol. Dec. 1995;63(6):928-37. [pmid: 8543715].
201 Wilson SA, Becker LA, Tinker RH. Fifteen-month follow-up of eye movement desensitization and reprocessing (EMDR) treatment for posttraumatic stress disorder and psychological trauma. J Consult Clin Psychol. Dec. 1997;65(6):1047-56. [pmid: 9420367].
202 Wolfe DA, Wekerle C, Scott K, et al. Dating violence prevention with at-risk youth: a controlled outcome evaluation. J Consult Clin Psychol. Apr. 2003;71(2):279-91. [pmid: 12699022].
203 Zahr L. An integrative research review of intervention studies with premature infants from disadvantaged backgrounds. Matern Child Nurs J. Jul–Sep. 1994;22(3):90-101. [pmid: 7815849].

## Wrong Intervention (N=42)

1 Antle BF, Barbee AP, Christensen DN, et al. The prevention of child maltreatment recidivism through the Solution-Based Casework model of child welfare practice. Child Youth Serv Rev. 2009;31(12):1346-51. 2009-13910-001.
2 Bavolek SJ, Comstock CM, McLaughlin JW. The Nurturing Program: A Validated Approach for Reducing Dysfuntional Family Interactions. Available at.
3 Berzin SC, Cohen E, Thomas K, et al. Does family group decision making affect child welfare outcomes? Findings from a randomized control study. Child Welfare. 2008;87(4):35-54. [pmid: 19391466].
4 Boles SM, Young NK, Moore T, et al. The Sacramento Dependency Drug Court: Development and outcomes. Child Maltreat. 2007;12(2):161-71. 2007-06642-006. [pmid: 17446569].
5 Brook J, McDonald TP. Evaluating the effects of comprehensive substance abuse intervention on successful reunification. Res Social Work Prac. 2007;17(6):664-73. 2007-15761-002.
6 Cameron G, Birnie-Lefcovitch S. Parent mutual aid organizations in child welfare demonstration project: A report of outcomes. Child Youth Serv Rev. 2000;22(6):421-40. 2000-05095-002.
7 Clark HB, Crosland KA, Geller D, et al. A functional approach to reducing runaway behavior and stabilizing placements for adolescents in foster care. Res Social Work Prac. 2008;18(5):429-41. 2008-12039-008.
8 Congdon D. Evaluating the effectiveness of infant mental health enhanced case management for dependency populations. J Evid Based Soc Work. Oct. 2010;7(5):481-7. [pmid: 21082476].
9 Courtney ME, Blakey J. Examination of the impact of increased court review on permanency outcomes for abused and neglected children. Family Court Review. 2003;41(4):471-9. 2003-08484-004.
10 Culp RE, Little V, Letts D, et al. Maltreated children’s self-concept: effects of a comprehensive treatment program. Am J Orthopsychiatry. Jan. 1991;61(1):114-21. [pmid: 2006667].
11 Davidson-Arad B, Englechin-Segal D, Wozner Y. Short-term follow-up of children at risk: comparison of the quality of life of children removed from home and children remaining at home. Child Abuse Negl. Jul. 2003;27(7):733-50. [pmid: 14627076].
12 DeSena AD, Murphy RA, Douglas-Palumberi H, et al. SAFE Homes: is it worth the cost? An evaluation of a group home permanency planning program for children who first enter out-of-home care. Child Abuse Negl. Jun. 2005;29(6):627-43. [pmid: 15979706].
13 Fernandez E. Children’s wellbeing in care: Evidence from a longitudinal study of outcomes. Child Youth Serv Rev. 2009;31(10):1092-100. 2009-14603-001.
14 Finn J, Kerman B, LeCornec J. Building Skills-Building Futures: Providing Information Technology to Foster Families. Families in Society. 2004;85(2):165-76. 2004-16410-004.
15 Heneghan AM, Horwitz SM, Leventhal JM. Evaluating intensive family preservation programs: a methodological review. Pediatrics. Apr. 1996;97(4):535-42. [pmid: 8632942].
16 Hodnett RH, Faulk K, Delinger A, et al. Evaluation of the Statewide Implementation of a Parent Education Program in Louisiana’s Child Welfare Agency: The Nurturing Parenting Program for Infants, Toddlers, and Pre-School Children. 2009. Available at: www.casey.org/Resources/Publications/pdf/EvaluationParentEdLA_FR.pdf.
17 Jaudes PK, Bilaver LA, Goerge RM, et al. Improving access to health care for foster children: The Illinois model. Child Welfare: Journal of Policy, Practice, and Program. 2004;83(3):215-38. 2004-14791-002.
18 Jenson JM, Jacobson M, Unrau Y, et al. Intervention for victims of child sexual abuse: An evaluation of the children’s advocacy model. Child Adolesc Soc Work J. 1996;13:139-56.
19 Johnson K, Wagner D. Evaluation of Michigan’s Foster Care Case Management System. Res Social Work Prac. 2005;15(5):372-80. 2005-08684-005.
20 Kirk R, Day A. Increasing college access for youth aging out of foster care: Evaluation of a summer camp program for foster youth transitioning from high school to college. Child Youth Serv Rev. 2011;33(7):1173-80. 2011-05458-001.
21 Kirk RS, Griffith DP. Intensive Family Preservation Services: Demonstrating Placement Prevention Using Event History Analysis. Soc Work Res. 2003;28:5-18.
22 Kirk RS, Griffith DP. Impact of intensive family preservation services on disproportionality of out-of-home placement of children of color in one state’s child welfare system. Child Welfare: Journal of Policy, Practice, and Program. 2008;87(5):87-105. 2009-04575-005.
23 Lawrence CR, Carlson EA, Egeland B. The impact of foster care on development. Dev Psychopathol. Winter. 2006;18(1):57-76. [pmid: 16478552].
24 Litzelfelner P. The effectiveness of CASAs in achieving positive outcomes for children. Child Welfare. 2000:179-93. [pmid: 10732258].
25 Loman A, Siegel GL. Alternative response in Minnesota: Findings of the program evaluation. Protecting Children. 2005;20(2/3):78-92.
26 MacLeod KJ, Marcin JP, Boyle C, et al. Using telemedicine to improve the care delivered to sexually abused children in rural, underserved hospitals. Pediatrics. Jan. 2009;123(1):223-8. [pmid: 19117886].
27 Marshall SK, Charles G, Kendrick K, et al. Comparing differential responses within child protective services: a longitudinal examination. Child Welfare. 2010;89(3):57-77. [pmid: 20945805].
28 McCombs-Thornton KL, Foster EM. The effect of the ZERO TO THREE court teams initiative on types of exits from the foster care system—A competing risks analysis. Child Youth Serv Rev. 2012;34(1):169-78. 2011-30269-009. First Author & Affiliation: McCombs-Thornton, Kimberly L.
29 Olsen LJ. Services for substance abuse-affected families: The Project Connect Experience. Child Adolesc Soc Work J. 1995;12(3):183-96.
30 Patterson D, Campbell R. A comparative study of the prosecution of childhood sexual abuse cases: the contributory role of pediatric Forensic Nurse Examiner (FNE) programs. J Forensic Nurs. 2009;5(1):38-45. [pmid: 19222688].
31 Rees CA, Selwyn J. Non-infant adoption from care: lessons for safeguarding children. Child Care Health Dev. Jul. 2009;35(4):561-7. [pmid: 19638026].
32 Rodenhiser RW, Chandy J, Ahmed K. Intensive Family Preservation Services: Do They Have Any Impact on Family Functioning. Family Preservation Journal Summer. 1995:69-85.
33 Sakai C, Lin H, Flores G. Health outcomes and family services in kinship care: analysis of a national sample of children in the child welfare system. Arch Pediatr Adolesc Med. Feb. 2011;165(2):159-65. [pmid: 21300656].
34 Shemesh E, Annunziato RA, Yehuda R, et al. Childhood abuse, nonadherence, and medical outcome in pediatric liver transplant recipients. J Am Acad Child Adolesc Psychiatry. Oct. 2007;46(10):1280-9. WOS:000249802900005. [pmid: 17885569].
35 Sundell K, Vinnerljung B. Outcomes of family group conferencing in Sweden. A 3-year follow-up. Child Abuse Negl. Mar. 2004;28(3):267-87. [pmid: 15066346].
36 Swenson CC, Randall J, Henggeler SW, et al. The outcomes and costs of an interagency partnership to serve maltreated children in state custody. Children’s Services: Social Policy, Research, &, Practice. 2000;3(4):191-209. 2000-16020-001.
37 Testa M, Rolock N. Professional foster care: A future worth pursuing?. Child Welfare. 1999;78(1):108-24.
38 Testa MF. Subsidized guardianship: Testing an idea whose time has finally come. Soc Work Res. 2002;26(3):145-58. 2002-18968-002.
39 Timmer SG, Urquiza AJ, Zebell N. Challenging foster caregiver-maltreated child relationships: The effectiveness of parent-child interaction therapy. Child Youth Serv Rev. 2006;28(1):1-19. 2005-16529-001.
40 Walton E. Enhancing investigative decisions in child welfare: an exploratory use of intensive family preservation services. Child Welfare. May–Jun. 1997;76(3):447-61. [pmid: 9130381].
41 Waxman HC, Houston WR, Profilet SM, et al. The long-term effects of the Houston Child Advocates, Inc., program on children and family outcomes. Child Welfare. 2009;88(6):23-46. [pmid: 20695290].
42 Zetlin A, Weinberg L, Kimm C. Improving Education Outcomes for Children in Foster Care: Intervention by an Education Liaison. Journal of Education for Students Placed at Risk. 2004;9(4):421-9. 2004-18309-005.

## Wrong Comparison (N=59)

1 Whitemore E, Ford M, Sack WH. Effectiveness of Day Treatment with Proctor Care for Young Children: A Four-Year Follow-Up. J Community Psychol. 2003;31(5):459-68. 2004-11654-002.
2 Veltkamp L, Miller TW, Kearl GW, et al. Interdisciplinary treatment of abused families in Kentucky. J Ky Med Assoc. May. 1992;90(5):232-9. [pmid: 1613336].
3 Treacy EC, Fisher CB. Foster parenting the sexually abused: a family life education program. Journal of Child Sexual Abuse. 1993;2(1):47-63.
4 Timmer SG, Ware LM, Urquiza AJ, et al. The effectiveness of parent-child interaction therapy for victims of interparental violence. Violence Vict. 2010;25(4):486-503. [pmid: 20712147].
5 Timmer SG, Urquiza AJ, Zebell NM, et al. Parent-Child Interaction Therapy: Application to maltreating parent-child dyads. Child Abuse Negl. 2005;29(7):825-42. 2005-09287-007. [pmid: 16051355].
6 Timmer SG, Urquiza AJ, Herschell AD, et al. Parent-Child Interaction Therapy: Application of an Empirically Supported Treatment to Maltreated Children in Foster Care. Child Welfare: Journal of Policy, Practice, and Program. 2006;85(6):919-39. 2007-01431-002.
7 Stubenbort K, Cohen MM, Trybalski V. The effectiveness of an attachment-focused treatment model in a therapeutic preschool for abused children. Clinical Social Work Journal. 2010;38(1):51-60. 2010-03016-006.
8 Stauffer LB, Deblinger E. Cognitive behavioral groups for nonoffending mothers and their young sexually abused children: A preliminary treatment outcome study. Child Maltreat. 1996;1(1):65-76. 1997-43260-006.
9 Staines J, Farmer E, Selwyn J. Implementing a therapeutic team parenting approach to fostering: The experiences of one independent foster-care agency. British Journal of Social Work. 2011;41(2):314-32. 2011-07757-007.
10 Smith DK, Stormshak E, Chamberlain P, et al. Placement disruption in treatment foster care. Journal of Emotional and Behavioral Disorders. 2001;9(3):200-5. 2001-11310-006.
11 Smagner JP, Sullivan MH. Investigating the Effectiveness of Behavioral Parent Training With Involuntary Clients in Child Welfare Settings. Res Social Work Prac. 2005;15(6):431-9. 2005-12558-002.
12 Slesnick N, Bartle-Haring S, Gangamma R. Predictors of substance use and family therapy outcome among physically and sexually abused runaway adolescents. J Marital Fam Ther. Jul. 2006;32(3):261-81. [pmid: 16933433].
13 Shamseddeen W, Asarnow JR, Clarke G, et al. Impact of physical and sexual abuse on treatment response in the Treatment of Resistant Depression in Adolescent Study (TORDIA). J Am Acad Child Adolesc Psychiatry. Mar. 2011;50(3):293-301. [pmid: 21334569].
14 Sewak A, Hwang R, Desir B, et al. The suitability of PCIT for sexually abused children. 2005. Annual Parent-Child Interaction Therapy Conference. 2005. Sacramento, CA. PCIT citation #18.
15 Scott TA, Burlingame G, Starling M, et al. Effects of individual client-centered play therapy on sexually abused children’s mood, self-concept, and social competence. International Journal of Play Therapy. 2003;12(1):7-30. 2003-05749-002.
16 Ryan JP, Schuerman JR. Matching family problems with specific family preservation services: a study of service effectiveness. Child Youth Serv Rev. 2004;26(4):347-72. 2004-95119-002.
17 Runyon MK, Deblinger E, Schroeder CM. Pilot evaluation of outcomes of combined parent-child cognitive-behavioral group therapy for families at risk for child physical abuse. Cognitive and Behavioral Practice. 2009;16(1):101-18. 2009-06469-012.
18 Reeker J, Ensing D, Elliott R. A meta-analytic investigation of group treatment outcomes for sexually abused children. Child Abuse Negl. Jul. 1997;21(7):669-80. [pmid: 9238550].
19 Reeker J, Ensing D. An evaluation of a group treatment for sexually abused young children. Journal of Child Sexual Abuse. 1998;7:65-85.
20 Purvis KB, Cross DR. Improvements in salivary cortisol, depression, and representations of family relationships in at-risk adopted children utilizing a short-term therapeutic intervention. Adoption Quarterly. 2007;10(1):25-43. 2007-05976-002.
21 Osofsky JD, Kronenberg M, Hammer JH, et al. The development and evaluation of the intervention model for the Florida Infant Mental Health Pilot Program. Infant Ment Health J. 2007;28(3):259-80. 2007-07668-001. First Author & Affiliation: Osofsky, Joy D.
22 O’Brien M. Measuring the effectiveness of routine child protection services: The results from an evidence based strategy. Child & Youth Services. 2011;32(4):303-16. 2011-30022-005. First Author & Affiliation: O’Brien, Michael.
23 Moore E, Armsden G, Gogerty PL. A twelve-year follow-up study of maltreated and at-risk children who received early therapeutic child care. Child Maltreat. 1998;3(1):3-16. 1997-39106-001.
24 Monck E. Evaluating therapeutic intervention with sexually abused children. Child Abuse Review. 1997;6(3):163-77. 1999-00066-001.
25 Misurell JR, Springer C, Tryon WW. Game-based cognitive-behavioral therapy (GB-CBT) group program for children who have experienced sexual abuse: A preliminary investigation. Journal of Child Sexual Abuse: Research, Treatment, & Program Innovations for Victims, Survivors, & Offenders. 2011;20(1):14-36. 2011-01562-002.
26 Mishna F. Meeting them ‘where they’re at’: Intensive school-based psychotherapy for children who have been maltreated. Psychoanalytic Social Work. 2007;14(2):15-42. 2007-18486-003.
27 McWey LM, Mullis AK. Improving the lives of children in foster care: The impact of supervised visitation. Family Relations. 2004;53(3):293-300. 2004-15875-005.
28 McNeil CB, Herschell AD, Gurwitch RH, et al. Training foster parents in parent-child interaction therapy. Education & Treatment of Children. 2005;28(2):182-96. 2006-06834-006.
29 McGuinness TM, Mason M, Tolbert G, et al. Becoming responsible teens: Promoting the health of adolescents in foster care. Journal of the American Psychiatric Nurses Association. 2002;8(3):92-8. 2002-13914-004.
30 Maynard J. Permanency Mediation: A Path to Open Adoption for Children in Out-of-Home Care. Child Welfare: Journal of Policy, Practice, and Program. 2005;84(4):507-26. 2005-07659-004.
31 Mathews TL, Fawcett SB, Sheldon JB. Effects of a peer engagement program on socially withdrawn children with a history of maltreatment. Child Fam Behav Ther. 2009;31(4):270-91. 2010-11652-002.
32 Lindon J, Nourse CA. A multi-dimensional model of groupwork for adolescent girls who have been sexually abused. Child Abuse Negl. Apr. 1994;18(4):341-8. [pmid: 8187019].
33 Lange A, Ruwaard J. Ethical dilemmas in online research and treatment of sexually abused adolescents. J Med Internet Res. 2010;12(5):e58. [pmid: 21169170].
34 Landy S, Munro S. Shared parenting: Assessing the success of a foster parent program aimed at family reunification. Child Abuse Negl. 1998;22(4):305-18. 1998-02289-003. [pmid: 9589181].
35 Kriebel DK, Wigfield A, Reilly D, et al. Preparing for Change: Results from a Therapeutic Intervention with Foster Children in the Midst of Permanency Planning. Adoption Quarterly. 2002;6(2):59-65. 2003-07207-004.
36 Koob JJ, Love SM. The implementation of solution-focused therapy to increase foster care placement stability. Child Youth Serv Rev. 2010;32(10):1346-50. 2010-17145-009.
37 Kolko DJ. Individual cognitive behavioral treatment and family therapy for physically abused children and their offending parents: A comparison of clinical outcomes. Child Maltreat. 1996;1:322-42.
38 Harder J. Prevention of Child Abuse and Neglect: An Evaluation of a Home Visitation Parent Aide Program Using Recidivism Data. Res Social Work Prac. 2005;15(4):246-56. 2005-05881-002.
39 Hansen ME. Using subsidies to promote the adoption of children from foster care. Journal of Family and Economic Issues. Sep. 1. 2007;28(3):377-93. [pmid: 19242555].
40 Habigzang LF, Stroeher FH, Hatzenberger R, et al. Cognitive behavioral group therapy for sexually abused girls. Rev Saude Publica. 2009:70-8. [pmid: 19669067].
41 Grella CE, Needell B, Shi Y, et al. Do drug treatment services predict reunification outcomes of mothers and their children in child welfare?. J Subst Abuse Treat. 2009;36(3):278-93. 2009-03411-007. [pmid: 18775623].
42 Gray J, Nielsen DR, Wood LE, et al. Academic progress of children who attended a preschool for abused children: a follow-up of the keepsafe project. Child Abuse Negl. Jan. 2000;24(1):25-32. [pmid: 10660007].
43 Gershater-Molko RM, Lutzker JR, Wesch D. Project SafeCare: Improving health, safety, and parenting skills in families reported for, and at-risk for child maltreatment. Journal of Family Violence. 2003;18(6):377-86. 2003-09468-008.
44 Gerring CE, Kemp SP, Marcenko MO. The Connections Project: A relational approach to engaging birth parents in visitation. Child Welfare: Journal of Policy, Practice, and Program. 2008;87(6):5-30. 2009-07883-001.
45 Finn J, Kerman B, LeCornec J. Reducing the Digital Divide for Children in Foster Care: First-Year Evaluation of the Building Skills-Building Futures Program. Res Social Work Prac. 2005;15(6):470-80. 2005-12558-006.
46 Fantuzzo J, Sutton-Smith B, Atkins M, et al. Community-based resilient peer treatment of withdrawn maltreated preschool children. J Consult Clin Psychol. Dec. 1996;64(6):1377-86. [pmid: 8991324].
47 Fantuzzo J, Manz P, Atkins M, et al. Peer-mediated treatment of socially withdrawn maltreated preschool children: cultivating natural community resources. J Clin Child Adolesc Psychol. Jun. 2005;34(2):320-5. [pmid: 15901232].
48 Deblinger E, Steer RA, Lippmann J. Two-year follow-up study of cognitive behavioral therapy for sexually abused children suffering post-traumatic stress symptoms. Child Abuse Negl. Dec. 1999;23(12):1371-8. [pmid: 10626618].
49 Deblinger E, Mannarino AP, Cohen JA, et al. Trauma-focused cognitive behavioral therapy for children: impact of the trauma narrative and treatment length. Depress Anxiety. Jan. 2011;28(1):67-75. [pmid: 20830695].
50 Deblinger E, Lippmann J, Steer R. Sexually Abused Children Suffering Posttraumatic Stress Symptoms: Initial Treatment Outcome Findings. Child Maltreat. 1996;1(4):310-21.
51 de Paúl J, Arruabarrena I. Evaluation of a Treatment Program for Abusive and High-Risk Families in Spain. Child Welfare: Journal of Policy, Practice, and Program. 2003;82(4):413-41. 2003-99394-002.
52 Crusto CA, Lowell DI, Paulicin B, et al. Evaluation of a wraparound process for children exposed to family violence. Best Practices in Mental Health: An International Journal. 2008;4(1):1-18. 2008-01658-002.
53 Collado C, Levine P. Reducing transfers of children in family foster care through onsite mental health interventions. Child Welfare: Journal of Policy, Practice, and Program. 2007;86(5):133-50. 2008-02808-008.
54 Cohen JA, Mannarino AP. Predictors of treatment outcome in sexually abused children. Child Abuse Negl. Jul. 2000;24(7):983-94. [pmid: 10905421].
55 Cohen JA, Mannarino AP. Factors that mediate treatment outcome of sexually abused preschool children: six- and 12-month follow-up. J Am Acad Child Adolesc Psychiatry. Jan. 1998;37(1):44-51. [pmid: 9444899].
56 Cicchetti D, Rogosch FA, Toth SL, et al. Normalizing the development of cortisol regulation in maltreated infants through preventive interventions. Dev Psychopathol. 2011;23(3):789-800. 2011-16581-004. [pmid: 21756432].
57 Berg B, Jones DP. Outcome of psychiatric intervention in factitious illness by proxy (Munchausen’s syndrome by proxy). Arch Dis Child. Dec. 1999;81(6):465-72. [pmid: 10569958].
58 Becker KD, Mathis G, Mueller CW, et al. Community-based treatment outcomes for parents and children exposed to domestic violence. Journal of Emotional Abuse. 2008;8(1–2):187-204. 2008-18644-012.
59 Antle BF, Barbee AP, Christenses DN, et al. Solution-Based Casework in Child Welfare: Preliminary Evaluation Research Journal of Public Child Welfare. 2008;2(2):197-227.

## Wrong Outcome (N=12)

1 Bechtel K, Ryan E, Gallagher D. Impact of sexual assault nurse examiners on the evaluation of sexual assault in a pediatric emergency department. Pediatr Emerg Care. Jul. 2008;24(7):442-7. [pmid: 18580706].
2 Corcoran J, Allen S. The Effects of a Police/Victim Assistance Crisis Team Approach to Domestic Violence. Journal of Family Violence. 2005;20(1):39-45. 2005-03733-006.
3 Edinburgh L, Saewyc E, Levitt C. Caring for young adolescent sexual abuse victims in a hospital-based children’s advocacy center. Child Abuse Negl. Dec. 2008;32(12):1119-26. [pmid: 19041133].
4 Haight WL, Mangelsdorf S, Black J, et al. Enhancing parent-child interaction during foster care visits: experimental assessment of an intervention. Child Welfare. Jul–Aug. 2005;84(4):459-81. [pmid: 16117259].
5 Horwitz SM, Owens P, Simms MD. Specialized assessments for children in foster care. Pediatrics. Jul. 2000;106(1 Pt 1):59-66. [pmid: 10878150].
6 Hughes JR, Gottlieb LN. The effects of the Webster-Stratton parenting program on maltreating families: fostering strengths. Child Abuse Negl. Oct. 2004;28(10):1081-97. [pmid: 15519437].
7 Leve LD, Chamberlain P. Association with Delinquent Peers: Intervention Effects for Youth in the Juvenile Justice System. Journal of Abnormal Child Psychology: An official publication of the International Society for Research in Child and Adolescent Psychopathology. 2005;33(3):339-47. 2005-04901-007.
8 Minnis H, Devine C. The effect of foster carer training on the emotional and behavioural functioning of looked after children. Adoption and Fostering. 2001;25(1):44-54.
9 N’zi AM, Steve ML, Eyberg SM. Child directed interaction training for kinship caregivers. 2012.
10 Pacifici C, Delaney R, White L, et al. Web-based training for foster, adoptive, and kinship parents. Child Youth Serv Rev. 2006;28(11):1329-43. 2006-11655-005.
11 Risley-Curtiss C, Stites B. Improving healthcare for children entering foster care. Child Welfare: Journal of Policy, Practice, and Program. 2007;86(4):123-44. 2007-15243-006.
12 Weigensberg EC, Barth RP, Guo S. Family group decision making: A propensity score analysis to evaluate child and family services at baseline and after 36-months. Child Youth Serv Rev. 2009;31(3):383-90. 2009-02007-015.

## Wrong Timing (N=1)

1 Kolko DJ. Clinical monitoring of treatment course in child physical abuse: psychometric characteristics and treatment comparisons. Child Abuse Negl. Jan. 1996;20(1):23-43. [pmid: 8640423].

## Systematic Review With Different I/E Criteria (e.g., Included Publications Before 1990)

1 Allin H, Wathen CN, MacMillan H. Treatment of child neglect: a systematic review. Can J Psychiatry. Jul. 2005;50(8):497-504. [pmid: 16127968].
2 Barlow J, Johnston I, Kendrick D, et al. Individual and group-based parenting programmes for the treatment of physical child abuse and neglect. Cochrane Database Syst Rev. 2006;3:CD005463. [pmid: 16856097].
3 Corcoran J, Pillai V. A meta-analysis of parent-involved treatment for child sexual abuse. Res Social Work Prac. Sep. 2008;18(5):453-64. WOS:000258415700010.
4 Harvey ST, Taylor JE. A meta-analysis of the effects of psychotherapy with sexually abused children and adolescents. Clin Psychol Rev. Jul. 2010;30(5):517-35. [pmid: 20417003].
5 Hetzel-Riggin MD, Brausch AM, Montgomery BS. A meta-analytic investigation of therapy modality outcomes for sexually abused children and adolescents: an exploratory study. Child Abuse Negl. Feb. 2007;31(2):125-41. [pmid: 17306369].
6 Macdonald GM, Higgins JP, Ramchandani P. Cognitive-behavioural interventions for children who have been sexually abused. Cochrane Database Syst Rev. 2006;(4):CD001930. [pmid: 17054148].
7 Macdonald GM, Turner W. Treatment foster care for improving outcomes in children and young people. Cochrane Database Syst Rev. 2008;(1):CD005649. [pmid: 18254087].
8 MacLeod J, Nelson G. Programs for the promotion of family wellness and the prevention of child maltreatment: a meta-analytic review. Child Abuse Negl. Sep. 2000;24(9):1127-49. [pmid: 11057701].
9 Ramchandani P, Jones DP. Treating psychological symptoms in sexually abused children: from research findings to service provision. Br J Psychiatry. Dec. 2003;183:484-90. [pmid: 14645018].
10 Turner W, Macdonald G, Dennis Jane A. Behavioural and cognitive behavioural training interventions for assisting foster carers in the management of difficult behaviour. Cochrane Database Syst Rev. Chichester, UK. John Wiley & Sons, Ltd. 2007.
11 Turner W, Macdonald GM, Dennis JA. Cognitive-behavioural training interventions for assisting foster carers in the management of difficult behaviour. Cochrane Database Syst Rev. 2007;(1):CD003760. [pmid: 17253496].