# Full Text Review Form

Author Last name, year:
Does this study assess the effects of an intervention?; - Yes; - No
Are ALL participants in the population of interest? OR Is there a sub-group of participants relevant and with outcome data stratified accordingly?; - Yes; - No
Does the study include an intervention of interest?; - Yes; - No
Does this study include a comparison of interest?; - Yes; - No
Does the study include outcomes relevant to 1 or more key questions?; - Yes; - No
Which best describes the study design?; - Randomized controlled trial (RCT); - Non-randomized controlled trial (NCT); - Prospective cohort; - Retrospective cohort; - Case-control; - Nested case-control; - Systematic Review; - Something else
Is the sample size ≥ 10; - Yes; - No