# Literature Search Strategy

PubMed—Conducted 26 September 2011

Search | Most Recent Queries | Result
#1 | Search “Child Abuse”[Mesh] OR “Child Welfare”[Mesh] OR “Infant Welfare”[Mesh] OR “Domestic Violence”[Mesh] OR “Foster Home Care”[Mesh] | 55628
#2 | Search “child abuse”[tiab] OR “child maltreatment”[tiab] OR “neglect”[tiab] OR “domestic violence”[tiab] OR “child welfare”[tiab] OR “foster care”[tiab] OR “kinship care”[tiab] OR “out of home care”[tiab] OR “out of home placement”[tiab] OR “looked after child”[tiab] OR “looked after young”[tiab] OR child protective service* OR physical abuse* | 23738
#3 | Search #1 OR #2 | 66583
#4 | Search “Adolescent”[Mesh] OR “Child”[Mesh] OR “Infant”[Mesh] | 2552525
#5 | Search #3 AND #4 | 47627
#6 | Search #5 Limits: Humans, English | 41282
#7 | Search ((#6) AND “1990/01/01”[Publication Date] : “2011/10/01”[Publication Date]) AND “0”[Publication Date]: “3000”[Publication Date] | 33533
#8 | Search “intervention”[tiab] OR “interventions”[tiab] OR “treatment”[tiab] OR “treatments”[tiab] OR “therapy”[tiab] OR “therapies”[tiab] OR “therapeutic”[tiab] OR “training”[tiab] OR “psychoeducation”[tiab] OR “program”[tiab] OR “programs”[tiab] | 4040391
#9 | Search “Intervention Studies”[Mesh] | 4862
#10 | Search “Psychotherapy”[Mesh] | 134066
#11 | Search “Complementary Therapies”[Mesh] | 151249
#12 | Search “Psychotropic Drugs”[Mesh] | 114945
#13 | Search Antidepressive Agents [Pharmacological Action] | 109682
#14 | Search Monoamine Oxidase Inhibitors [Pharmacological Action] | 18977
#15 | Search Anticonvulsants [Pharmacological Action] | 120174
#16 | Search Adrenergic Agents [Pharmacological Action] | 301728
#17 | Search Antipsychotic Agents [Pharmacological Action] | 114583
#18 | Search Tranquilizing Agents [Pharmacological Action] | 168679
#19 | Search “Benzodiazepines”[MeSH] | 54507
#20 | Search “Opiate Alkaloids”[Mesh] | 69593
#21 | Search “Anesthetics, Dissociative” [Pharmacological Action] | 8329
#22 | Search “Drug Therapy”[Mesh] | 912570
#23 | Search #7 AND (#8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 OR #21 OR #22) | 10202
#24 | Search “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh] OR “trial”[tiab] | 611454
#25 | Search “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 50172
#26 | Search “Comparative Study”[Publication Type] OR “comparative study” | 1547696
#27 | Search (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH AND “systematic”[tiab]) | 42860
#28 | Search “Cohort Studies”[Mesh] | 1105472
#29 | Search “Observation”[Mesh] | 3766
#30 | Search “Case-Control Studies”[Mesh] | 512695
#31 | Search #23 AND (#24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30) | 2736

Update Search (May 4, 2012) N = 83

Cochrane—Conducted 26 September 2011

ID | Search | Hits
#1 | “Child Abuse”[Mesh] OR “Child Welfare”[Mesh] OR “Infant Welfare”[Mesh] OR “Domestic Violence”[Mesh] OR “Foster Home Care”[Mesh] | 995
#2 | “child abuse”[tiab] OR “child maltreatment”[tiab] OR “neglect”[tiab] OR “domestic violence”[tiab] OR “child welfare”[tiab] OR “foster care”[tiab] OR “kinship care”[tiab] OR “out of home care”[tiab] OR “out of home placement”[tiab] OR “looked after child”[tiab] OR “looked after young”[tiab] OR child protective service* OR physical abuse* | 2084
#3 | (#1 OR #2) | 2153
#4 | “Adolescent”[Mesh] OR “Child”[Mesh] OR “Infant”[Mesh] | 118022
#5 | (#3 AND #4) | 1378
#6 | “intervention”[tiab] OR “interventions”[tiab] OR “treatment”[tiab] OR “treatments”[tiab] OR “therapy”[tiab] OR “therapies”[tiab] OR “therapeutic”[tiab] OR “training”[tiab] OR “psychoeducation”[tiab] OR “program”[tiab] OR “programs”[tiab] | 446518
#7 | “Intervention Studies”[Mesh] | 2576
#8 | “Psychotherapy”[Mesh] | 6282
#9 | “Complementary Therapies”[Mesh] | 765
#10 | “Antidepressive Agents”[Pharmacological Action] | 4378
#11 | “Monoamine Oxidase Inhibitors”[Pharmacological Action] | 542
#12 | “Anticonvulsants”[Pharmacological Action] | 2055
#13 | “Adrenergic Agents”[Pharmacological Action] | 139
#14 | “Antipsychotic Agents”[Pharmacological Action] | 3254
#15 | “Tranquilizing Agents”[Pharmacological Action] | 524
#16 | “Benzodiazepines”[MeSH] | 2830
#17 | “Opiate Alkaloids”[Mesh] | 3
#18 | “Anesthetics, Dissociative”[Pharmacological Action] | 251
#19 | “Psychotropic Drugs”[Mesh] | 646
#20 | “Drug Therapy”[Mesh] | 182773
#21 | (#5 AND ( #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19 OR #20 )) | 1171
#22 | (#21), from 1990 to 2011 | 1128
#23 | “Randomized Controlled Trial”[Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh] OR “Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] OR “Random Allocation”[Mesh] OR “trial”[tiab] | 463984
#24 | “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “meta-analysis”[All Fields] | 17488
#25 | “Comparative Study”[Publication Type] OR “comparative study” | 136548
#26 | (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH AND “systematic”[tiab]) | 27441
#27 | “Cohort Studies”[Mesh] | 6943
#28 | “Observation”[Mesh] | 15866
#29 | “Case-Control Studies”[Mesh] | 4102
#30 | (#22 AND ( #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29 )) | 1041
#31 | “Humans”[Mesh] in Cochrane Reviews, Other Reviews, Clinical Trials, Methods Studies, Technology Assessments and Economic Evaluations | 412691
#32 | (#30 AND #31) | 948

Update Search (May 4, 2012) N = 591

ISI Web of Science—Conducted 26 September 2011

Set | Results | Query
# 1 | 2,141 | TS=(“child maltreatment”) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 2 | 23,588 | TS=(child) AND TS=(abuse*) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 3 | 67,944 | TS=(neglect) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 4 | 7,383 | TS=(“domestic violence”) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 5 | 3,426 | TS=(“child welfare”) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 6 | 2,706 | TS=(“foster care”) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 7 | 295 | TS=(“kinship care”) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 8 | 347 | TS=(“out of home care”) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 9 | 220 | TS=(“out of home placement”) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 10 | 2 | TS=(“looked after child”) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 11 | 11 | TS=(“looked after young”) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 12 | 1,110 | TS=(child protective service*) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 13 | 10,826 | TS=(physical abuse*) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 14 | 104,550 | #13 OR #12 OR #11 OR #10 OR #9 OR #8 OR #7 OR #6 OR #5 OR #4 OR #3 OR #2 OR #1 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 15 | 2,374,692 | TS=(“treatment”) OR TS=(“treatments”) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 16 | 396,759 | TS=(“intervention”) OR TS=(“interventions”) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 17 | 2,071,928 | TS=(“therapy”) OR TS=(“therapies”) OR TS=(“therapeutic”) OR TS=(“training”) OR TS=(“psychoeducation”) OR TS=(“program”) OR TS=(“programs”) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=All Years Lemmatization=On
# 18 | 23,048 | (TS=(Psychotherapy)) AND Language=(English) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=1990–2011 Lemmatization=On
# 19 | 3,577,518 | #18 OR #17 OR #16 OR #15 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=1990–2011 Lemmatization=On
# 20 | 23,003 | #19 AND #14 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=1990–2011 Lemmatization=On
# 21 | 92,092 | (#14) AND Language=(English) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=1990–2011 Lemmatization=On
# 22 | 1,439 | (#14) AND Language=(English) Refined by: Web of Science Categories=( PHARMACOLOGY PHARMACY OR MEDICINE RESEARCH EXPERIMENTAL ) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=1990–2011 Lemmatization=On
# 23 | 23,741 | #22 OR #20 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=1990–2011 Lemmatization=On
# 24 | 933,961 | (TS=(child*) OR TS=(youth) OR TS=(baby) OR TS=(adolescent) OR TS=(teen) OR TS=(teenager) OR TS=(toddler) OR TS=(Infant)) AND Language=(English) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=1990–2011 Lemmatization=On
# 25 | 11,218 | #24 AND #23 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=1990–2011 Lemmatization=On
# 26 | 10,701 | #24 AND #23Refined by: Document Type=( ARTICLE OR REVIEW ) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=1990–2011 Lemmatization=On
# 27 | 338,451 | (TS=(“systematic review”) OR TS=(“randomized controlled trial”) OR TS=(observational) OR TS=(“cohort study”) OR TS=(“Comparative study”) OR TS=(“meta-analysis”) OR TS=(“Case Control”)) AND Language=(English) Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=1990–2011 Lemmatization=On
# 28 | 640 | #27 AND #26 Databases=SCI-EXPANDED, SSCI, A&HCI Timespan=1990–2011 Lemmatization=On

Update Search (May 4, 2012) N = 125

PsycINFO—Conducted 29 September 2011

# | Query | Results
S27 | S25 or S26 | 2431
S26 | S12 Limiters - Publication Year from: 1990–2011; Publication Type: All Journals; English; Language: English; Age Groups: Childhood (birth-12 yrs), Neonatal (birth-1 mo), Infancy (2–23 mo), Preschool Age (2–5 yrs), School Age (6–12 yrs), Adolescence (13–17 yrs); Population Group: Human; Document Type: Journal Article; Methodology: CLINICAL CASE STUDY, -Experimental Replication, -Followup Study, -Longitudinal Study, ---Prospective Study, ---Retrospective Study, -Systematic Review, -Meta Analysis, -Qualitative Study, -Quantitative Study, TREATMENT OUTCOME/CLINICAL TRIAL; Exclude Dissertations Search modes - Boolean/Phrase | 2316
S25 | S12 and S24 Limiters - Publication Year from: 1990–2011; Publication Type: All Journals; English; Language: English; Age Groups: Childhood (birth-12 yrs), Neonatal (birth-1 mo), Infancy (2–23 mo), Preschool Age (2–5 yrs), School Age (6–12 yrs), Adolescence (13–17 yrs); Population Group: Human; Exclude Dissertations Search modes - Boolean/Phrase | 328
S24 | S13 or S14 or S15 or S16 or S17 or S18 or S19 or S20 or S21 or S22 or S23 | 221984
S23 | “case control” | 4562
S22 | Observation | 88503
S21 | cohort stud* | 8303
S20 | systematic review* | 6441
S19 | comparative Stud* | 13619
S18 | meta-analysis | 12211
S17 | trial | 98113
S16 | “Random Allocation” | 119
S15 | “Double-Blind Method” | 46
S14 | “Single-Blind Method” | 1
S13 | Randomized Controlled Trial* | 10329
S12 | S10 and S11 | 33327
S11 | S6 or S7 or S8 or S9 | 1172138
S10 | S1 or S2 or S3 or S4 or S5 | 65781
S9 | DE “Drugs” OR DE “Adrenergic Blocking Drugs” OR DE “Adrenergic Drugs” OR DE “Alcohols” OR DE “Alkaloids” OR DE “Amines” OR DE “Analgesic Drugs” OR DE “Anesthetic Drugs” OR DE “Anti Inflammatory Drugs” OR DE “Antiandrogens” OR DE “Antibiotics” OR DE “Anticoagulant Drugs” OR DE “Anticonvulsive Drugs” OR DE “Antidepressant Drugs” OR DE “Antiemetic Drugs” OR DE “Antiestrogens” OR DE “Antihistaminic Drugs” OR DE “Antihypertensive Drugs” OR DE “Antineoplastic Drugs” OR DE “Antispasmodic Drugs” OR DE “Antitremor Drugs” OR DE “Antitubercular Drugs” OR DE “Antiviral Drugs” OR DE “Appetite Depressing Drugs” OR DE “Barbiturates” OR DE “Benzodiazepines” OR DE “Bromides” OR DE “Cannabis” OR DE “Channel Blockers” OR DE “Cholinergic Blocking Drugs” OR DE “Cholinergic Drugs” OR DE “Cholinomimetic Drugs” OR DE “CNS Affecting Drugs” OR DE “Diuretics” OR DE “Dopamine Agonists” OR DE “Emetic Drugs” OR DE “Enzyme Inhibitors” OR DE “Enzymes” OR DE “Ergot Derivatives” OR DE “Ganglion Blocking Drugs” OR DE “Generic Drugs” OR DE “Hallucinogenic Drugs” OR DE “Heart Rate Affecting Drugs” OR DE “Hypnotic Drugs” OR DE “Muscle Relaxing Drugs” OR DE “Narcotic Agonists” OR DE “Narcotic Antagonists” OR DE “Narcotic Drugs” OR DE “Neurotransmitter Uptake Inhibitors” OR DE “Nonprescription Drugs” OR DE “Nootropic Drugs” OR DE “Performance Enhancing Drugs” OR DE “Prescription Drugs” OR DE “Psychotomimetic Drugs” OR DE “Respiration Stimulating Drugs” OR DE “Sedatives” OR DE “Serotonin Agonists” OR DE “Serotonin Antagonists” OR DE “Statins” OR DE “Steroids” OR DE “Sympatholytic Drugs” OR DE “Sympathomimetic Drugs” OR DE “Thimerosal” OR DE “Tranquilizing Drugs” OR DE “Vasoconstrictor Drugs” OR DE “Vasodilator Drugs” | 81289
S8 | DE “Alternative Medicine” OR DE “Acupuncture” OR DE “Aromatherapy” OR DE “Faith Healing” OR DE “Folk Medicine” | 5000
S7 | DE “Psychotherapy” OR DE “Adlerian Psychotherapy” OR DE “Adolescent Psychotherapy” OR DE “Analytical Psychotherapy” OR DE “Autogenic Training” OR DE “Behavior Therapy” OR DE “Brief Psychotherapy” OR DE “Child Psychotherapy” OR DE “Client Centered Therapy” OR DE “Cognitive Behavior Therapy” OR DE “Conversion Therapy” OR DE “Eclectic Psychotherapy” OR DE “Emotion Focused Therapy” OR DE “Existential Therapy” OR DE “Experiential Psychotherapy” OR DE “Expressive Psychotherapy” OR DE “Eye Movement Desensitization Therapy” OR DE “Feminist Therapy” OR DE “Geriatric Psychotherapy” OR DE “Gestalt Therapy” OR DE “Group Psychotherapy” OR DE “Guided Imagery” OR DE “Humanistic Psychotherapy” OR DE “Hypnotherapy” OR DE “Individual Psychotherapy” OR DE “Insight Therapy” OR DE “Integrative Psychotherapy” OR DE “Interpersonal Psychotherapy” OR DE “Logotherapy” OR DE “Narrative Therapy” OR DE “Persuasion Therapy” OR DE “Primal Therapy” OR DE “Psychoanalysis” OR DE “Psychodrama” OR DE “Psychodynamic Psychotherapy” OR DE “Psychotherapeutic Counseling” OR DE “Rational Emotive Behavior Therapy” OR DE “Reality Therapy” OR DE “Relationship Therapy” OR DE “Solution Focused Therapy” OR DE “Supportive Psychotherapy” OR DE “Transactional Analysis” | 131427
S6 | “intervention” OR “interventions” OR “treatment” OR “treatments” OR “therapy” OR “therapies” OR “therapeutic” OR “training” OR “psychoeducation” OR “program” OR “programs” | 1119024
S5 | “child abuse” OR “child maltreatment” OR “neglect” OR “domestic violence” OR “child welfare” OR “foster care” OR “kinship care” OR “out of home care” OR “out of home placement” OR “looked after child” OR “looked after young” OR child protective service* OR physical abuse* | 65763
S4 | DE “Foster Care” | 3234
S3 | DE “Domestic Violence” | 7813
S2 | DE “Child Welfare” | 4750
S1 | DE “Child Abuse” OR DE “Battered Child Syndrome” | 20171

Update Search (May 4, 2012) N = 149