# References

1 Campbell MF, Wein AJ, Kavoussi LR. Campbell-Walsh Urology. 9th ed. Philadelphia. W.B. Saunders. 2007.
2 Miller DC, Saigal CS, Litwin MS. The demographic burden of urologic diseases in America. Urol Clin North Am. Feb. 2009;36(1):11-27. v. [pmid: 19038632].
3 Barthold JS, Gonzalez R. The epidemiology of congenital cryptorchidism, testicular ascent and orchiopexy. J Urol. Dec. 2003;170(6 Pt 1):2396-401. [pmid: 14634436].
4 Docimo SG, Silver RI, Cromie W. The undescended testicle: diagnosis and management. Am Fam Physician. Nov. 1. 2000;62(9):2037-44. 47. 8. [pmid: 11087186].
5 Berkowitz GS, Lapinski RH, Dolgin SE, et al. Prevalence and natural history of cryptorchidism. Pediatrics. Jul. 1993;92(1):44-9. [pmid: 8100060].
6 Ritzen EM, Kollin C. Management of undescended testes: how and when?. Pediatr Endocrinol Rev. Sep. 2009;7(1):32-7. [pmid: 19696714].
7 Pohl HG, Joyce GF, Wise M, et al. Cryptorchidism and hypospadias. J Urol. May. 2007;177(5):1646-51. [pmid: 17437777].
8 Hsieh MH, Roth DR, Meng MV. Economic analysis of infant vs postpubertal orchiopexy to prevent testicular cancer. Urology. Apr. 2009;73(4):776-81. [pmid: 19193413].
9 Abratt RP, Reddi VB, Sarembock LA. Testicular cancer and cryptorchidism. Br J Urol. Dec. 1992;70(6):656-9. [pmid: 1362513].
10 Walsh TJ, Dall’Era MA, Croughan MS, et al. Prepubertal orchiopexy for cryptorchidism may be associated with lower risk of testicular cancer. J Urol. Oct. 2007;178(4 Pt 1):1440-6. discussion 6. [pmid: 17706709].
11 Wood HM, Elder JS. Cryptorchidism and testicular cancer: separating fact from fiction. J Urol. Feb. 2009;181(2):452-61. [pmid: 19084853].
12 Higgins JPT, Altman DG, Sterne JAC. Chapter 8: Assessing risk of bias in included studies. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0 (updated March 2011). The Cochrane Collaboration. 2011.
13 Wells GA, Shea B, O’Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. Available at: http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed January 24th, 2012.
14 Whiting PF, Rutjes AW, Westwood ME, et al. QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. Oct. 18. 2011;155(8):529-36. [pmid: 22007046].
15 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville. AHRQ Publication. 2011. www.effectivehealthcare.ahrq.gov/methodsguide.cfm.
16 Rajfer J, Handelsman DJ, Swerdloff RS, et al. Hormonal therapy of cryptorchidism. A randomized, double-blind study comparing human chorionic gonadotropin and gonadotropin-releasing hormone. N Engl J Med. Feb. 20. 1986;314(8):466-70. [pmid: 2868413].
17 Ferro F, Spagnoli A, Zaccara A, et al. Is preoperative laparoscopy useful for impalpable testis?. J Urol. Sep. 1999;162(3 Pt 2):995-6. discussion 7. [pmid: 10458419].
18 Christiansen P, Muller J, Buhl S, et al. Treatment of cryptorchidism with human chorionic gonadotropin or gonadotropin releasing hormone. A double-blind controlled study of 243 boys. Horm Res. 1988;30(4–5):187-92. [pmid: 2907896].
19 Olsen LH, Genster HG, Mosegaard A, et al. Management of the non-descended testis: doubtful value of luteinizing-hormone-releasing-hormone (LHRH). A double-blind, placebo-controlled multicentre study. Int J Androl. Apr. 1992;15(2):135-43. [pmid: 1349301].
20 Bertelloni S, Baroncelli GI, Ghirri P, et al. Hormonal treatment for unilateral inguinal testis: comparison of four different treatments. Horm Res. 2001;55(5):236-9. [pmid: 11740145].
21 Bica DT, Hadziselimovic F. Buserelin treatment of cryptorchidism: a randomized, double-blind, placebo-controlled study. J Urol. Aug. 1992;148(2 Pt 2):617-21. [pmid: 1353540].
22 Bica DT, Hadziselimovic F. The behavior of epididymis, processus vaginalis and testicular descent in cryptorchid boys treated with buserelin. Eur J Pediatr. Suppl 2. 1993;152:S38-42. [pmid: 8101813].
23 De Muinck Keizer-Schrama SM, Hazebroek FW, Drop SL, et al. LH-RH nasal spray treatment for cryptorchidism. A double-blind, placebo-controlled study. Eur J Pediatr. Suppl 2. 1987;146:S35-7. [pmid: 2891518].
24 De Muinck Keizer-Schrama SM, Hazebroek FW, Matroos AW, et al. Double-blind, placebo-controlled study of luteinising-hormone-releasing-hormone nasal spray in treatment of undescended testes. Lancet. Apr. 19. 1986;1(8486):876-80. [pmid: 2870353].
25 Hazebroek FW, de Muinck Keizer-Schrama SM, van Maarschalkerweerd M, et al. Why luteinizing-hormone-releasing-hormone nasal spray will not replace orchiopexy in the treatment of boys with undescended testes. J Pediatr Surg. Dec. 1987;22(12):1177-82. [pmid: 3326926].
26 Forest MG, David M, David L, et al. Undescended testis: comparison of two protocols of treatment with human chorionic gonadotropin. Effect on testicular descent and hormonal response. Horm Res. 1988;30(4–5):198-205. discussion -6. [pmid: 2907898].
27 Hagberg S, Westphal O. Treatment of undescended testes with intranasal application of synthetic LH-RH. Eur J Pediatr. Dec. 1982;139(4):285-8. [pmid: 6133757].
28 Hesse V, Fischer G. Three injections of human chorionic gonadotropin are as effective as ten injections in the treatment of cryptorchidism. Horm Res. 1988;30(4–5):193-7. [pmid: 2907897].
29 Karpe B, Eneroth P, Ritzen EM. LHRH treatment in unilateral cryptorchidism: effect on testicular descent and hormonal response. J Pediatr. Dec. 1983;103(6):892-7. [pmid: 6139422].
30 Wit JM, Delemarre-Van de Waal HA, Bax NM, et al. Effect of LHRH treatment on testicular descent and hormonal response in cryptorchidism. Clin Endocrinol (Oxf). May. 1986;24(5):539-48. [pmid: 2878745].
31 Abolyosr A. Laparoscopic versus open orchiopexy in the management of abdominal testis: a descriptive study. Int J Urol. Nov. 2006;13(11):1421-4. [pmid: 17083396].
32 Arda IS, Ersoy E. The place of the technique of narrowing neck of the dartos pouch on the ascent of testis after surgery. Scand J Urol Nephrol. Dec. 2001;35(6):505-8. [pmid: 11848432].
33 Na SW, Kim SO, Hwang EC, et al. Single Scrotal Incision Orchiopexy for children with palpable low-lying undescended testis: Early outcome of a prospective randomized controlled study. Korean J Urol. Sep. 2011;52(9):637-41. [pmid: 22025961].
34 Nazem M, Hosseinpour M, Shahbandari M. Evaluation of orchidopexy with or without opening the external oblique fascia in children with superficial inguinal undescended testis. Eur J Pediatr Surg. 2011;21(4):255-7. [pmid: 21590656].
35 Aycan Z, Ustunsalih-Inan Y, Cetinkaya E, et al. Evaluation of low-dose hCG treatment for cryptorchidism. Turk J Pediatr. Jul-Sep. 2006;48(3):228-31. [pmid: 17172066].
36 Escarcega-Fujigaki P, Rezk GHP, Huerta-Murrieta E, et al. Orchiopexy-laparoscopy or traditional surgical technique in patients with an undescended palpable testicle. Journal of Laparoendoscopic and Advanced Surgical Techniques. 01. Mar. 2011;21(2):185-7. [pmid: 21401409].
37 Merksz M, Toth J, Pirot L. Testosterone secretion in children with undescended testis. Int Urol Nephrol. 1992;24(4):429-37. [pmid: 1360946].
38 Esposito C, De Lucia A, Palmieri A, et al. Comparison of five different hormonal treatment protocols for children with cryptorchidism. Scand J Urol Nephrol. 2003;37(3):246-9. [pmid: 12775284].
39 Davenport M, Brain C, Vandenberg C, et al. The use of the hCG stimulation test in the endocrine evaluation of cryptorchidism. Br J Urol. Dec. 1995;76(6):790-4. [pmid: 8535728].
40 Stec AA, Tanaka ST, Adams MC, et al. Orchiopexy for intra-abdominal testes: factors predicting success. J Urol. Oct. 2009;182(4 Suppl):1917-20. [pmid: 19695613].
41 Al-Mandil M, Khoury AE, El-Hout Y, et al. Potential complications with the prescrotal approach for the palpable undescended testis? A comparison of single prescrotal incision to the traditional inguinal approach. J Urol. Aug. 2008;180(2):686-9. [pmid: 18554646].
42 Anoussakis C, Liakakos D, Kiburis J, et al. Effect of surgical repair of cryptorchidism on endocrine testicular function. J Pediatr. Dec. 1983;103(6):919-21. [pmid: 6139423].
43 Hadziselimovic F. Successful treatment of unilateral cryptorchid boys risking infertility with LH-RH analogue. Int Braz J Urol. May–Jun. 2008;34(3):319-26. discussion 27–8. [pmid: 18601762].
44 Hadziselimovic F, Herzog B. Treatment with a luteinizing hormone-releasing hormone analogue after successful orchiopexy markedly improves the chance of fertility later in life. J Urol. Sep. 1997;158(3 Pt 2):1193-5. [pmid: 9258170].
45 Gheiler EL, Barthold JS, Gonzalez R. Benefits of laparoscopy and the Jones technique for the nonpalpable testis. J Urol. Nov. 1997;158(5):1948-51. [pmid: 9334646].
46 Gilhooly PE, Meyers F, Lattimer JK. Fertility prospects for children with cryptorchidism. Am J Dis Child. Oct. 1984;138(10):940-3. [pmid: 6148009].
47 Humphrey GM, Najmaldin AS, Thomas DF. Laparoscopy in the management of the impalpable undescended testis. Br J Surg. Jul. 1998;85(7):983-5. [pmid: 9692579].
48 Kim J, Min GE, Kim KS. Laparoscopic orchiopexy for a nonpalpable testis. Korean J Urol. February. 2010;51(2):106-10. [pmid: 20414422].
49 Lintula H, Kokki H, Eskelinen M, et al. Laparoscopic versus open orchidopexy in children with intra-abdominal testes. J Laparoendosc Adv Surg Tech A. Jun. 2008;18(3):449-56. [pmid: 18503383].
50 Moursy EE, Gamal W, Hussein MM. Laparoscopic orchiopexy for non-palpable testes: Outcome of two techniques. J Pediatr Urol. April. 2011;7(2):178-81. [pmid: 20541475].
51 Okuyama A, Nonomura N, Nakamura M, et al. Surgical management of undescended testis: retrospective study of potential fertility in 274 cases. J Urol. Sep. 1989;142(3):749-51. [pmid: 2570166].
52 Radmayr C, Oswald J, Schwentner C, et al. Long-term outcome of laparoscopically managed nonpalpable testes. J Urol. Dec. 2003;170(6 Pt 1):2409-11. [pmid: 14634439].
53 Yavetz H, Harash B, Paz G, et al. Cryptorchidism: incidence and sperm quality in infertile men. Andrologia. Sep–Oct. 1992;24(5):293-7. [pmid: 1356318].
54 Baker LA, Docimo SG, Surer I, et al. A multi-institutional analysis of laparoscopic orchidopexy. BJU Int. Apr. 2001;87(6):484-9. [pmid: 11298039].
55 Chandrasekharam VV. Laparoscopy vs inguinal exploration for nonpalpable undescended testis. Indian J Pediatr. Dec. 2005;72(12):1021-3. [pmid: 16388149].
56 Chang B, Palmer LS, Franco I. Laparoscopic orchidopexy: a review of a large clinical series. BJU Int. Apr. 2001;87(6):490-3. [pmid: 11298040].
57 Chang M, Franco I. Laparoscopic Fowler-Stephens orchiopexy: the Westchester Medical Center experience. J Endourol. Jun. 2008;22(6):1315-9. [pmid: 18484895].
58 Cloutier J, Moore K, Nadeau G, et al. Modified scrotal (Bianchi) mid raphe single incision orchiopexy for low palpable undescended testis: early outcomes. J Urol. Mar. 2011;185(3):1088-92. [pmid: 21255806].
59 Comploj E, Mian M, Koen M, et al. Single-vs. Two-stage fowler-stephens orchidopexy: Are two operations better than one? A retrospective, single-institution critical analysis. Curr Urol. April. 2011;5(1):12-7.
60 Denes FT, Saito FJ, Silva FA, et al. Laparoscopic diagnosis and treatment of nonpalpable testis. Int Braz J Urol. May–Jun. 2008;34(3):329-34. discussion 35. [pmid: 18601763].
61 Dhanani NN, Cornelius D, Gunes A, et al. Successful outpatient management of the nonpalpable intra-abdominal testis with staged Fowler-Stephens orchiopexy. J Urol. Dec. 2004;172(6 Pt 1):2399-401. [pmid: 15538278].
62 Kullendorff CM, Hederstrom E, Forsberg L. Preoperative ultrasonography of the undescended testis. Scand J Urol Nephrol. 1985;19(1):13-5. [pmid: 2862701].
63 Al-Shareef ZH, Al-Shlash S, Koneru SR, et al. Laparoscopic orchidopexy: one-stage alternative for non-palpable testes. Ann R Coll Surg Engl. Mar. 1996;78(2):115-8. [pmid: 8678443].
64 Cain MP, Garra B, Gibbons MD. Scrotal-inguinal ultrasonography: a technique for identifying the nonpalpable inguinal testis without laparoscopy. J Urol. Aug. 1996;156(2 Pt 2):791-4. [pmid: 8683785].
65 Lam WW, Tam PK, Ai VH, et al. Gadolinium-infusion magnetic resonance angiogram: a new, noninvasive, and accurate method of preoperative localization of impalpable undescended testes. J Pediatr Surg. Jan. 1998;33(1):123-6. [pmid: 9473116].
66 Desireddi NV, Liu DB, Maizels M, et al. Magnetic resonance arteriography/venography is not accurate to structure management of the impalpable testis. J Urol. Oct. 2008;180(4 Suppl):1805-8. discussion 8–9. [pmid: 18721972].
67 Green R Jr. Computerized axial tomography vs spermatic venography in localization of cryptorchid testes. Urology. Nov. 1985;26(5):513-7. [pmid: 2865842].
68 Kanemoto K, Hayashi Y, Kojima Y, et al. Accuracy of ultrasonography and magnetic resonance imaging in the diagnosis of non-palpable testis. Int J Urol. Jul. 2005;12(7):668-72. [pmid: 16045560].
69 Kato T, Kojima Y, Kamisawa H, et al. Findings of fat-suppressed T2-weighted and diffusion-weighted magnetic resonance imaging in the diagnosis of non-palpable testes. BJU Int. Jan. 2011;107(2):290-4. [pmid: 20735388].
70 Kier R, McCarthy S, Rosenfield AT, et al. Nonpalpable testes in young boys: evaluation with MR imaging. Radiology. Nov. 1988;169(2):429-33. [pmid: 2902656].
71 Lam WW, Tam PK, Ai VH, et al. Using gadolinium-infusion MR venography to show the impalpable testis in pediatric patients. AJR Am J Roentgenol. May. 2001;176(5):1221-6. [pmid: 11312185].
72 Maghnie M, Vanzulli A, Paesano P, et al. The accuracy of magnetic resonance imaging and ultrasonography compared with surgical findings in the localization of the undescended testis. Arch Pediatr Adolesc Med. Jul. 1994;148(7):699-703. [pmid: 7912611].
73 Malone PS, Guiney EJ. A comparison between ultrasonography and laparoscopy in localising the impalpable undescended testis. Br J Urol. Apr. 1985;57(2):185-6. [pmid: 2859072].
74 Miyano T, Kobayashi H, Shimomura H, et al. Magnetic resonance imaging for localizing the nonpalpable undescended testis. J Pediatr Surg. May. 1991;26(5):607-9. [pmid: 1676414].
75 Nijs SM, Eijsbouts SW, Madern GC, et al. Nonpalpable testes: is there a relationship between ultrasonographic and operative findings?. Pediatr Radiol. Apr. 2007;37(4):374-9. [pmid: 17325824].
76 Siemer S, Humke U, Uder M, et al. Diagnosis of nonpalpable testes in childhood: comparison of magnetic resonance imaging and laparoscopy in a prospective study. Eur J Pediatr Surg. Apr. 2000;10(2):114-8. [pmid: 10877080].
77 Yeung CK, Tam YH, Chan YL, et al. A new management algorithm for impalpable undescended testis with gadolinium enhanced magnetic resonance angiography. J Urol. Sep. 1999;162(3 Pt 2):998-1002. [pmid: 10458420].
78 Kantarci M, Doganay S, Yalcin A, et al. Diagnostic performance of diffusion-weighted MRI in the detection of nonpalpable undescended testes: comparison with conventional MRI and surgical findings. AJR Am J Roentgenol. Oct. 2010;195(4):W268-73. [pmid: 20858788].
79 Guvenc BH, Sozubir S, Ekingen G, et al. Advantages of video-assisted approach in detecting epididymal anomalies and treatment of nonpalpable testis. Urol Int. 2005;74(2):127-34. discussion 34. [pmid: 15756064].
80 Lamah M, McCaughey ES, Finlay FO, et al. The ascending testis: is late orchidopexy due to failure of screening or late ascent?. Pediatr Surg Int. Jul. 2001;17(5–6):421-3. [pmid: 11527181].
81 Kogan SJ. Fertility in cryptorchidism. An overview in 1987. Eur J Pediatr. Suppl 2. 1987;146:S21-4. [pmid: 2891514].
82 Leissner J, Filipas D, Wolf HK, et al. The undescended testis: considerations and impact on fertility. BJU Int. May. 1999;83(8):885-91. quiz 91–2. [pmid: 10368225].
83 Lee PA. Fertility after cryptorchidism: epidemiology and other outcome studies. Urology. Aug. 2005;66(2):427-31. [pmid: 16098371].
84 Lee PA, Bellinger MF, Coughlin MT. Correlations among hormone levels, sperm parameters and paternity in formerly unilaterally cryptorchid men. J Urol. Sep. 1998;160(3 Pt 2):1155-7. discussion 78. [pmid: 9719298].
85 Lee PA, Bellinger MF, Songer NJ, et al. An epidemiologic study of paternity after cryptorchidism: initial results. Eur J Pediatr. Suppl 2. 1993;152:S25-7. [pmid: 8101807].
86 Cooper TG, Noonan E, von Eckardstein S, et al. World Health Organization reference values for human semen characteristics. Hum Reprod Update. May–Jun. 2010;16(3):231-45. [pmid: 19934213].