# Peer Reviewers

Doug A. Husmann, M.D.

Chair, Department of Urology

Mayo Clinic

Rochester, MN

John M. Hutson, M.D.

Professor, University of Melbourne

Chairman, Pediatric Surgery

Melbourne, Australia

Chester Koh, M.D.

Pediatric Urology Director, Robotic Surgery Program

Children’s Hospital of Los Angeles

Saban Research Institute

Los Angeles, CA

Paul J. Kokorowski, M.D., M.P.H.

Fellow, Pediatric Urology

Children’s Hospital Boston, Harvard Medical School

Boston, MA

Thomas F. Kolon, M.D.

Associate Professor, Urology

University of Pennsylvania School of Medicine

Children’s Hospital of Philadelphia

Philadelphia, PA

Caleb Nelson, M.D., M.P.H.

Assistant Professor, Surgery and Pediatrics

Co-Director, Kidney Stone Center

Harvard University

Boston, MA