# Technical Expert Panel

Laurence S. Baskin, M.D.

Professor, Department of Urology and Pediatrics

Department Chief, Pediatric Urology

University of California San Francisco Children’s Medical Center

San Francisco, CA

Victoria K. Cortessis, Ph.D.

Assistant Professor of Research, Department of Preventive Medicine

Keck School of Medicine

University of Southern California

Los Angeles, CA

Jose L. Gonzalez, M.D., J.D., M.S.Ed., C.P.E.

State of Texas, Medicaid Medical Director

Galveston, TX

Paul J. Kokorowski, M.D., M.P.H.

Fellow, Pediatric Urology

Children’s Hospital Boston, Harvard Medical School

Boston, MA

Thomas F. Kolon, M.D.

Associate Professor, Urology

University of Pennsylvania School of Medicine

Children’s Hospital of Philadelphia

Philadelphia, PA