# Key Informants

Laurence S. Baskin, M.D.

Professor, Department of Urology and Pediatrics

Department Chief, Pediatric Urology

University of California San Francisco Children’s Medical Center

San Francisco, CA

Victoria K. Cortessis, Ph.D.

Assistant Professor of Research, Department of Preventive Medicine

Keck School of Medicine

University of Southern California

Los Angeles, CA

Steven G. Docimo, M.D.

Vice Chairman and Professor of Urology

Program Director, Pediatric Urology Fellowship, Children’s Hospital of Pittsburgh

University of Pittsburgh School of Medicine

Pittsburgh, PA

Paul J. Kokorowski, M.D., M.P.H.

Fellow, Pediatric Urology

Children’s Hospital Boston, Harvard Medical School

Boston, MA

Thomas F. Kolon, M.D.

Associate Professor, Urology

University of Pennsylvania School of Medicine

Children’s Hospital of Philadelphia

Philadelphia, PA

Jacob Rajfer, M.D.

Professor, Division of Urology, Department of Surgery

University of California at Los Angeles

Los Angeles, CA