# Quality of the Literature

The Quality Assessment of Diagnostic Accuracy Studies-Revised1 (QUADAS-2) tool was used to assess the quality of studies included in Key Question 1a. We constructed an evaluation form using the criteria outlined in the QUADAS-2 and completed one form for each technique assessed by studies included in our review. Each individual item could receive an assessment of yes, no, or unclear. Some included studies analyzed more than one imaging technique; in these instances, a separate evaluation form was completed for each technique.

Two authors independently completed evaluation forms for each study. Discrepancies were discussed and adjudicated by the two authors and the methods lead. The results of the evaluations of each study are presented below (Tables E-1–E-3), separated by imaging technique.

QUADAS-2 Evaluation Form

## QUADAS-2 Assessments

Table E-1 QUADAS-2 assessments of ultrasound accuracy studies

Study | Patient Selection | | | Index Test | | Reference Standard | | Flow and Timing
Study | Consecutive or random sample | Non-case-control | Avoid exclusions | Knowledge of standard | Pre-specified threshold | Likely to correctly classify the target condition | Knowledge of index test | Appropriate interval between tests | All receive standard | Same reference standard | All patients analyzed
Al-Shareef et al., 1996^2^ | Y | Y | Y | Y | Y | Y | N | U | Y | Y | Y
Cain et al., 1996^3^ | Y | Y | Y | Y | Y | Y | N | U | Y | Y | Y
Guvenc et al., 2005^4^ | N | Y | Y | Y | Y | Y | N | N | Y | N | Y
Kanemoto et al., 2005^5^ | N | Y | Y | Y | Y | Y | N | U | Y | Y | Y
Kullendorf et al., 1985^6^ | Y | Y | Y | Y | Y | Y | U | Y | Y | Y | Y
Maghnie et al., 1994^7^ | N | Y | Y | Y | Y | Y | Y | U | Y | Y | N
Malone et al., 1985^8^ | N | Y | Y | Y | Y | Y | N | U | Y | Y | Y
Nijs et al., 2007^9^ | N | Y | Y | Y | Y | Y | N | U | Y | Y | N
Yeung et al., 1999^10^ | N | Y | Y | Y | Y | Y | N | U | Y | Y | Y

Y= yes; N = no; U = unclear

Table E-2 QUADAS-2 assessments of MRI accuracy studies

Study | Patient Selection | | | Index Test | | Reference Standard | | Flow and Timing
Study | Consecutive or random sample | Non-case-control | Avoid exclusions | Knowledge of standard | Pre-specified threshold | Likely to correctly classify the target condition | Knowledge of index test | Appropriate interval between tests | All receive standard | Same reference standard | All patients analyzed
Al-Shareef et al., 1996^2^ | Y | Y | Y | Y | Y | Y | N | U | Y | Y | Y
Kanemoto et al., 2005^5^ | N | Y | Y | Y | Y | Y | N | U | Y | Y | N
Kantarci et al., 2010^11^ | N | Y | Y | Y | Y | Y | Y | Y | Y | Y | Y
Kato et al., 2011^12^ | N | Y | Y | Y | Y | Y | N | U | Y | Y | Y
Kier et al., 1988^13^ | N | Y | Y | N | Y | Y | N | U | Y | Y | Y
Lam et al., 1998^14^ | Y | Y | Y | Y | Y | Y | N | U | Y | Y | Y
Maghnie et al., 1994^7^ | N | Y | Y | Y | Y | Y | N | U | Y | Y | Y
Miyano et al., 1991^15^ | N | Y | Y | Y | Y | Y | N | U | Y | Y | Y
Siemer et al., 2000^16^ | N | Y | Y | Y | Y | Y | N | U | Y | Y | Y
Yeung et al., 1999^10^ | N | Y | Y | Y | Y | Y | N | U | Y | Y | Y

Y= yes; N = no; U = unclear

Table E-3 QUADAS-2 assessments of other accuracy technique studies

Study Technique | Patient Selection | | | Index Test | | Reference Standard | | Flow and Timing
Study Technique | Consecutive or random sample | Non-case-control | Avoid exclusions | Knowledge of standard | Pre-specified threshold | Likely to correctly classify the target condition | Knowledge of index test | Appropriate interval between tests | All receive standard | Same reference standard | All patients analyzed
Desireddi et al., 2008^17^ MRI + MRA/V | N | Y | Y | Y | Y | Y | Y | U | Y | N | N
Green, 1985^18^ CT Scan | N | Y | Y | Y | Y | Y | N | U | Y | Y | Y
Lam et al., 2001^19^ MRV | N | Y | Y | Y | Y | Y | N | U | Y | Y | Y
Lam et al., 1998^14^ MRA | Y | Y | Y | Y | Y | Y | N | U | Y | Y | Y
Yeung et al., 1999^10^ MRA | N | Y | Y | Y | Y | Y | N | U | Y | Y | Y

Y= yes; N = no; U = unclear ; CT=computed tomography; MRA=magnetic resonance angiography; MRA/V= Magnetic Resonance Imaging in combination with arteriography/venography ; MRI=magnetic resonance imaging

## Risk of Bias and Quality

Per the methods of the QUADAS-2, a risk of bias (ROB) score was calculated for each of the four domains assessed in the evaluation of each study: patient selection, index test (imaging technique), reference standard (surgical verification technique), and flow and timing. Each domain could receive a rating of high, low, or unclear ROB.

For the patient selection, index test, and flow and timing domains, a “Yes” response to all individual items was necessary to receive a low ROB assessment. One answer of “No” or “Unclear” for any individual item within these three domains resulted in an assessment of high ROB.

The QUADAS-2 ROB assessments were then converted into the AHRQ quality standards of good, fair, and poor using the following criteria:

- Good quality = an assessment of low ROB for all four domains
- Fair quality = an assessment of high ROB for one domain
- Poor quality = an assessment of high ROB for two or more domains

The quality and ROB assessments for each study are presented below (Tables E-4–E-6), separated by imaging technique.

Table E-4 ROB and quality scores of ultrasound accuracy studies

Study | Quality Score | Patient Selection | Imaging | Surgery | Flow and Timing
Al-Shareef et al., 1996^2^ | Fair | L | L | L | H
Cain et al., 1996^3^ | Fair | L | L | L | H
Guvenc et al., 2005^4^ | Poor | H | L | L | H
Kanemoto et al., 2005^5^ | Poor | H | L | L | H
Kullendorf et al., 1985^6^ | Good | L | L | L | L
Maghnie et al., 1994^7^ | Poor | H | L | L | H
Malone et al., 1985^8^ | Poor | H | L | L | H
Nijs et al., 2007^9^ | Poor | H | L | L | H
Yeung et al., 1999^10^ | Poor | H | L | L | H

H = high; L = low; ROB=risk of bias

Table E-5 ROB and quality scores of MRI accuracy studies

Study | Quality Score | Patient Selection | Imaging | Surgery | Flow and Timing
Al-Shareef et al., 1996^2^ | Fair | L | L | L | H
Kanemoto et al., 2005^5^ | Poor | H | L | L | H
Kantarci et al., 2010^11^ | Fair | H | L | L | L
Kato et al., 2011^12^ | Poor | H | L | L | H
Kier et al., 1988^13^ | Poor | H | H | L | H
Lam et al., 1998^14^ | Fair | L | L | L | H
Maghnie et al., 1994^7^ | Poor | H | L | L | H
Miyano et al., 1991^15^ | Poor | H | L | L | H
Siemer et al., 2000^16^ | Poor | H | L | L | H
Yeung et al., 1999^10^ | Poor | H | L | L | H

H = high; L = low; MRI=magnetic resonance imaging; ROB=risk of bias

Table E-6 ROB and quality scores of other accuracy technique studies

Study Technique | Quality Score | Patient Selection | Imaging | Surgery | Flow and Timing
Desireddi et al., 2008^17^ MRI + MRA/V | Poor | H | L | L | H
Green, 1985^18^ CT Scan | Poor | H | L | L | H
Lam et al., 2001^19^ MRV | Poor | H | L | L | H
Lam et al., 1998^14^ MRA | Fair | L | L | L | H
Yeung et al., 1999^10^ MRA | Poor | H | L | L | H

H = high; L = low; CT=computed tomography;MRA=magnetic resonance angiography; MRA/V= Magnetic Resonance Imaging in combination with arteriography/venography; MRI=magnetic resonance imaging; ROB=risk of bias

Cochrane Risk of Bias Tool for Randomized Controlled Trials

Table E-7 Quality ratings for randomized control trials included in Key Question 2

Study | Quality rating | Random sequence generation | Allocation concealment | Selective reporting | Other sources of bias | Blinding (participants and personnel) | Blinding (outcome assessment) | Incomplete outcome data
Key Question 2: Effectiveness of hormone therapy for the treatment of cryptorchidism
Bertelloni et al., 2001^20^ | Poor | H | U | L | U | H | H | L
Bica and Hadziselimovic, 1992 & 1993^21, 22^ | Poor | U | U | L | U | L | H | L
Christiansen et al., 1988^23^ | Fair | L | L | L | H | L | L | L
De Muinck Keizer-Schrama and Hazebroek et al., 1986–1987^24–26^ | Poor | U | U | L | U | L | L | L
Forest et al., 1988^27^ | Poor | H | H | L | H | H | H | L
Hagberg and Westphal, 1982^28^ | Poor | U | U | L | U | L | L | L
Hesse and Fischer, 1988^29^ | Poor | H | H | L | U | L | L | L
Karpe et al., 1983^30^ | Poor | U | U | L | L | L | L | L
Olsen et al., 1992^31^ | Fair | L | L | L | L | L | L | H
Rajfer et al., 1986^32^ | Good | L | L | L | L | L | L | L
Wit et al., 1986^33^ | Poor | U | U | L | L | L | L | L

H=high; L=low; U=unclear

Table E-8 Quality ratings for randomized control trials included in Key Question 3

Key Question 3: Effectiveness of surgical therapies for the treatment of cryptorchidism
Study | Quality rating | Random sequence generation | Allocation concealment | Selective reporting | Other sources of bias | Blinding (participants and personnel) | Blinding (outcome assessment) | Incomplete outcome data
Abolyosr, 2006^34^ | Poor | H | H | H | L | H | H | U
Arda and Ersoy, 2001^35^ | Poor | H | H | U | L | L | H | L
Ferro et al., 1999^36^ | Good | L | L | L | L | L | L | L
Na et al., 2011^37^ | Poor | U | U | L | L | L | L | H
Nazem et al., 2011^38^ | Poor | H | U | H | L | L | L | L

H = high; L = low; U = unclear

Newcastle-Ottawa Quality Assessment Form for Cohort Studies

Table E-9 Quality ratings for cohort studies included in Key Question 1b

| | Selection (0–4 stars) | | | | Comparability (n/a, 0–2 stars) | Outcome (0–3 stars)
Citation | Quality rating | Representativeness of exposed cohort | Selection of non exposed | Ascertainment of exposure | Outcome not present at start of study | Comparability of cohorts | Assessment | Long enough followup | Adequacy of follow up
Davenport et al., 1995^39^ | Poor | b)somewhat representative | a)drawn from same community | a)secure record | a) yes | c) no | b)record linkage | a) yes | a)complete followup
Merksz et al., 1992^40^ | Fair | b)somewhat representative | a)drawn from same community | a)secure record | b) no | b) other | b)record linkage | a) yes | a)complete followup

Table E-10 Quality ratings for cohort studies included in Key Question 2

| | Selection (0–4 stars) | | | | Comparability (n/a, 0–2 stars) | Outcome (0–3 stars)
Citation | Quality rating | Representativeness of exposed cohort | Selection of non exposed | Ascertainment of exposure | Outcome not present at start of study | Comparability of cohorts | Assessment | Long enough followup | Adequacy of follow up
Aycan et al., 2006^41^ | Good | b)somewhat representative | a)drawn from same community | a)secure record | a) yes | a) yes | a)independent blind assessment | a) yes | a)complete followup
Esposito et al., 2003^42^ | Poor | d) no description | a)drawn from same community | d)no description | a) yes | c) no | a)independent blind assessment | a) yes | a)complete followup
Hadziselimovic and Herzog, 1997 & 2008^43, 44^ | Good | c)selected group | a)drawn from same community | a)secure record | a) yes | a) yes | a)independent blind assessment | a) yes | a)complete followup

Table E-11 Quality ratings for cohort studies included in Key Question 3

| | Selection (0–4 stars) | | | | Comparability (n/a, 0–2 stars) | Outcome (0–3 stars)
Citation | Quality rating | Representativeness of exposed cohort | Selection of non exposed | Ascertainment of exposure | Outcome not present at start of study | Comparability of cohorts | Assessment | Long enough followup | Adequacy of follow up
Al-Mandil et al., 2008^45^ | Good | b)somewhat representative | a)drawn from same community | a)secure record | a) yes | a) yes | a)independent blind assessment | a) yes | d)no statement
Anousskasis et al., 1983^46^ | Good | b)somewhat representative | a)drawn from same community | a)secure record | a) yes | a) yes | a)independent blind assessment | a) yes | d)no statement
Baker et al.,2001^47^ | Poor | b)somewhat representative | a)drawn from same community | a)secure record | a) yes | c) no | a)independent blind assessment | a) yes | c)>80%
Chandrasekharam, 2005^48^ | Poor | b)somewhat representative | a)drawn from same community | d)no description | a) yes | a) yes | d) no description | b) no | d)no statement
Chang et al., 2001^49^ | Poor | c)selected group | a)drawn from same community | a)secure record | a) yes | c) no | a)independent blind assessment | b) no | c)>80%
Chang et al., 2008^50^ | Poor | c)selected group | a)drawn from same community | a)secure record | a) yes | c) no | a)independent blind assessment | a) yes | c)>80%
Cloutier et al., 2011^51^ | Poor | b)somewhat representative | a)drawn from same community | a)secure record | a) yes | b) other | a)independent blind assessment | b) no | d)no statement
Comploj et al., 2011^52^ | Poor | b)somewhat representative | a)drawn from same community | a)secure record | a) yes | c) no | a)independent blind assessment | a) yes | c)>80%
Denes et al., 2008^53^ | Poor | d) no description | a)drawn from same community | d)no description | a) yes | c) no | d)no description | b) no | c)>80%
Dhanani et al., 2004^54^ | Poor | d)no description | a)drawn from same community | a)secure record | a) yes | c) no | a)independent blind assessment | a) yes | c)>80%
Escarcega-Fujigaki et al., 2011^55^ | Fair | b)somewhat representative | a)drawn from same community | d)no description | b) no | b) other | c) self report | a) yes | c)>80%
Gheiler et al., 1997^56^ | Poor | b)somewhat representative | a)drawn from same community | a)secure record | a) yes | c) no | a)independent blind assessment | b) no | d)no statement
Gilhooly et al., 1984^57^ | Poor | d)no description | b)drawn from different source | d)no description | b) no | c) no | c)self report | b) no | d)no statement
Humphrey et al., 1998^58^ | Poor | d)no description | a)drawn from same community | d)no description | a) yes | c) no | d) no description | a) yes | d)no statement
Kim et al., 2010^59^ | Poor | d)no description | a)drawn from same community | a)secure record | a) yes | c) no | a)independent blind assessment | b) no | c)>80%
Lintula et al., 2008^60^ | Poor | a)truly representative | a)drawn from same community | a)secure record | a) yes | c) no | a)independent blind assessment | a) yes | b) <20%
Moursy et al., 2011^61^ | Poor | d)no description | a)drawn from same community | d)no description | a) yes | c) no | d) no description | a) yes | c)>80%
Okuyama et al., 1989^62^ | Poor | d)no description | b)drawn from different source | d)no description | b) no | c) no | a)independent blind assessment | a) yes | d)no statement
Radmayr et al., 2003^63^ | Poor | d)no description | a)drawn from same community | d)no description | a) yes | c) no | d) no description | a) yes | d)no statement
Stec et al., 2009^64^ | Good | b)somewhat representative | a)drawn from same community | a)secure record | a) yes | a & b | a)independent blind assessment | a) yes | c)>80%
Yavetz et al., 1992^65^ | Poor | d)no description | b)drawn from different source | d)no description | b) no | c) no | a)independent blind assessment | a) yes | d)no statement

## References for Appendix E

1 Whiting PF, Rutjes AW, Westwood ME, et al. QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. Oct. 18. 2011;155(8):529-36. [pmid: 22007046].
2 Al-Shareef ZH, Al-Shlash S, Koneru SR, et al. Laparoscopic orchidopexy: one-stage alternative for non-palpable testes. Ann R Coll Surg Engl. Mar. 1996;78(2):115-8. [pmid: 8678443].
3 Cain MP, Garra B, Gibbons MD. Scrotal-inguinal ultrasonography: a technique for identifying the nonpalpable inguinal testis without laparoscopy. J Urol. Aug. 1996;156(2 Pt 2):791-4. [pmid: 8683785].
4 Guvenc BH, Sozubir S, Ekingen G, et al. Advantages of video-assisted approach in detecting epididymal anomalies and treatment of nonpalpable testis. Urol Int. 2005;74(2):127-34. discussion 34. [pmid: 15756064].
5 Kanemoto K, Hayashi Y, Kojima Y, et al. Accuracy of ultrasonography and magnetic resonance imaging in the diagnosis of non-palpable testis. Int J Urol. Jul. 2005;12(7):668-72. [pmid: 16045560].
6 Kullendorff CM, Hederstrom E, Forsberg L. Preoperative ultrasonography of the undescended testis. Scand J Urol Nephrol. 1985;19(1):13-5. [pmid: 2862701].
7 Maghnie M, Vanzulli A, Paesano P, et al. The accuracy of magnetic resonance imaging and ultrasonography compared with surgical findings in the localization of the undescended testis. Arch Pediatr Adolesc Med. Jul. 1994;148(7):699-703. [pmid: 7912611].
8 Malone PS, Guiney EJ. A comparison between ultrasonography and laparoscopy in localising the impalpable undescended testis. Br J Urol. Apr. 1985;57(2):185-6. [pmid: 2859072].
9 Nijs SM, Eijsbouts SW, Madern GC, et al. Nonpalpable testes: is there a relationship between ultrasonographic and operative findings?. Pediatr Radiol. Apr. 2007;37(4):374-9. [pmid: 17325824].
10 Yeung CK, Tam YH, Chan YL, et al. A new management algorithm for impalpable undescended testis with gadolinium enhanced magnetic resonance angiography. J Urol. Sep. 1999;162(3 Pt 2):998-1002. [pmid: 10458420].
11 Kantarci M, Doganay S, Yalcin A, et al. Diagnostic performance of diffusion-weighted MRI in the detection of nonpalpable undescended testes: comparison with conventional MRI and surgical findings. AJR Am J Roentgenol. Oct. 2010;195(4):W268-73. [pmid: 20858788].
12 Kato T, Kojima Y, Kamisawa H, et al. Findings of fat-suppressed T2-weighted and diffusion-weighted magnetic resonance imaging in the diagnosis of non-palpable testes. BJU Int. Jan. 2011;107(2):290-4. [pmid: 20735388].
13 Kier R, McCarthy S, Rosenfield AT, et al. Nonpalpable testes in young boys: evaluation with MR imaging. Radiology. Nov. 1988;169(2):429-33. [pmid: 2902656].
14 Lam WW, Tam PK, Ai VH, et al. Gadolinium-infusion magnetic resonance angiogram: a new, noninvasive, and accurate method of preoperative localization of impalpable undescended testes. J Pediatr Surg. Jan. 1998;33(1):123-6. [pmid: 9473116].
15 Miyano T, Kobayashi H, Shimomura H, et al. Magnetic resonance imaging for localizing the nonpalpable undescended testis. J Pediatr Surg. May. 1991;26(5):607-9. [pmid: 1676414].
16 Siemer S, Humke U, Uder M, et al. Diagnosis of nonpalpable testes in childhood: comparison of magnetic resonance imaging and laparoscopy in a prospective study. Eur J Pediatr Surg. Apr. 2000;10(2):114-8. [pmid: 10877080].
17 Desireddi NV, Liu DB, Maizels M, et al. Magnetic resonance arteriography/venography is not accurate to structure management of the impalpable testis. J Urol. Oct. 2008;180(4 Suppl):1805-8. discussion 8–9. [pmid: 18721972].
18 Green R Jr. Computerized axial tomography vs spermatic venography in localization of cryptorchid testes. Urology. Nov. 1985;26(5):513-7. [pmid: 2865842].
19 Lam WW, Tam PK, Ai VH, et al. Using gadolinium-infusion MR venography to show the impalpable testis in pediatric patients. AJR Am J Roentgenol. May. 2001;176(5):1221-6. [pmid: 11312185].
20 Bertelloni S, Baroncelli GI, Ghirri P, et al. Hormonal treatment for unilateral inguinal testis: comparison of four different treatments. Horm Res. 2001;55(5):236-9. [pmid: 11740145].
21 Bica DT, Hadziselimovic F. Buserelin treatment of cryptorchidism: a randomized, double-blind, placebo-controlled study. J Urol. Aug. 1992;148(2 Pt 2):617-21. [pmid: 1353540].
22 Bica DT, Hadziselimovic F. The behavior of epididymis, processus vaginalis and testicular descent in cryptorchid boys treated with buserelin. Eur J Pediatr. Suppl 2. 1993;152:S38-42. [pmid: 8101813].
23 Christiansen P, Muller J, Buhl S, et al. Treatment of cryptorchidism with human chorionic gonadotropin or gonadotropin releasing hormone. A double-blind controlled study of 243 boys. Horm Res. 1988;30(4–5):187-92. [pmid: 2907896].
24 De Muinck Keizer-Schrama SM, Hazebroek FW, Drop SL, et al. LH-RH nasal spray treatment for cryptorchidism. A double-blind, placebo-controlled study. Eur J Pediatr. Suppl 2. 1987;146:S35-7. [pmid: 2891518].
25 De Muinck Keizer-Schrama SM, Hazebroek FW, Matroos AW, et al. Double-blind, placebo-controlled study of luteinising-hormone-releasing-hormone nasal spray in treatment of undescended testes. Lancet. Apr. 19. 1986;1(8486):876-80. [pmid: 2870353].
26 Hazebroek FW, de Muinck Keizer-Schrama SM, van Maarschalkerweerd M, et al. Why luteinizing-hormone-releasing-hormone nasal spray will not replace orchiopexy in the treatment of boys with undescended testes. J Pediatr Surg. Dec. 1987;22(12):1177-82. [pmid: 3326926].
27 Forest MG, David M, David L, et al. Undescended testis: comparison of two protocols of treatment with human chorionic gonadotropin. Effect on testicular descent and hormonal response. Horm Res. 1988;30(4–5):198-205. discussion -6. [pmid: 2907898].
28 Hagberg S, Westphal O. Treatment of undescended testes with intranasal application of synthetic LH-RH. Eur J Pediatr. Dec. 1982;139(4):285-8. [pmid: 6133757].
29 Hesse V, Fischer G. Three injections of human chorionic gonadotropin are as effective as ten injections in the treatment of cryptorchidism. Horm Res. 1988;30(4–5):193-7. [pmid: 2907897].
30 Karpe B, Eneroth P, Ritzen EM. LHRH treatment in unilateral cryptorchidism: effect on testicular descent and hormonal response. J Pediatr. Dec. 1983;103(6):892-7. [pmid: 6139422].
31 Olsen LH, Genster HG, Mosegaard A, et al. Management of the non-descended testis: doubtful value of luteinizing-hormone-releasing-hormone (LHRH). A double-blind, placebo-controlled multicentre study. Int J Androl. Apr. 1992;15(2):135-43. [pmid: 1349301].
32 Rajfer J, Handelsman DJ, Swerdloff RS, et al. Hormonal therapy of cryptorchidism. A randomized, double-blind study comparing human chorionic gonadotropin and gonadotropin-releasing hormone. N Engl J Med. Feb. 20. 1986;314(8):466-70. [pmid: 2868413].
33 Wit JM, Delemarre-Van de Waal HA, Bax NM, et al. Effect of LHRH treatment on testicular descent and hormonal response in cryptorchidism. Clin Endocrinol (Oxf). May. 1986;24(5):539-48. [pmid: 2878745].
34 Abolyosr A. Laparoscopic versus open orchiopexy in the management of abdominal testis: a descriptive study. Int J Urol. Nov. 2006;13(11):1421-4. [pmid: 17083396].
35 Arda IS, Ersoy E. The place of the technique of narrowing neck of the dartos pouch on the ascent of testis after surgery. Scand J Urol Nephrol. Dec. 2001;35(6):505-8. [pmid: 11848432].
36 Ferro F, Spagnoli A, Zaccara A, et al. Is preoperative laparoscopy useful for impalpable testis?. J Urol. Sep. 1999;162(3 Pt 2):995-6. discussion 7. [pmid: 10458419].
37 Na SW, Kim SO, Hwang EC, et al. Single Scrotal Incision Orchiopexy for children with palpable low-lying undescended testis: Early outcome of a prospective randomized controlled study. Korean J Urol. Sep. 2011;52(9):637-41. [pmid: 22025961].
38 Nazem M, Hosseinpour M, Shahbandari M. Evaluation of orchidopexy with or without opening the external oblique fascia in children with superficial inguinal undescended testis. Eur J Pediatr Surg. 2011;21(4):255-7. [pmid: 21590656].
39 Davenport M, Brain C, Vandenberg C, et al. The use of the hCG stimulation test in the endocrine evaluation of cryptorchidism. Br J Urol. Dec. 1995;76(6):790-4. [pmid: 8535728].
40 Merksz M, Toth J, Pirot L. Testosterone secretion in children with undescended testis. Int Urol Nephrol. 1992;24(4):429-37. [pmid: 1360946].
41 Aycan Z, Ustunsalih-Inan Y, Cetinkaya E, et al. Evaluation of low-dose hCG treatment for cryptorchidism. Turk J Pediatr. Jul–Sep. 2006;48(3):228-31. [pmid: 17172066].
42 Esposito C, De Lucia A, Palmieri A, et al. Comparison of five different hormonal treatment protocols for children with cryptorchidism. Scand J Urol Nephrol. 2003;37(3):246-9. [pmid: 12775284].
43 Hadziselimovic F. Successful treatment of unilateral cryptorchid boys risking infertility with LH-RH analogue. Int Braz J Urol. May–Jun. 2008;34(3):319-26. discussion 27–8. [pmid: 18601762].
44 Hadziselimovic F, Herzog B. Treatment with a luteinizing hormone-releasing hormone analogue after successful orchiopexy markedly improves the chance of fertility later in life. J Urol. Sep. 1997;158(3 Pt 2):1193-5. [pmid: 9258170].
45 Al-Mandil M, Khoury AE, El-Hout Y, et al. Potential complications with the prescrotal approach for the palpable undescended testis? A comparison of single prescrotal incision to the traditional inguinal approach. J Urol. Aug. 2008;180(2):686-9. [pmid: 18554646].
46 Anoussakis C, Liakakos D, Kiburis J, et al. Effect of surgical repair of cryptorchidism on endocrine testicular function. J Pediatr. Dec. 1983;103(6):919-21. [pmid: 6139423].
47 Baker LA, Docimo SG, Surer I, et al. A multi-institutional analysis of laparoscopic orchidopexy. BJU Int. Apr. 2001;87(6):484-9. [pmid: 11298039].
48 Chandrasekharam VV. Laparoscopy vs inguinal exploration for nonpalpable undescended testis. Indian J Pediatr. Dec. 2005;72(12):1021-3. [pmid: 16388149].
49 Chang B, Palmer LS, Franco I. Laparoscopic orchidopexy: a review of a large clinical series. BJU Int. Apr. 2001;87(6):490-3. [pmid: 11298040].
50 Chang M, Franco I. Laparoscopic Fowler-Stephens orchiopexy: the Westchester Medical Center experience. J Endourol. Jun. 2008;22(6):1315-9. [pmid: 18484895].
51 Cloutier J, Moore K, Nadeau G, et al. Modified scrotal (Bianchi) mid raphe single incision orchiopexy for low palpable undescended testis: early outcomes. J Urol. Mar. 2011;185(3):1088-92. [pmid: 21255806].
52 Comploj E, Mian M, Koen M, et al. Single-vs. Two-stage fowler-stephens orchidopexy: Are two operations better than one? A retrospective, single-institution critical .analysis. Curr Urol. April. 2011;5(1):12-7.
53 Denes FT, Saito FJ, Silva FA, et al. Laparoscopic diagnosis and treatment of nonpalpable testis. Int Braz J Urol. May–Jun. 2008;34(3):329-34. discussion 35. [pmid: 18601763].
54 Dhanani NN, Cornelius D, Gunes A, et al. Successful outpatient management of the nonpalpable intra-abdominal testis with staged Fowler-Stephens orchiopexy. J Urol. Dec. 2004;172(6 Pt 1):2399-401. [pmid: 15538278].
55 Escarcega-Fujigaki P, Rezk GHP, Huerta-Murrieta E, et al. Orchiopexy-laparoscopy or traditional surgical technique in patients with an undescended palpable testicle. Journal of Laparoendoscopic and Advanced Surgical Techniques. 01. Mar. 2011;21(2):185-7. [pmid: 21401409].
56 Gheiler EL, Barthold JS, Gonzalez R. Benefits of laparoscopy and the Jones technique for the nonpalpable testis. J Urol. Nov. 1997;158(5):1948-51. [pmid: 9334646].
57 Gilhooly PE, Meyers F, Lattimer JK. Fertility prospects for children with cryptorchidism. Am J Dis Child. Oct. 1984;138(10):940-3. [pmid: 6148009].
58 Humphrey GM, Najmaldin AS, Thomas DF. Laparoscopy in the management of the impalpable undescended testis. Br J Surg. Jul. 1998;85(7):983-5. [pmid: 9692579].
59 Kim J, Min GE, Kim KS. Laparoscopic orchiopexy for a nonpalpable testis. Korean J Urol. February. 2010;51(2):106-10. [pmid: 20414422].
60 Lintula H, Kokki H, Eskelinen M, et al. Laparoscopic versus open orchidopexy in children with intra-abdominal testes. J Laparoendosc Adv Surg Tech A. Jun. 2008;18(3):449-56. [pmid: 18503383].
61 Moursy EE, Gamal W, Hussein MM. Laparoscopic orchiopexy for non-palpable testes: Outcome of two techniques. J Pediatr Urol. April. 2011;7(2):178-81. [pmid: 20541475].
62 Okuyama A, Nonomura N, Nakamura M, et al. Surgical management of undescended testis: retrospective study of potential fertility in 274 cases. J Urol. Sep. 1989;142(3):749-51. [pmid: 2570166].
63 Radmayr C, Oswald J, Schwentner C, et al. Long-term outcome of laparoscopically managed nonpalpable testes. J Urol. Dec. 2003;170(6 Pt 1):2409-11. [pmid: 14634439].
64 Stec AA, Tanaka ST, Adams MC, et al. Orchiopexy for intra-abdominal testes: factors predicting success. J Urol. Oct. 2009;182(4 Suppl):1917-20. [pmid: 19695613].
65 Yavetz H, Harash B, Paz G, et al. Cryptorchidism: incidence and sperm quality in infertile men. Andrologia. Sep–Oct. 1992;24(5):293-7. [pmid: 1356318].