# Evidence Tables

## Tables

Table D-1 Evidence table for studies assessing imaging accuracy

Table D-2 Evidence table for studies assessing hormonal stimulation testing

Table D-3 Evidence table for studies assessing hormonal treatment

Table D-4 Evidence table for studies assessing surgical treatment

## Acronyms/Abbreviations/Symbols

LHRH: Luteinizing Hormone-releasing Hormone
GnRH: Gonadotropin-releasing Hormone
hCG: Human Chorionic Gonadotropin
hMG: Human Menopausal Gonadotropin
KQ: Key Questions
PICOTS: Population, Interventions, Comparators, Outcomes, Timing, Settings
UDT: Undescended Testis
CER: Comparative Effectiveness Review
ARHQ: Agency for Healthcare Research and Quality
TEP: Technical Expert Panel
MeSH: Medical Subject Heading
CINAHL: Cumulative Index to Nursing and Allied Health Literature
PPV: Positive Predictive Value
NPV: Negative Predictive Value
OAC: Overall Accuracy Rate
RCT: Randomized Controlled Trials
QUADAS: Quality Assessment of Diagnostic Accuracy Studies Revised
US: Ultrasonography
MRI: Magnetic Resonance Imaging
CT: Computed Tomography
MRA: Magnetic Resonance Angiogram
MRV: Magnetic Resonance Venogram/Venography
MRA/V: Magnetic Resonance Imaging in combination with arteriography/venography
DWI: Diffusion-weighted Imaging
NPT: Non-Palpable Testes
Se: Sensitivity
Sp: Specificity
IU: International Unit
μg: Microgram
mmol: Millimolar
N: Number
IM: Intramuscular
kg: Kilogram
FS: Fowler-Stevens
SOE: Strength of Evidence