# Excluded Studies

Reasons for exclusion:

- X-1: Not original research
- X-2: Does not include relevant population
- X-3: Does not include an intervention for cryptorchidism
- X-4: Does not utilize a relevant comparison group (for intervention studies only)
- X-5: Does not assess the effectiveness of imagining techniques
- X-6: Is not a study of hormonal stimulation testing for treatment planning
- X-7: Is not an evaluation of the effectiveness of a therapeutic intervention
- X-8: Ineligible study size
- X-9: Not published in English
- X-10: Cannot extract usable data to answer a key question

## Excluded During Abstract Review

1 Cryptorchidism: an apparent substantial increase since 1960. John Radcliffe Hospital Cryptorchidism Study Group. Br Med J (Clin Res Ed). Nov. 29. 1986;293(6559):1401-4. X-3.
2 International Symposium on Pediatric and Surgical Andrology: Cryptorchidism. March. 26–27. Basle, Switzerland. On the occasion of the 125th anniversary of the Children’s Hospital Basle. Eur J Pediatr. 1987. 1987;146(Suppl 2):S1-68. X-1. [pmid: 2891510].
3 Clinical diagnosis of cryptorchidism. John Radcliffe Hospital Cryptorchidism Study Group. Arch Dis Child. Jun. 1988;63(6):587-91. X-3. [pmid: 2898923].
4 Cryptorchidism: a prospective study of 7500 consecutive male births, 1984–8. John Radcliffe Hospital Cryptorchidism Study Group. Arch Dis Child. Jul. 1992;67(7):892-9. X-3, X-4, X-5, X-6. [pmid: 1355643].
5 Cryptorchidism and male pseudo-hermaphroditism. Eur J Pediatr. Suppl 2. 1993;152:S1-92. X-1.
6 Aetiology of testicular cancer: association with congenital abnormalities, age at puberty, infertility, and exercise. United Kingdom Testicular Cancer Study Group. BMJ. May. 28. 1994;308(6941):1393-9. X-2, X-3. [pmid: 7912596].
7 Social, behavioural and medical factors in the aetiology of testicular cancer: results from the UK study. UK Testicular Cancer Study. Group Br J Cancer. Sep. 1994;70(3):513-20. X-2, X-3.
8 Efficacy and safety of highly purified urinary follicle-stimulating hormone with human chorionic gonadotropin for treating men with isolated hypogonadotropic hypogonadism. Fertility and Sterility. Aug. 1998;70(2):256-262. X-2, X-3. [pmid: 9696217].
9 Testicular self-examination. Postgraduate Medicine. 1999;105(4):241. X-1, X-2, X-3. [pmid: 10223101].
10 Testis-sparing surgery for benign testicular tumors in children. J Urol. Jun. 2001;165(6 Pt 2):2280-3. X-2, X-3. [pmid: 11379598].
11 Aass N, Fossa SD, Ous S, et al. Is routine primary retroperitoneal lymph node dissection still justified in patients with low stage non-seminomatous testicular cancer?. Br J Urol. Apr. 1990;65(4):385-90. X-2, X-3. [pmid: 2340372].
12 Aass N, Grunfeld B, Kaalhus O, et al. Pre- and post-treatment sexual life in testicular cancer patients: a descriptive investigation. Br J Cancer. May. 1993;67(5):1113-7. X-2, X-3. [pmid: 8494708].
13 Abantanga FA. Groin and scrotal swellings in children aged 5 years and below: a review of 535 cases. Pediatr Surg Int. Aug. 2003;19(6):446-50. X-4, X-5, X-6. [pmid: 12750933].
14 Abantanga FA, Amaning EP. Paediatric elective surgical conditions as seen at a referral hospital in Kumasi, Ghana. ANZ J Surg. Dec. 2002;72(12):890-2. X-2, X-3. [pmid: 12485228].
15 Abdel-Maguid AF, Othman I. Microsurgical and nonmagnified subinguinal varicocelectomy for infertile men: A comparative study. Fertility and Sterility. December. 2010;94(7):2600-2603. X-2, X-3. [pmid: 20447629].
16 Abdel-Meguid TA. Predictors of sperm recovery and azoospermia relapse in men with nonobstructive azoospermia after varicocele repair. Journal of Urology. January. 2012;187(1):222-226. X-2, X-3. [pmid: 22100001].
17 Abdelrahim F, Mostafa A, Hamdy A, et al. Testicular morphology and function in varicocele patients: pre-operative and post-operative histopathology. Br J Urol. Nov. 1993;72(5 Pt 1):643-7. X-2, X-3. [pmid: 10071553].
18 Abdullah NA, Pearce MS, Parker L, et al. Birth prevalence of cryptorchidism and hypospadias in northern England, 1993–2000. Arch Dis Child. Jul. 2007;92(7):576-9. X-4, X-5, X-6. [pmid: 17142312].
19 Abdur-Rahman LO, Kolawole IK, Adeniran JO, et al. Pediatric day case surgery: experience from a tertiary health institution in Nigeria. Ann Afr Med. Jul–Sep. 2009;8(3):163-7. X-3, X-4, X-5, X-6. [pmid: 19884692].
20 Abe T, Aoyama K, Gotoh T, et al. Cranial attachment of the gubernaculum associated with undescended testes. J Pediatr Surg. May. 1996;31(5):652-5. X-3. [pmid: 8861474].
21 AbouZeid AA, Mousa MH, Soliman HA, et al. Intra-abdominal testis: histological alterations and significance of biopsy. J Urol. Jan. 2011;185(1):269-74. X-3, X-4, X-5, X-6. [pmid: 21075394].
22 Abrahams HM, Kallakury BV, Sheehan CE, et al. A comparison of palpable and impalpable cryptorchid testes using CD-99 immunohistochemistry. BJU Int. Jan. 2004;93(1):130-4. X-4, X-5, X-6. [pmid: 14678384].
23 Abratt RP, Reddi VB, Sarembock LA. Testicular cancer and cryptorchidism. Br J Urol. Dec. 1992;70(6):656-9. X-3. [pmid: 1362513].
24 AbuJbara MA, Hamamy HA, Jarrah NS, et al. Clinical and inheritance profiles of Kallmann syndrome in Jordan. Reproductive Health. 24. Oct. 2004;1(5). X-2, X-3.
25 Abyholm T. Azoospermia and oligozoospermia etiology and clinical findings. Arch Androl. Mar. 1983;10(1):57-65. X-2, X-3. [pmid: 6405704].
26 Acerini CL, Miles HL, Dunger DB, et al. The descriptive epidemiology of congenital and acquired cryptorchidism in a UK infant cohort. Arch Dis Child. Nov. 2009;94(11):868-72. X-3. [pmid: 19542061].
27 Achiron R, Pinhas-Hamiel O, Zalel Y, et al. Development of fetal male gender: Prenatal sonographic measurement of the scrotum and evaluation of testicular descent. Ultrasound in Obstetrics and Gynecology. 1998;11(4):242-245. X-2, X-3. [pmid: 9618845].
28 Acquafredda A, Vassal J, Job JC. Rudimentary testes syndrome revisited. Pediatrics. 1987;80(2):209-214. X-3, X-4, X-5, X-6. [pmid: 3112728].
29 Acs N, Banhidy F, Puho EH, et al. No association between vulvovaginitis-bacterial vaginosis, related drug treatments of pregnant women, and congenital abnormalities in their offspring - A population-based case-control study. Central European Journal of Medicine. September. 2008;3(3):332-340. X-3.
30 Acs N, Banhidy F, Puho EH, et al. Senna treatment in pregnant women and congenital abnormalities in their offspring-A population-based case-control study. Reproductive Toxicology. July. 2009;28(1):100-104. X-2, X-3. [pmid: 19491001].
31 Adachi M, Asakura Y, Tachibana K, et al. Abnormal steroidogenesis in three patients with Antley-Bixler syndrome: Apparent decreased activity of 17alpha-hydroxylase, 17,20-lyase and 21-hydroxylase. Pediatrics International. Oct. 2004;46(5):583-589. X-2, X-3. [pmid: 15491389].
32 Adaletli I, Kurugoglu S, Kantarci F, et al. Testicular volume before and after hydrocelectomy in children. J Ultrasound Med. Sep. 2006;25(9):1131-6. quiz 1137–8. X-2, X-3. [pmid: 16929013].
33 Adam AS, Allaway AJ. The difficult orchidopexy: the value of the abdominal pre-peritoneal approach. BJU Int. Feb. 1999;83(3):290-3. X-4, X-5, X-6. [pmid: 10233497].
34 Adams SV, Hastert TA, Huang Y, et al. No association between maternal pre-pregnancy obesity and risk of hypospadias or cryptorchidism in male newborns. Birth Defects Res A Clin Mol Teratol. Apr. 2011;91(4):241-8. X-3. 3142793. [pmid: 21462299].
35 Adamsen S, Borjesson B. Factors affecting the outcome of orchiopexy for undescended testis. Acta Chir Scand. Sep. 1988;154(9):529-33. X-4, X-5, X-6. [pmid: 2904721].
36 Adan L, Couto-Silva AC, Trivin C, et al. Congenital gonadotropin deficiency in boys: management during childhood. J Pediatr Endocrinol Metab. Feb. 2004;17(2):149-55. X-3. [pmid: 15055348].
37 Adan L, Lechevalier P, Couto-Silva AC, et al. Plasma inhibin B and antimullerian hormone concentrations in boys: Discriminating between congenital hypogonadotropic hypogonadism and constitutional pubertal delay. Case Reports and Clinical Practice Review. 2010;16(11):CR511-CR517. X-2, X-3.
38 Adeoti ML, Fadiora SO, Oguntola AS, et al. Cryptorchidism in a local population in Nigeria. West African Journal of Medicine. Jan. 2004;23(1):62-64. X-2, X-3. [pmid: 15171530].
39 Adesunkanmi AR, Adejuyigbe O, Agbakwuru EA. Prognostic factors in childhood inguinal hernia at Wesley Guild Hospital, Ilesa, Nigeria. East Afr Med J. Mar. 1999;76(3):144-7. X-3. [pmid: 10442114].
40 Adham MN, Teimourian B, Mosca P. Buried penis release in adults with suction lipectomy and abdominoplasty. Plast Reconstr Surg. Sep. 2000;106(4):840-4. X-2, X-3. [pmid: 11007398].
41 Adiga SK, Ehmcke J, Schlatt S, et al. Reduced expression of DNMT3B in the germ cells of patients with bilateral spermatogenic arrest does not lead to changes in the global methylation status. Molecular Human Reproduction. September. 2011;17(9):545-549. (gar023). X-2, X-3. [pmid: 21482616].
42 Aeberhard P, Klaiber C, Meyenberg A, et al. Prospective audit of laparoscopic totally extraperitoneal inguinal hernia repair: A multicenter study of the Swiss Association for Laparoscopic and Thoracoscopic Surgery (SALTC). Surgical Endoscopy. Nov. 1999;13(11):1115-1120. X-2, X-3. [pmid: 10556450].
43 Afsar H, Baydar I, Sirmatel F. Epididymo-orchitis due to brucellosis. Br J Urol. Jul. 1993;72(1):104-5. X-2, X-3. [pmid: 8149154].
44 Agarwal BB, Manish K. Endoscopic varicocelectomy by extraperitoneal route: a novel technique. Int J Surg. Aug. 2009;7(4):377-81. X-2, X-3. [pmid: 19540943].
45 Agarwal PK, Diaz M, Elder JS. Retractile testis--is it really a normal variant?. J Urol. Apr. 2006;175(4):1496-9. X-3, X-4, X-5, X-6. [pmid: 16516034].
46 Agarwal S. Vascular morphology in testes of infertile males with varicocele. Indian J Med Res. Jun. 1991;94:228-31. X-2, X-3. [pmid: 1937605].
47 Agarwal V, Li JKH, Bard R. Lymphocytic orchitis: A case report. Human Pathology. 1990;21(10):1080-1082. X-2, X-3. [pmid: 2210732].
48 Agostini S, Magrini SM, Simoncini R, et al. Association between testicular cancer and spinal bifida occulta. Acta Oncologica. 1991;30(5):579-581. X-2, X-3. [pmid: 1892674].
49 Agrawal A, Joshi M, Mishra P, et al. Laparoscopic Stephen-Fowler stage procedure: appropriate management for high intra-abdominal testes. J Laparoendosc Adv Surg Tech A. Mar. 2010;20(2):183-5. X-4, X-5, X-6. [pmid: 19916748].
50 Agrawal S, Shaw A, Soon Y. Single-port laparoscopic totally extraperitoneal inguinal hernia repair with the TriPort system: initial experience. Surg Endosc. Apr. 2010;24(4):952-6. X-2, X-3. [pmid: 19730953].
51 Aguilera RG, Lopez JP, Aldosa RR, et al. Intralbugineous testicular prosthesis, a new technique. Summary of 30 implants. Int Urol Nephrol. 1990;22(4):367-71. X-2, X-3. [pmid: 2228499].
52 Ahmed E, Young RH, Scully RE. Adult granulosa cell tumor of the ovary with foci of hepatic cell differentiation: a report of four cases and comparison with two cases of granulosa cell tumor with Leydig cells. Am J Surg Pathol. Sep. 1999;23(9):1089-93. X-2, X-3. [pmid: 10478669].
53 Ahmed SF, Cheng A, Dovey L, et al. Phenotypic features, androgen receptor binding, and mutational analysis in 278 clinical cases reported as androgen insensitivity syndrome. J Clin Endocrinol Metab. Feb. 2000;85(2):658-65. X-2, X-3. [pmid: 10690872].
54 Ahmed SF, Keir L, McNeilly J, et al. The concordance between serum anti-Mullerian hormone and testosterone concentrations depends on duration of hCG stimulation in boys undergoing investigation of gonadal function. Clin Endocrinol (Oxf). Jun. 2010;72(6):814-9. X-3, X-4, X-5, X-6. [pmid: 19811508].
55 Aizenstein RI, DiDomenico D, Wilbur AC, et al. Testicular microlithiasis: association with male infertility. J Clin Ultrasound. May. 1998;26(4):195-8. X-2, X-3. [pmid: 9572382].
56 Akbay E, Cayan S, Doruk E, et al. The prevalence of varicocele and varicocele-related testicular atrophy in Turkish children and adolescents. BJU Int. Sep. 2000;86(4):490-3. X-2, X-3. [pmid: 10971279].
57 Akbulut G, Serteser M, Yucel A, et al. Can laparoscopic hernia repair alter function and volume of testis? Randomized clinical trial. Surg Laparosc Endosc Percutan Tech. Dec. 2003;13(6):377-81. X-2, X-3. [pmid: 14712099].
58 Akdogan B, Divrik RT, Tombul T, et al. Bilateral testicular germ cell tumors in Turkey: increase in incidence in last decade and evaluation of risk factors in 30 patients. J Urol. Jul. 2007;178(1):129-33. discussion 133. X-2, X-3. [pmid: 17499297].
59 Akinci E, Bodur H, Cevik MA, et al. A complication of brucellosis: epididymoorchitis. Int J Infect Dis. Mar. 2006;10(2):171-7. X-2, X-3. [pmid: 16360332].
60 Akre O, Lipworth L, Cnattingius S, et al. Risk factor patterns for cryptorchidism and hypospadias. Epidemiology. Jul. 1999;10(4):364-9. X-3. [pmid: 10401869].
61 Aksglaede L, Christiansen P, Sorensen K, et al. Serum concentrations of Anti-Mullerian Hormone (AMH) in 95 patients with Klinefelter syndrome with or without cryptorchidism. Acta Paediatr. Jun. 2011;100(6):839-45. X-3. [pmid: 21251056].
62 Aksglaede L, Skakkebaek NE, Almstrup K, et al. Clinical and biological parameters in 166 boys, adolescents and adults with nonmosaic Klinefelter syndrome: a Copenhagen experience. Acta Paediatr. Jun. 2011;100(6):793-806. X-3. [pmid: 21362037].
63 Aksglaede L, Sorensen K, Boas M, et al. Changes in anti-Mullerian hormone (AMH) throughout the life span: a population-based study of 1027 healthy males from birth (cord blood) to the age of 69 years. J Clin Endocrinol Metab. Dec. 2010;95(12):5357-64. X-2, X-3. [pmid: 20843948].
64 al-Abbadi K, Smadi SA. Genital abnormalities and groin hernias in elementary-school children in Aqaba: an epidemiological study. East Mediterr Health J. Mar–May. 2000;6(2–3):293-8. X-3. [pmid: 11556015].
65 Al-Adl AM. Intra-testicular hemodynamics and seminal parameters in men with oligospermia: Preoperative predictors of improvement after Varicocelectomy. Current Urology. December. 2010;4(4):182-187. X-2, X-3.
66 Al-Agha AE, Thomsett MJ, Batch JA. The child of uncertain sex: 17 years of experience. J Paediatr Child Health. Aug. 2001;37(4):348-51. X-2, X-3. [pmid: 11532053].
67 Alam S, Radhakrishnan J. Laparoscopy for nonpalpable testes. J Pediatr Surg. Oct. 2003;38(10):1534-6. X-4, X-5, X-6. [pmid: 14577082].
68 Albayrak S, Can C, Sarica K. Extended vein ligation: a new aspect of the surgical treatment of varicocele. Urol Int. 1993;51(4):220-4. X-2, X-3. [pmid: 8266614].
69 Albers P, Goll A, Bierhoff E, et al. Clinical course and histopathologic risk factor assessment in patients with bilateral testicular germ cell tumors. Urology. Oct. 1999;54(4):714-718. X-2, X-3. [pmid: 10510934].
70 Albores-Saavedra J, Huffman H, Alvarado-Cabrero I, et al. Anaplastic variant of spermatocytic seminoma. Human Pathology. 1996;27(7):650-655. X-2, X-3. [pmid: 8698307].
71 Alderdice JM, Merrett JD. Factors influencing the survival of patients with testicular teratoma. J Clin Pathol. Jul. 1985;38(7):791-6. X-2, X-3. [pmid: 2410461].
72 Al-Fifi S, Al-Binali A, Al-Shahrani M, et al. Congenital anomalies and other perinatal outcomes in ICSI vs. naturally conceived pregnancies: A comparative study. Journal of Assisted Reproduction and Genetics. July. 2009;26(7):377-381. X-2, X-3. [pmid: 19680803].
73 Alicelebic S, Kapic D, Mornjakovic Z. Urinary system birth defects in surgically treated infants in Sarajevo region of Bosnia and Herzegovina. Bosn J Basic Med Sci. May. 2008;8(2):126-30. X-2, X-3. [pmid: 18498261].
74 Allanson JE, Anneren G, Aoki Y, et al. Cardio-facio-cutaneous syndrome: Does genotype predict phenotype?. American Journal of Medical Genetics, Part C: Seminars in Medical Genetics. 15. May. 2011;157(2):129-135. X-2, X-3.
75 Al-Marzooq RH, Al-Rayes AAN, Altawash FM. Paediatric Testicular Torsion - Clinical Evaluation and Role of Doppler Ultrasound. Bahrain Medical Bulletin. Dec. 2003;25(4):153-155. X-2, X-3.
76 Almeida C, Cunha M, Ferraz L, et al. Caspase-3 detection in human testicular spermatozoa from azoospermic and non-azoospermic patients. International Journal of Andrology. October. 2011;34(5 PART 2):e407-e414. X-2, X-3. [pmid: 21812785].
77 Almstrup K, Lippert M, Mogensen HO, et al. Screening of subfertile men for testicular carcinoma in situ by an automated image analysis-based cytological test of the ejaculate. International Journal of Andrology. August. 2011;34(4 PART 2):e21-e31. X-2, X-3. [pmid: 21696398].
78 Al-Saied G. Balloon inflation-created subdartos pouch during orchiopexy: a new simplified technique. Pediatr Surg Int. Oct. 2008;24(10):1187-90. X-4, X-5, X-6. [pmid: 18751986].
79 Al-Salem AH. Intra-uterine testicular torsion: early diagnosis and treatment. BJU Int. Jun. 1999;83(9):1023-5. X-2, X-3. [pmid: 10368249].
80 Al-Salem AH. Intrauterine testicular torsion: a surgical emergency. J Pediatr Surg. Nov. 2007;42(11):1887-91. X-2, X-3. [pmid: 18022441].
81 Altarac S. Management of 53 cases of testicular trauma. Eur Urol. 1994;25(2):119-23. X-2, X-3. [pmid: 8137851].
82 Altay B, Hekimgil M, Cikili N, et al. Histopathological mapping of open testicular biopsies in patients with unobstructive azoospermia. BJU Int. Jun. 2001;87(9):834-7. X-2, X-3. [pmid: 11412222].
83 Alukal JP, Lipshultz LI. Why treat the male in the Era of assisted Reproduction?. Seminars in Reproductive Medicine. March. 2009;27(2):109-114. X-1, X-2, X-3. [pmid: 19247912].
84 Alvarez-Nava F, Gonzalez S, Soto M, et al. Complete androgen insensitivity syndrome: clinical and anatomopathological findings in 23 patients. Genet Couns. 1997;8(1):7-12. X-2, X-3. [pmid: 9101272].
85 Alvarez-Nava F, Gonzalez S, Soto S, et al. Mixed gonadal dysgenesis: a syndrome of broad clinical, cytogenetic and histopathologic spectrum. Genet Couns. 1999;10(3):233-43. X-2, X-3. [pmid: 10546094].
86 Alvarez-Nava F, Soto M, Temponi A, et al. Female pseudohermaphroditism with phallic urethra in the offspring of a mother with an adrenal tumor. J Pediatr Endocrinol Metab. Nov. 2004;17(11):1571-4. X-1, X-2, X-3. [pmid: 15570996].
87 Al-Zahem A, Shun A. Routine contralateral orchiopexy for children with a vanished testis. Eur J Pediatr Surg. Oct. 2006;16(5):334-6. X-2. [pmid: 17160778].
88 Amat P, Paniagua R, Montero J. Seminiferous tubule degeneration in human cryptorchid testes. J Androl. Jan–Feb. 1985;6(1):1-9. X-2, X-3. [pmid: 2857707].
89 Amati S, Petrini E, Ceresi E, et al. Particular ultrastructural aspects of cryptorchid testis in adult and advanced age. Boll Soc Ital Biol Sper. Apr. 30. 1984;60(4):805-10. X-2, X-3. [pmid: 6145433].
90 Ameh EA. Morbidity and mortality of inguinal hernia in the newborn. Niger Postgrad Med J. Dec. 2002;9(4):233-4. X-2, X-3. [pmid: 12690685].
91 Amendola BE, Hutchinson R, Grossman HB, et al. Isolated testicular leukemic relapse. Response to radiation therapy. Urology. Sep. 1987;30(3):240-3. X-2, X-3. [pmid: 3477044].
92 Amer M, Ateyah A, Hany R, et al. Prospective comparative study between microsurgical and conventional testicular sperm extraction in non-obstructive azoospermia: follow-up by serial ultrasound examinations. Hum Reprod. Mar. 2000;15(3):653-6. X-2, X-3. [pmid: 10686214].
93 Amer M, Haggar SE, Moustafa T, et al. Testicular sperm extraction: impact of testicular histology on outcome, number of biopsies to be performed and optimal time for repetition. Hum Reprod. Dec. 1999;14(12):3030-4. X-2, X-3. [pmid: 10601092].
94 Amiel GE, Sukhotnik I, Kawar B, et al. Use of N-butyl-2-cyanoacrylate in elective surgical incisions--longterm outcomes. J Am Coll Surg. Jul. 1999;189(1):21-5. X-3. [pmid: 10401736].
95 Anand J, Kumaran V, Rajamani G, et al. Route to neo-inguinal canal: Our experience. Journal of Minimal Access Surgery. July–September. 2011;7(3):178-180. X-4, X-5, X-6. [pmid: 22022100].
96 Andersen HR, Schmidt IM, Grandjean P, et al. Impaired reproductive development in sons of women occupationally exposed to pesticides during pregnancy. Environ Health Perspect. Apr. 2008;116(4):566-72. X-2, X-3. [pmid: 18414644].
97 Andersen L, Wille-Jorgensen PA. Torsion of the testis. A 5-year material. Scand J Urol Nephrol. 1990;24(2):91-3. X-2, X-3. [pmid: 1972591].
98 Anderson JB, Cooper MJ, Thomas WE, et al. Impaired spermatogenesis in testes at risk of torsion. Br J Surg. Oct. 1986;73(10):847-9. X-2, X-3. [pmid: 3768659].
99 Anderson JB, Williamson RC. The fate of the human testes following unilateral torsion of the spermatic cord. Br J Urol. Dec. 1986;58(6):698-704. X-2, X-3. [pmid: 3099882].
100 Anderson MJ, Dunn JK, Lipshultz LI, et al. Semen quality and endocrine parameters after acute testicular torsion. J Urol. Jun. 1992;147(6):1545-50. X-2, X-3. [pmid: 1593686].
101 Andersson AM, Jorgensen N, Frydelund-Larsen L, et al. Impaired Leydig cell function in infertile men: a study of 357 idiopathic infertile men and 318 proven fertile controls. J Clin Endocrinol Metab. Jul. 2004;89(7):3161-7. X-2, X-3. [pmid: 15240588].
102 Andersson AM, Petersen JH, Jorgensen N, et al. Serum inhibin B and follicle-stimulating hormone levels as tools in the evaluation of infertile men: significance of adequate reference values from proven fertile men. J Clin Endocrinol Metab. Jun. 2004;89(6):2873-9. X-2, X-3. [pmid: 15181071].
103 Andrade-Rocha FT. Ureaplasma urealyticum and Mycoplasma hominis in men attending for routine semen analysis. Prevalence, incidence by age and clinical settings, influence on sperm characteristics, relationship with the leukocyte count and clinical value. Urol Int. 2003;71(4):377-81. X-2, X-3. [pmid: 14646436].
104 Andreassen KE, Grotmol T, Cvancarova MS, et al. Risk of metachronous contralateral testicular germ cell tumors: a population-based study of 7,102 Norwegian patients (1953–2007). Int J Cancer. Dec. 15. 2011;129(12):2867-74. X-2, X-3. [pmid: 21626506].
105 Anger JT, Goldstein M. Intravasal “toothpaste” in men with obstructive azoospermia is derived from vasal epithelium, not sperm. J Urol. Aug. 2004;172(2):634-6. X-2, X-3. [pmid: 15247749].
106 Angulo JC, Gonzalez J, Rodriguez N, et al. Clinicopathological study of regressed testicular tumors (apparent extragonadal germ cell neoplasms). J Urol. Nov. 2009;182(5):2303-10. X-2, X-3. [pmid: 19762049].
107 Angwafo FF 3rd, Takongmo S, Mbakop A, et al. Testes tumors in a Sub-Saharan African city (Yaounde). Incident cases and histopathology. Eur Urol. 1996;30(3):345-8. X-2, X-3. [pmid: 8931968].
108 Antao B, Mackinnon E. Simple placement of prosthetic testes in children. Pediatric Surgery International. May. 2006;22(5):422-424. X-3, X-4, X-5, X-6. [pmid: 16609898].
109 Antic T, Hyjek EM, Taxy JB. The vanishing testis: a histomorphologic and clinical assessment. Am J Clin Pathol. Dec. 2011;136(6):872-80. X-3. [pmid: 22095372].
110 Antinori S, Versaci C, Dani G, et al. Fertilization with human testicular spermatids: four successful pregnancies. Hum Reprod. Feb. 1997;12(2):286-91. X-2, X-3. [pmid: 9070712].
111 Aoki K, Hirayama A, Tanaka N, et al. A higher level of prostaglandin E2 in the urinary bladder in young boys and boys with lower urinary tract obstruction. Biomedical Research. December. 2009;30(6):343-347. X-2, X-3. [pmid: 20051643].
112 Aparicio-Rodriguez JM, Cuellar-Lopez F, Hurtado-Hernandez ML, et al. Disorders of sexual development in genetic pediatrics: Three different ambiguous genitalia cases report from hospital para el Nino Poblano, Mexico. International Journal of Genetics and Molecular Biology. December. 2010;2(10):207-216. X-2, X-3.
113 Aprikian AG, Herr HW, Bajorin DF, et al. Resection of postchemotherapy residual masses and limited retroperitoneal lymphadenectomy in patients with metastatic testicular nonseminomatous germ cell tumors. Cancer. Aug. 15. 1994;74(4):1329-34. X-2, X-3. [pmid: 8055456].
114 Aragona F, Ragazzi R, Pozzan GB, et al. Correlation of testicular volume, histology and LHRH test in adolescents with idiopathic varicocele. Eur Urol. 1994;26(1):61-6. X-2, X-3. [pmid: 7925532].
115 Aragona F, Talenti E, Santacatterina U, et al. Unusual, benign asymptomatic scrotal masses in children: Case reports and review of the literature. International Urology and Nephrology. 1994;26(5):563-570. X-2, X-3. [pmid: 7860206].
116 Arai A, Mitsuhashi S, Saito Y, et al. Nemaline (actin) myopathy with myofibrillar dysgenesis and abnormal ossification. Neuromuscul Disord. Jul. 2009;19(7):485-8. X-1, X-2, X-3. [pmid: 19553121].
117 Arai Y, Ishitoya S, Okubo K, et al. Nerve-sparing retroperitoneal lymph node dissection for metastatic testicular cancer. Int J Urol. Sep. 1997;4(5):487-92. X-2, X-3. [pmid: 9354952].
118 Arcari AJ, Bergada I, Rey RA, et al. Predictive value of anatomical findings and karyotype analysis in the diagnosis of patients with disorders of sexual development. Sex Dev. 2007;1(4):222-9. X-2, X-3. [pmid: 18391533].
119 Arce B, Padron RS, Perez-Plaza M. Sterility caused by functional absence of ejaculatory ducts. Reproduccion. Apr–Jun. 1981;5(2):105-11. X-2, X-3. [pmid: 7262455].
120 Arena F, Arena S, Paolata A, et al. Is a complete urological evaluation necessary in all newborns with asymptomatic renal ectopia?. Int J Urol. Jun. 2007;14(6):491-5. X-2, X-3. [pmid: 17593091].
121 Arena F, Nicotina PA, Romeo C, et al. Prenatal testicular torsion: ultrasonographic features, management and histopathological findings. Int J Urol. Feb. 2006;13(2):135-41. X-2, X-3. [pmid: 16563138].
122 Arenas MI, Lobo MV, Caso E, et al. Normal and pathological human testes express hormone-sensitive lipase and the lipid receptors CLA-1/SR-BI and CD36. Hum Pathol. Jan. 2004;35(1):34-42. X-2, X-3. [pmid: 14745722].
123 Armstrong GR, Buckley CH, Kelsey AM. Germ cell expression of placental alkaline phosphatase in male pseudohermaphroditism. Histopathology. Jun. 1991;18(6):541-7. X-2, X-3. [pmid: 1879814].
124 Arnbjornsson E, Kullendorff CM. Testicular torsion in children--bilateral or unilateral operation. Acta Chir Scand. 1985;151(5):425-7. X-2, X-3. [pmid: 4050272].
125 Arnhold IJP, Melo K, Costa EMF, et al. 46,XY disorders of sex development (46,XY DSD) due to androgen receptor defects: Androgen insensitivity syndrome. Endocrinology. (Advances in Experimental Medicine and Biology. 707). 2011:59-61. X-2, X-3. [pmid: 21047945].
126 Arora R, Thakur JS, Azad RK, et al. Cisplatin-based chemotherapy: Add high-frequency audiometry in the regimen. Indian Journal of Cancer. 01. Oct. 2009;46(4):311-317. X-2, X-3. [pmid: 19749461].
127 Arrigo T, De Luca F, Maghnie M, et al. Relationships between neuroradiological and clinical features in apparently idiopathic hypopituitarism. Eur J Endocrinol. Jul. 1998;139(1):84-8. X-2, X-3. [pmid: 9703383].
128 Ars E, Lo Giacco D, Bassas L, et al. Further insights into the role of T222P variant of RXFP2 in non-syndromic cryptorchidism in two Mediterranean populations. Int J Androl. Aug. 2011;34(4):333-8. X-3. [pmid: 20636340].
129 Asakura Y, Toyota Y, Muroya K, et al. Endocrine and radiological studies in patients with molecularly confirmed CHARGE syndrome. J Clin Endocrinol Metab. Mar. 2008;93(3):920-4. X-2, X-3. [pmid: 18089695].
130 Aschim EL, Nordenskjold A, Giwercman A, et al. Linkage between cryptorchidism, hypospadias, and GGN repeat length in the androgen receptor gene. J Clin Endocrinol Metab. Oct. 2004;89(10):5105-9. X-3. [pmid: 15472213].
131 Ashley RA, Barthold JS, Kolon TF. Cryptorchidism: pathogenesis, diagnosis, treatment and prognosis. Urol Clin North Am. May. 2010;37(2):183-93. X-1. [pmid: 20569797].
132 Ashley RA, McGee SM, Isotaolo PA, et al. Clinical and pathological features associated with the testicular tumor of the adrenogenital syndrome. J Urol. Feb. 2007;177(2):546-9. discussion 549. X-2, X-3. [pmid: 17222630].
133 Ashley RA, Yu Z, Fung KM, et al. Developmental evaluation of aldo-keto reductase 1C3 expression in the cryptorchid testis. Urology. Jul. 2010;76(1):67-72. X-3, X-4, X-5, X-6. [pmid: 19942269].
134 Askin FB, Land VJ, Sullivan MP, et al. Occult testicular leukemia: testicular biopsy at three years continuous complete remission of childhood leukemia: a Southwest Oncology Group Study. Cancer. Feb. 1. 1981;47(3):470-5. X-2, X-3. [pmid: 6939470].
135 Asklund C, Jorgensen N, Skakkebaek NE, et al. Increased frequency of reproductive health problems among fathers of boys with hypospadias. Hum Reprod. Oct. 2007;22(10):2639-46. X-2, X-3. [pmid: 17728352].
136 Assaf GJ. Non-palpable testicular lesion: the case for testicular preservation. Can J Urol. Apr. 2006;13(2):3034-8. X-2, X-3. [pmid: 16672115].
137 Assies J, Gooren LJG, Van Geel B, et al. Signs of testicular insufficiency in andrenomyeloneuropathy and neurologically asymptomatic X-linked adrenoleukodystrophy: A retrospective study. International Journal of Andrology. 1997;20(5):315-321. X-2, X-3. [pmid: 16130276].
138 Assmus M, Svechnikov K, von Euler M, et al. Single subcutaneous administration of chorionic gonadotropin to rats induces a rapid and transient increase in testicular expression of pro-inflammatory cytokines. Pediatr Res. Jun. 2005;57(6):896-901. X-2, X-3. [pmid: 15845639].
139 Assumpcao JG, Ferraz LFC, Benedetti CE, et al. A naturally occurring deletion in the SRY promoter region affecting the Sp1 binding site is associated with sex reversal. Journal of Endocrinological Investigation. 2005;28(7):651-656. X-2, X-3. [pmid: 16218050].
140 Atasoy C, Fitoz S. Gray-scale and color Doppler sonographic findings in intratesticular varicocele. J Clin Ultrasound. Sep. 2001;29(7):369-73. X-2, X-3. [pmid: 11579398].
141 Ates O, Aktug T, Hakguder G, et al. The role of simulated models in pediatric surgery to acquire diagnostic skills of inguino-scrotal disorders. J Pediatr Surg. Nov. 2003;38(11):1616-20. X-2, X-3. [pmid: 14614711].
142 Atilla MK, Sargin H, Yilmaz Y, et al. Undescended testes in adults: clinical significance of resistive index values of the testicular artery measured by Doppler ultrasound as a predictor of testicular histology. J Urol. Sep. 1997;158(3 Pt 1):841-3. X-2, X-3. [pmid: 9258095].
143 Atlas I, Stone N. Laparoscopy for evaluation of cryptorchid testis. Urology. Sep. 1992;40(3):256-8. X-4, X-5, X-6. [pmid: 1355936].
144 Atwell JD. Ascent of the testis: Fact or fiction. British Journal of Urology. 1985;57(4):474-477. X-3, X-4, X-5, X-6. [pmid: 2862947].
145 Atwell JD, Levick P. Congenital hypertrophic pyloric stenosis and associated anomalies in the genitourinary tract. J Pediatr Surg. Dec. 1981;16(6):1029-35. X-2, X-3. [pmid: 6279815].
146 Atwood CS, Bowen RL. Metabolic clues regarding the enhanced performance of elite endurance athletes from orchiectomy-induced hormonal changes. Med Hypotheses. 2007;68(4):735-49. X-2, X-3. [pmid: 17095167].
147 Audry G, Johanet S, Achrafi H, et al. The risk of wound infection after inguinal incision in pediatric outpatient surgery. Eur J Pediatr Surg. Apr. 1994;4(2):87-9. X-2, X-3. [pmid: 7912955].
148 Auger J, Eustache F, Andersen AG, et al. Sperm morphological defects related to environment, lifestyle and medical history of 1001 male partners of pregnant women from four European cities. Hum Reprod. Dec. 2001;16(12):2710-7. X-2, X-3. [pmid: 11726600].
149 Auzanneau C, Norez C, Antigny F, et al. Transient receptor potential vanilloid 1 (TRPV1) channels in cultured rat Sertoli cells regulate an acid sensing chloride channel. Biochemical Pharmacology. 15. Jan. 2008;75(2):476-483. X-2, X-3. [pmid: 17945192].
150 Avci A, Erol B, Eken C, et al. Nine cases of nonpalpable testicular mass: an incidental finding in a large scale ultrasonography survey. Int J Urol. Sep. 2008;15(9):833-6. X-2, X-3. [pmid: 18662173].
151 Avila NA, Shawker TS, Jones JV, et al. Testicular adrenal rest tissue in congenital adrenal hyperplasia: serial sonographic and clinical findings. AJR Am J Roentgenol. May. 1999;172(5):1235-8. X-2, X-3. [pmid: 10227495].
152 Avlan D, Erdougan K, Cimen B, et al. The protective effect of selenium on ipsilateral and contralateral testes in testicular reperfusion injury. Pediatr Surg Int. Apr. 2005;21(4):274-8. X-2, X-3. [pmid: 15742187].
153 Avolio L, Chiari G, Caputo MA, et al. Abdominoscrotal hydrocele in childhood: is it really a rare entity?. Urology. Dec. 20. 2000;56(6):1047-9. X-2, X-3. [pmid: 11113758].
154 Awojobi OA, Nkposong EO. Seminal fluid changes after testicular torsion. Urology. Feb. 1986;27(2):109-11. X-2, X-3. [pmid: 3946032].
155 Aydos K, Soygur T, Kupeli B, et al. Testicular effects of vasectomy in rats: An ultrastructural and immunohistochemical study. Urology. Jun. 1998;51(6):1051-1056. X-2, X-3. [pmid: 9609654].
156 Ayub K, Williams MP. A simple alternative technique of orchiopexy for high undescended testis. Ann R Coll Surg Engl. Jan. 1998;80(1):69-71. X-1. [pmid: 9579135].
157 Ayyash EH, Hamza A, Al Dahham A, et al. Laparoscopic inguinal hernia repair using the TEP technique: A preliminary report. Kuwait Medical Journal. June. 2008;40(2):137-139. X-2, X-3.
158 Babaian RJ, Zagars GK. Testicular seminoma: the MD Anderson experience. An analysis of pathological and patient characteristics, and treatment recommendations. J Urol. Feb. 1988;139(2):311-4. X-2, X-3. [pmid: 3339730].
159 Baccetti B, Collodel G, Piomboni P. Apoptosis in human ejaculated sperm cells (notulae seminologicae 9). J Submicrosc Cytol Pathol. Oct. 1996;28(4):587-96. X-2, X-3. [pmid: 8933742].
160 Bach AM, Hann LE, Shi W, et al. Is there an increased incidence of contralateral testicular cancer in patients with intratesticular microlithiasis?. AJR Am J Roentgenol. Feb. 2003;180(2):497-500. X-2, X-3. [pmid: 12540459].
161 Bach DW, Weissbach L, Hartlapp JH. Bilateral testicular tumor. J Urol. May. 1983;129(5):989-91. X-2, X-3. [pmid: 6854777].
162 Bach JR. Medical considerations of long-term survival of Werdnig-Hoffmann disease. Am J Phys Med Rehabil. May. 2007;86(5):349-55. X-2, X-3. [pmid: 17449979].
163 Bach T, Pfeiffer D, Tauber R. Baseline follicle-stimulating hormone is a strong predictor for the outcome of the gonadotrophin-releasing hormone test in young men with unilateral medium- or high-grade varicocele. BJU Int. Sep. 2006;98(3):619-22. X-2, X-3. [pmid: 16925763].
164 Backus ML, Mack LA, Middleton WD, et al. Testicular microlithiasis: imaging appearances and pathologic correlation. Radiology. Sep. 1994;192(3):781-5. X-2, X-3. [pmid: 8058947].
165 Bacon CM, Ye H, Diss TC, et al. Primary follicular lymphoma of the testis and epididymis in adults. Am J Surg Pathol. Jul. 2007;31(7):1050-8. X-2, X-3. [pmid: 17592272].
166 Bader MI, Peeraully R, Ba’ath M, et al. The testicular regression syndrome--do remnants require routine excision?. J Pediatr Surg. Feb. 2011;46(2):384-6. X-2, X-3. [pmid: 21292092].
167 Baek M, Park SW, Moon KH, et al. Nationwide survey to evaluate the prevalence of varicoceles in South Korean middle school boys: a population based study. Int J Urol. Jan. 2011;18(1):55-60. X-2, X-3. [pmid: 21077961].
168 Baghdassarian R, Tansey LA, Martin DC, et al. Use of bupivacaine as block to relieve postoperative pain in pediatric orchiopexy and hernia repair. Urology. Jun. 1986;27(6):537-9. X-3, X-4, X-5, X-6. [pmid: 2872745].
169 Baglaj M, Carachi R. Neonatal bilateral testicular torsion: a plea for emergency exploration. J Urol. Jun. 2007;177(6):2296-9. X-2, X-3. [pmid: 17509343].
170 Bahador A, Hosseini SMV, Foroutan H, et al. Total inguinal canal mobilization in two-stage orchiopexy. Iranian Journal of Medical Sciences. June. 2009;34(2):100-103. X-4, X-5, X-6.
171 Bahceci M, Ersay AR, Tuzcu A, et al. A novel missense mutation of 5-alpha reductase type 2 gene (SRD5A2) leads to severe male pseudohermaphroditism in a Turkish family. Urology. Aug. 2005;66(2):407-10. X-2, X-3. [pmid: 16098368].
172 Bajpai A, Kabra M, Menon PS. 21-Hydroxylase deficiency: clinical features, laboratory profile and pointers to diagnosis in Indian children. Indian Pediatr. Dec. 2004;41(12):1226-32. X-2, X-3. [pmid: 15623903].
173 Baker BA, Morley R, Lucas A. Plasma testosterone in preterm infants with cryptorchidism. Arch Dis Child. Oct. 1988;63(10):1198-200. X-3. [pmid: 2904244].
174 Bale PM, Howard NJ, Wright JE. Male pseudohermaphroditism in XY children with female phenotype. Pediatr Pathol. Jan–Feb. 1992;12(1):29-49. X-2, X-3. [pmid: 1561151].
175 Bandak M, Aksglaede L, Juul A, et al. The pituitary-Leydig cell axis before and after orchiectomy in patients with stage I testicular cancer. Eur J Cancer. Nov. 2011;47(17):2585-91. X-2, X-3. [pmid: 21704509].
176 Banhidy F, Acs N, Puho E, et al. A population-based case-control teratologic study of oral dipyrone treatment during pregnancy. Drug Safety. 2007;30(1):59-70. X-2, X-3. [pmid: 17194171].
177 Banhidy F, Acs N, Puho EH, et al. Possible association of maternal haemorrhoid with congenital abnormalities in their children - A population-based case-control study. Balkan Journal of Medical Genetics. 01. Jan. 2010;13(1):23-33. X-2, X-3.
178 Banhidy F, Puho EH, Czeizel AE. Efficacy of medical care of epileptic pregnant women based on the rate of congenital abnormalities in their offspring. Congenital Anomalies. March. 2011;51(1):34-42. X-3. [pmid: 21039911].
179 Banieghbal B. A simplified technique for giant inguinal hernia repair in infants. Pediatr Surg Int. Jun. 2008;24(6):737-9. X-1, X-2, X-3. [pmid: 18408940].
180 Baniel J, Foster RS, Rowland RG, et al. Complications of primary retroperitoneal lymph node dissection. J Urol. Aug. 1994;152(2 Pt 1):424-7. X-2, X-3. [pmid: 8015086].
181 Baniel J, Foster RS, Rowland RG, et al. Complications of primary retroperitoneal lymph-node dissection for low-stage testicular cancer. World J Urol. 1994;12(3):139-42. X-2, X-3. [pmid: 7951340].
182 Bani-Hani KE, Matani YS, Bani-Hani IH. Cryptorchidism and testicular neoplasia. Saudi Med J. Feb. 2003;24(2):166-9. X-3. [pmid: 12682681].
183 Banker BQ. Arthrogryposis multiplex congenita: spectrum of pathologic changes. Hum Pathol. Jul. 1986;17(7):656-72. X-2, X-3. [pmid: 3721492].
184 Barone JG, Christiano AP, Ward WS. DNA organization in patients with a history of cryptorchidism. Urology. Dec. 20. 2000;56(6):1068-70. X-3. [pmid: 11113770].
185 Barqawi AZ, Blyth B, Jordan GH, et al. Role of laparoscopy in patients with previous negative exploration for impalpable testis. Urology. Jun. 2003;61(6):1234-7. discussion 1237. X-3, X-4, X-5, X-6. [pmid: 12809907].
186 Barrio R, De Luis D, Alonso M, et al. Induction of puberty with human chorionic gonadotropin and follicle- stimulating hormone in adolescent males with hypogonadotropic hypogonadism. Fertility and Sterility. Feb. 1999;71(2):244-248. X-2, X-3. [pmid: 9988392].
187 Barros BA, Moraes SG, Coeli FB, et al. OCT4 immunohistochemistry may be necessary to identify the real risk of gonadal tumors in patients with Turner syndrome and y chromosome sequences. Human Reproduction. December. 2011;26(12):3450-3455. X-2, X-3. [pmid: 21930534].
188 Bar-Shira A, Rosner G, Rosner S, et al. Array-based comparative genome hybridization in clinical genetics. Pediatric Research. Sep. 2006;60(3):353-358. X-3. [pmid: 16857771].
189 Barss P, Ennis S. Injuries caused by pigs in Papua New Guinea. Medical Journal of Australia. 1988;149(11–12):649-656. X-2, X-3. [pmid: 3200190].
190 Bartfai Z, Kocsis J, Puho EH, et al. A population-based case-control teratologic study of promethazine use during pregnancy. Reproductive Toxicology. Feb. 2008;25(2):276-285. X-2, X-3. [pmid: 18272326].
191 Bartfai Z, Somoskovi A, Puho EH, et al. No teratogenic effect of prenoxdiazine: A population-based case-control study. Congenital Anomalies. Mar. 2007;47(1):16-21. X-2, X-3. [pmid: 17300686].
192 Barthold JS, Manson J, Regan V, et al. Reproductive hormone levels in infants with cryptorchidism during postnatal activation of the pituitary-testicular axis. J Urol. Oct. 2004;172(4 Pt 2):1736-41. discussion 1741. X-3. [pmid: 15371802].
193 Bartone FF, Schmidt MA. Cryptorchidism: incidence of chromosomal anomalies in 50 cases. J Urol. Jun. 1982;127(6):1105-6. X-2, X-3. [pmid: 6123604].
194 Bartsch G, Frank S, Marberger H, et al. Testicular torsion: late results with special regard to fertility and endocrine function. J Urol. Sep. 1980;124(3):375-8. X-2, X-3. [pmid: 6776291].
195 Basekim CC, Kizilkaya E, Pekkafali Z, et al. Mumps epididymo-orchitis: sonography and color Doppler sonographic findings. Abdom Imaging. May–Jun. 2000;25(3):322-5. X-2, X-3. [pmid: 10823460].
196 Bashamboo A, Rahman MM, Prasad A, et al. Fate of SRY, PABY, DYS1, DYZ3 and DYZ1 loci in Indian patients harbouring sex chromosomal anomalies. Mol Hum Reprod. Feb. 2005;11(2):117-27. X-2, X-3. [pmid: 15579656].
197 Basiri A, Asl-Zare M, Sichani MM, et al. Laparoscopic bilateral retroperitoneal lymph node dissection in stage II testis cancer. Urol J. Summer. 2010;7(3):157-60. X-2, X-3. [pmid: 20845290].
198 Basiri A, Djaladat H, Mohammadi Sichani M, et al. Journal of Endourology. [Conference Abstract]. October. Conference: 27th WCE 2009. Munich Germany. Conference Start: 20091006 Conference End: 20091010. Conference Publication: (var.pagings). 2009;23:A371. X-2, X-3.
199 Bassel YS, Scherz HC, Kirsch AJ. Scrotal incision orchiopexy for undescended testes with or without a patent processus vaginalis. J Urol. Apr. 2007;177(4):1516-8. X-4, X-5, X-6. [pmid: 17382769].
200 Bastida MG, Rey RA, Bergada I, et al. Establishment of testicular endocrine function impairment during childhood and puberty in boys with Klinefelter syndrome. Clinical Endocrinology. Dec. 2007;67(6):863-870. X-2, X-3. [pmid: 17645574].
201 Battaglia A, Chines C, Carey JC. The FG syndrome: report of a large Italian series. Am J Med Genet A. Oct. 1. 2006;140(19):2075-9. X-1, X-2, X-3. [pmid: 16691600].
202 Bayne A, Paduch D, Skoog SJ. Pressure, fluid and anatomical characteristics of abdominoscrotal hydroceles in infants. J Urol. Oct. 2008;180(4 Suppl):1720-3. discussion 1723. X-2, X-3. [pmid: 18708213].
203 Bayne AP, Alonzo DG, Hsieh MH, et al. Impact of anatomical and socioeconomic factors on timing of urological consultation for boys with cryptorchidism. J Urol. Oct. 2011;186(4 Suppl):1601-5. X-4, X-5, X-6. [pmid: 21855921].
204 Bayram MM, Kervancioglu R. Scrotal gray-scale and color Doppler sonographic findings in genitourinary brucellosis. J Clin Ultrasound. Oct. 1997;25(8):443-7. X-2, X-3. [pmid: 9321717].
205 Beard CM, Melton LJ 3rd, O’Fallon WM, et al. Cryptorchism and maternal estrogen exposure. Am J Epidemiol. Nov. 1984;120(5):707-16. X-2, X-3. [pmid: 6149686].
206 Bebars GA, Zaki A, Dawood AR, et al. Laparoscopic versus open high ligation of the testicular veins for the treatment of varicocele. JSLS. Jul–Sep. 2000;4(3):209-13. X-2, X-3. [pmid: 10987396].
207 Beck EM, Schlegel PN, Goldstein M. Intraoperative varicocele anatomy: a macroscopic and microscopic study. J Urol. Oct. 1992;148(4):1190-4. X-2, X-3. [pmid: 1404635].
208 Beck SD, Foster RS, Bihrle R, et al. Is full bilateral retroperitoneal lymph node dissection always necessary for postchemotherapy residual tumor?. Cancer. Sep. 15. 2007;110(6):1235-40. X-2, X-3. [pmid: 17665498].
209 Beck SD, Peterson MD, Bihrle R, et al. Short-term morbidity of primary retroperitoneal lymph node dissection in a contemporary group of patients. J Urol. Aug. 2007;178(2):504-6. discussion 506. X-2, X-3. [pmid: 17561131].
210 Beheshti M, Churchill BM, Mancer JFK. External genital abnormalities associated with Wilms tumor. Urology. 1984;24(2):130-133. X-2, X-3. [pmid: 6147039].
211 Beiglbock A, Pera I, Ellerbrock K, et al. Dog epididymis-specific mRNA encoding secretory glutathione peroxidase-like protein. J Reprod Fertil. Mar. 1998;112(2):357-67. X-2, X-3. [pmid: 9640275].
212 Beiraghi S, Leon-Salazar V, Larson B, et al. Craniofacial and intraoral phenotype of Robinow syndrome forms. Clinical Genetics. July. 2011;80(1):15-24. X-2, X-3. [pmid: 21496006].
213 Bektas H, Bilsel Y, Ersoz F, et al. Comparison of totally extraperitoneal technique and darn plication of primary inguinal hernia. Journal of Laparoendoscopic and Advanced Surgical Techniques. 01. Sep. 2011;21(7):583-588. X-2, X-3. [pmid: 21774699].
214 Belgorosky A, Rivarola MA. Sex hormone binding globulin response to testosterone. An androgen sensitivity test. Acta Endocrinol (Copenh). May. 1985;109(1):130-8. X-2, X-3. [pmid: 2860769].
215 Bellah RD, States LJ, Duckett JW. Pseudoprune-Belly syndrome: imaging findings and clinical outcome. AJR Am J Roentgenol. Dec. 1996;167(6):1389-93. X-2, X-3. [pmid: 8956564].
216 Bellinger MF. The blind-ending vas: the fate of the contralateral testis. J Urol. Apr. 1985;133(4):644-5. X-3, X-4, X-5, X-6. [pmid: 2858596].
217 Belman AB. Acquired undescended (ascended) testis: effects of human chorionic gonadotropin. J Urol. Nov. 1988;140(5 Pt 2):1189-90. X-3, X-4, X-5, X-6. [pmid: 2903257].
218 Belman AB, Rushton HG. Is the vanished testis always a scrotal event?. BJU Int. Apr. 2001;87(6):480-3. X-2, X-3. [pmid: 11298038].
219 Belman AB, Rushton HG. Is an empty left hemiscrotum and hypertrophied right descended testis predictive of perinatal torsion?. J Urol. Oct. 2003;170(4 Pt 2):1674-5. discussion 1675–6. X-2, X-3. [pmid: 14501689].
220 Beltran-Brown F, Villegas-Alvarez F. Clinical classification for undescended testes: experience in 1,010 orchidopexies. J Pediatr Surg. May. 1988;23(5):444-7. X-4, X-5, X-6. [pmid: 2898014].
221 Benacerraf BR, Bromley B. Sonographic finding of undescended testes in fetuses at 35–40 weeks: significance and outcome. J Clin Ultrasound. Feb. 1998;26(2):69-71. X-3. [pmid: 9460633].
222 Benedetto VD, Bagnara V, Guys JM, et al. A transvesical approach to mullerian duct remnants. Pediatr Surg Int. Feb. 1997;12(2–3):151-4. X-2, X-3.
223 Ben-Meir D, Deshpande A, Hutson JM. Re-exploration of the acute scrotum. BJU Int. Feb. 2006;97(2):364-6. X-2, X-3. [pmid: 16430648].
224 Benoff S, Goodwin LO, Millan C, et al. Deletions in L-type calcium channel alpha1 subunit testicular transcripts correlate with testicular cadmium and apoptosis in infertile men with varicoceles. Fertil Steril. Mar. 2005;83(3):622-34. X-2, X-3. [pmid: 15749491].
225 Benoff SH, Millan C, Hurley IR, et al. Bilateral increased apoptosis and bilateral accumulation of cadmium in infertile men with left varicocele. Hum Reprod. Mar. 2004;19(3):616-27. X-2, X-3. [pmid: 14998961].
226 Bercovici JP, Nahoul K, Ducasse M, et al. Leydig cell tumor with gynecomastia: further studies--the recovery after unilateral orchidectomy. J Clin Endocrinol Metab. Nov. 1985;61(5):957-62. X-2, X-3. [pmid: 3930556].
227 Berger AP, Hager J. Management of neonates with large abdominal wall defects and undescended testis. Urology. Jul. 2006;68(1):175-8. X-3, X-4, X-5, X-6. [pmid: 16806430].
228 Bergeron MB, Brochu P, Lemyre E, et al. Correlation of intercentromeric distance, mosaicism, and sexual phenotype: Molecular localization of breakpoints in isodicentric Y chromosomes. American Journal of Medical Genetics, Part A. November. 2011;155(11):2705-2712. X-2, X-3.
229 Bergman JE, Bocca G, Hoefsloot LH, et al. Anosmia predicts hypogonadotropic hypogonadism in CHARGE syndrome. J Pediatr. Mar. 2011;158(3):474-9. X-2, X-3. [pmid: 20884005].
230 Bergmann M, Behre HM, Nieschlag E. Serum FSH and testicular morphology in male infertility. Clin Endocrinol (Oxf). Jan. 1994;40(1):133-6. X-2, X-3. [pmid: 8306472].
231 Berhan Y, Lemma BE, Ergete W, et al. True hermaphrodite: very unusual type. Ethiop Med J. Jul. 2004;42(3):221-8. X-2, X-3. [pmid: 16895042].
232 Berkman WA, Price RB, Wheatley JK, et al. Varicoceles: a coaxial coil occlusion system. Radiology. Apr. 1984;151(1):73-7. X-2, X-3. [pmid: 6701340].
233 Berkmen F. Malignant lymphomas of the testis. Radiology and Oncology. Mar. 2003;37(1):23-27. +57. X-2, X-3.
234 Berkmen F, Alagol H. Germinal cell tumors of the testis in cryptorchids. J Exp Clin Cancer Res. Dec. 1998;17(4):409-12. X-3, X-4, X-5, X-6. [pmid: 10089059].
235 Berkmen F, Peker AF, Basay S, et al. Synchronous and metachronous bilateral germ cell tumours of the testis. Radiology and Oncology. 2000;34(4):363-368. X-2, X-3.
236 Berkowitz GS, Lapinski RH. Risk factors for cryptorchidism: a nested case-control study. Paediatr Perinat Epidemiol. Jan. 1996;10(1):39-51. X-3. [pmid: 8746430].
237 Berkowitz GS, Lapinski RH, Godbold JH, et al. Maternal and neonatal risk factors for cryptorchidism. Epidemiology. Mar. 1995;6(2):127-31. X-3. [pmid: 7742397].
238 Bermudez M, Frank N, Bernal J, et al. High prevalence of CBS p.T191M mutation in homocystinuric patients from Colombia. Hum Mutat. Mar. 2006;27(3):296. X-2, X-3. [pmid: 16470595].
239 Bernal RM, Zaontz MR. Journal of Urology. [Conference Abstract]. April. Conference: 2009 American Urological Association (AUA) Annual Meeting. Chicago, IL United States. Conference Start: 20090425 Conference End: 20090430. Conference Publication: (var.pagings). 2009;181(4 SUPPL 1):118. X-4, X-5, X-6.
240 Bernard J, Yi ES. Pulmonary thromboendarterectomy: a clinicopathologic study of 200 consecutive pulmonary thromboendarterectomy cases in one institution. Hum Pathol. Jun. 2007;38(6):871-7. X-2, X-3. [pmid: 17350667].
241 Bernstein L, Depue RH, Ross RK, et al. Higher maternal levels of free estradiol in first compared to second pregnancy: early gestational differences. J Natl Cancer Inst. Jun. 1986;76(6):1035-9. X-2, X-3. [pmid: 3458941].
242 Bernstein L, Pike MC, Depue RH, et al. Maternal hormone levels in early gestation of cryptorchid males: a case-control study. Br J Cancer. Sep. 1988;58(3):379-81. X-2, X-3. [pmid: 2902875].
243 Bertelsen A, Thorup J, Pedersen PV, et al. Intranasal LH-RH treatment of cryptorchidism. A clinical trial and 5 years follow-up. Eur J Pediatr. Suppl 2. 1987;146:S40-1. X-4, X-5, X-6. [pmid: 2891520].
244 Berthelsen JG. Sperm counts and serum follicle-stimulating hormone levels before and after radiotherapy and chemotherapy in men with testicular germ cell cancer. Fertil Steril. Feb. 1984;41(2):281-6. X-2, X-3. [pmid: 6199233].
245 Berthelsen JG, Engelholm SA, von der Maase H, et al. Serum testosterone, LH, and FSH in patients with testicular cancer before and after radio- and chemotherapy. Scand J Urol Nephrol. 1983;17(3):287-90. X-2, X-3. [pmid: 6316483].
246 Berthelsen JG, Skakkebaek NE. Gonadal function in men with testis cancer. Fertil Steril. Jan. 1983;39(1):68-75. X-2, X-3. [pmid: 6293886].
247 Berthelsen JG, Skakkebaek NE, von der Maase H, et al. Screening for carcinoma in situ of the contralateral testis in patients with germinal testicular cancer. Br Med J (Clin Res Ed). Dec. 11. 1982;285(6356):1683-6. X-2, X-3.
248 Bertini V, Bertelloni S, Valetto A, et al. Homeobox HOXA10 gene analysis in cryptorchidism. J Pediatr Endocrinol Metab. Jan. 2004;17(1):41-5. X-3. [pmid: 14960020].
249 Bettocchi C, Parkinson MC, Ralph DJ, et al. Clinical aspects associated with Sertoli-cell-only histology. Br J Urol. Oct. 1998;82(4):534-7. X-2, X-3. [pmid: 9806183].
250 Bhagavath B, Podolsky RH, Ozata M, et al. Clinical and molecular characterization of a large sample of patients with hypogonadotropic hypogonadism. Fertil Steril. Mar. 2006;85(3):706-13. X-3. [pmid: 16500342].
251 Bhansali A, Walia R, Singh R, et al. Disorders of sex development: A study of ninety-five patients. Endocrinologist. May–June. 2009;19(3):98-101. X-2, X-3.
252 Bhasin SD, Shrikhande SS. Secondary carcinoma of testis--a clinicopathologic study of 10 cases. Indian J Cancer. Jun. 1990;27(2):83-90. X-2, X-3. [pmid: 2228016].
253 Bhatnagar AM, Mohite PN, Suthar M. Fournier’s gangrene: a review of 110 cases for aetiology, predisposing conditions, microorganisms, and modalities for coverage of necrosed scrotum with bare testes. N Z Med J. Jun. 6. 2008;121(1275):46-56. X-1, X-2, X-3. [pmid: 18551153].
254 Bhatti AZ, Rasool MI. Darning vs Bassini repair in primary unilateral inguinal hernia. Medical Forum Monthly. 01. Jun. 2002;13(6):23-25. X-2, X-3.
255 Bianchi A. Microvascular orchiopexy for high undescended testes. Br J Urol. Oct. 1984;56(5):521-4. X-3, X-4, X-5, X-6. [pmid: 6152545].
256 Bianchi G, Beltrami P, Giusti G, et al. Unilateral laparoscopic retroperitoneal lymph node dissection for clinical stage I nonseminomatous germ cell testicular neoplasm. Eur Urol. 1998;33(2):190-4. X-2, X-3. [pmid: 9519363].
257 Bierich JR. Undescended testes: treatment with gonadotropin. Eur J Pediatr. Dec. 1982;139(4):275-9. X-1. [pmid: 6133755].
258 Biermann K, Goke F, Nettersheim D, et al. c-KIT is frequently mutated in bilateral germ cell tumours and down-regulated during progression from intratubular germ cell neoplasia to seminoma. J Pathol. Nov. 2007;213(3):311-8. X-2, X-3. [pmid: 17768701].
259 Biggs ML, Baer A, Critchlow CW. Maternal, delivery, and perinatal characteristics associated with cryptorchidism: a population-based case-control study among births in Washington State. Epidemiology. Mar. 2002;13(2):197-204. X-3. [pmid: 11880761].
260 Bigliardi E, Vegni-Talluri M. Electron microscopic study of interstitial cells in cryptorchid human testes. I: Interstitial cells in prepubertal age. Andrologia. May–Jun. 1982;14(3):276-83. X-2, X-3. [pmid: 6126142].
261 Bigot JM, Le Blanche AF, Carette MF, et al. Anastomoses between the spermatic and visceral veins: a retrospective study of 500 consecutive patients. Abdom Imaging. Mar–Apr. 1997;22(2):226-32. X-2, X-3. [pmid: 9013539].
262 Bilinska B, Kotula-Balak M, Sadowska J. Morphology and function of human Leydig cells in vitro. Immunocytochemical and radioimmunological analyses. Eur J Histochem. Jan–Mar. 2009;53(1):35-42. X-2, X-3. [pmid: 19351611].
263 Billingsley G, Bin J, Fieggen KJ, et al. Mutations in chaperonin-like BBS genes are a major contributor to disease development in a multiethnic Bardet-Biedl syndrome patient population. J Med Genet. Jul. 2010;47(7):453-63. X-2, X-3. [pmid: 20472660].
264 Binder G, Martin DD, Kanther I, et al. The course of neonatal cholestasis in congenital combined pituitary hormone deficiency. J Pediatr Endocrinol Metab. Jun. 2007;20(6):695-702. X-2, X-3. [pmid: 17663294].
265 Binder G, Neuer K, Ranke MB, et al. PTPN11 mutations are associated with mild growth hormone resistance in individuals with Noonan syndrome. J Clin Endocrinol Metab. Sep. 2005;90(9):5377-81. X-2, X-3. [pmid: 15985475].
266 Bingol-Kologlu M, Demirci M, Buyukpamukcu N, et al. Cremasteric reflexes of boys with descended, retractile, or undescended testes: an electrophysiological evaluation. J Pediatr Surg. Mar. 1999;34(3):430-4. X-3. [pmid: 10211648].
267 Bingol-Kologlu M, Sara Y, Tanyel FC, et al. Contractility and electrophysiological parameters of cremaster muscles of boys with a hernia or undescended testis. J Pediatr Surg. Oct. 1998;33(10):1490-4. X-2, X-3. [pmid: 9802798].
268 Bingol-Kologlu M, Tanyel FC, Akcoren Z, et al. A comparative histopathologic and immunohistopathologic evaluation of cremaster muscles from boys with various inguinoscrotal pathologies. Eur J Pediatr Surg. Apr. 2001;11(2):110-5. X-2, X-3. [pmid: 11371030].
269 Bingol-Kologlu M, Tanyel FC, Anlar B, et al. Cremasteric reflex and retraction of a testis. J Pediatr Surg. Jun. 2001;36(6):863-7. X-2, X-3. [pmid: 11381413].
270 Bird DJ, Seiler MW. Annulate lamellae and single-pore complexes in human spermatogonia. J Submicrosc Cytol. Oct. 1986;18(4):823-8. X-2, X-3. [pmid: 2878089].
271 Bissada NK, el Senoussi M, Hanash KA, et al. Testicular seminomas in Saudi Arabia: clinical characteristics, prognostic indicators, and recommendations for management. J Surg Oncol. Oct. 1986;33(2):136-9. X-2, X-3. [pmid: 2876131].
272 Bjoro K Jr, Dybvik T. Congenital abnormalities and growth patterns among cryptorchidic boys. Ann Chir Gynaecol. 1983;72(6):342-6. X-3, X-4, X-5, X-6. [pmid: 6141761].
273 Blatt J, Sherins RJ, Niebrugge D, et al. Leydig cell function in boys following treatment for testicular relapse of acute lymphoblastic leukemia. J Clin Oncol. Sep. 1985;3(9):1227-31. X-2, X-3. [pmid: 3928829].
274 Blau H, Freud E, Mussaffi H, et al. Urogenital abnormalities in male children with cystic fibrosis. Arch Dis Child. Aug. 2002;87(2):135-8. X-2, X-3. [pmid: 12138064].
275 Bloom DA. Two-step orchiopexy with pelviscopic clip ligation of the spermatic vessels. J Urol. May. 1991;145(5):1030-3. X-4, X-5, X-6. [pmid: 1673160].
276 Blumenfeld Z, Kerner H, Makler A, et al. Clinical, endocrine and ultrastructural study of XY gonadal dysgenesis. A case report. J Reprod Med. Mar. 1985;30(3):211-6. X-2, X-3. [pmid: 2987496].
277 Bockers TM, Nieschlag E, Kreutz MR, et al. Localization of follicle-stimulating hormone (FSH) immunoreactivity and hormone receptor mRNA in testicular tissue of infertile men. Cell Tissue Res. Dec. 1994;278(3):595-600. X-1, X-2, X-3. [pmid: 7850869].
278 Boeckx W, Vereecken R, Depuydt K. Microsurgery for intra-abdominal testicular retention. European Journal of Obstetrics Gynecology and Reproductive Biology. 01. Dec. 1998;81(2):191-196. X-4, X-5, X-6.
279 Bogatcheva NV, Ferlin A, Feng S, et al. T222P mutation of the insulin-like 3 hormone receptor LGR8 is associated with testicular maldescent and hinders receptor expression on the cell surface membrane. Am J Physiol Endocrinol Metab. Jan. 2007;292(1):E138-44. X-2, X-3. [pmid: 16926383].
280 Boggis AR, Rowlatt RJ. A study of the sources of delay in the diagnosis and treatment of undescended testicle. J R Coll Gen Pract. Aug. 1984;34(265):440-1. X-2, X-3. [pmid: 6147410].
281 Boguszewski MCS, Mericq V, Bergada I, et al. Latin American Consensus: Children Born Small for Gestational Age. BMC Pediatrics. 19. Jul. 2011;11(66). X-2, X-3.
282 Bohring C, Krause W. Serum levels of inhibin B in men with different causes of spermatogenic failure. Andrologia. May. 1999;31(3):137-41. X-2, X-3. [pmid: 10363117].
283 Boisen KA, Chellakooty M, Schmidt IM, et al. Hypospadias in a cohort of 1072 Danish newborn boys: prevalence and relationship to placental weight, anthropometrical measurements at birth, and reproductive hormone levels at three months of age. J Clin Endocrinol Metab. Jul. 2005;90(7):4041-6. X-2, X-3. [pmid: 15870122].
284 Boisen KA, Kaleva M, Main KM, et al. Difference in prevalence of congenital cryptorchidism in infants between two Nordic countries. Lancet. Apr. 17. 2004;363(9417):1264-9. X-3. [pmid: 15094270].
285 Bokemeyer C, Berger CC, Hartmann JT, et al. Analysis of risk factors for cisplatin-induced ototoxicity in patients with testicular cancer. Br J Cancer. Apr. 1998;77(8):1355-62. X-2, X-3. [pmid: 9579846].
286 Bokemeyer C, Frank B, Schoffski P, et al. Phantom sensations after orchiectomy for testicular cancer. International Journal of Oncology. 1993;2(4):633-636. X-2, X-3. [pmid: 21573603].
287 Bokemeyer C, Schmoll HJ, Schoffski P, et al. Bilateral testicular tumours: prevalence and clinical implications. Eur J Cancer. 1993;29A(6):874-6. X-2, X-3. [pmid: 8387319].
288 Bonduelle M, Legein J, Derde MP, et al. Comparative follow-up study of 130 children born after intracytoplasmic sperm injection and 130 children born after in-vitro fertilization. Hum Reprod. Dec. 1995;10(12):3327-31. X-2, X-3. [pmid: 8822470].
289 Bonner MR, McCann SE, Moysich KB. Dietary factors and the risk of testicular cancer. Nutr Cancer. 2002;44(1):35-43. X-2, X-3. [pmid: 12672639].
290 Bonney T, Hutson J, Southwell B, et al. Update on congenital versus acquired undescended testes: incidence, diagnosis and management. ANZ J Surg. Nov. 2008;78(11):1010-3. X-1. [pmid: 18959703].
291 Bonney T, Southwell B, Donnath S, et al. Orchidopexy trends in the paediatric population of Victoria, 1999–2006. J Pediatr Surg. Feb. 2009;44(2):427-31. X-4, X-5, X-6. [pmid: 19231549].
292 Bono AV, Roggia A. The anti-inflammatory action of flurbiprofen suppositories in paediatric urology in comparison with co-trimoxazole. J Int Med Res. 1984;12(2):128-31. X-4, X-5, X-6. [pmid: 6144602].
293 Booth WD, Baldwin BA. Lack of effect on sexual behaviour or the development of testicular function after removal of olfactory bulbs in prepubertal boars. J Reprod Fertil. Jan. 1980;58(1):173-82. X-2, X-3. [pmid: 7188969].
294 Bor P, Hindkjaer J, Kolvraa S, et al. Screening for Y microdeletions in men with testicular cancer and undescended testis. J Assist Reprod Genet. Jan. 2006;23(1):41-5. X-2, X-3. [pmid: 16550456].
295 Borer JG, Nitti VW, Glassberg KI. Mixed gonadal dysgenesis and dysgenetic male pseudohermaphroditism. J Urol. Apr. 1995;153(4):1267-73. X-2, X-3. [pmid: 7869527].
296 Bosenberg AT, Ratcliffe S. The respiratory effects of tramadol in children under halothane an anaesthesia. Anaesthesia. Oct. 1998;53(10):960-4. X-2, X-3. [pmid: 9893539].
297 Bosl GJ, Geller N, Cirrincione C, et al. Interrelationships of histopathology and other clinical variables in patients with germ cell tumors of the testis. Cancer. Jun. 1. 1983;51(11):2121-5. X-2, X-3. [pmid: 6188528].
298 Bouloux P, Warne DW, Loumaye E. Efficacy and safety of recombinant human follicle-stimulating hormone in men with isolated hypogonadotropic hypogonadism. Fertility and Sterility. 2002;77(2):270-273. X-2, X-3. [pmid: 11821082].
299 Bouloux PMG, Nieschlag E, Burger HG, et al. Induction of Spermatogenesis by Recombinant Follicle-Stimulating Hormone (Puregon) in Hypogonadotropic Azoospermic Men Who Failed to Respond to Human Chorionic Gonadotropin Alone. Journal of Andrology. Jul. 2003;24(4):604-611. X-2, X-3. [pmid: 12826700].
300 Bouvattier C, Mignot B, Lefevre H, et al. Impaired sexual activity in male adults with partial androgen insensitivity. Journal of Clinical Endocrinology and Metabolism. 2006;91(9):3310-3315. X-2, X-3. [pmid: 16757528].
301 Bouvattier C, Tauber M, Jouret B, et al. Gonadotropin treatment of hypogonadotropic hypogonadal adolescents. J Pediatr Endocrinol Metab. Apr. 1999;12(Suppl 1):339-44. X-2, X-3. [pmid: 10698599].
302 Boyd HA, Myrup C, Wohlfahrt J, et al. Maternal serum alpha-fetoprotein level during pregnancy and isolated cryptorchidism in male offspring. Am J Epidemiol. Sep. 1. 2006;164(5):478-86. X-3. [pmid: 16790515].
303 Boyle KE, Thomas AJ Jr, Marmar JL, et al. Sperm harvesting and cryopreservation during vasectomy reversal is not cost effective. Fertil Steril. Apr. 2006;85(4):961-4. X-2, X-3. [pmid: 16580381].
304 Bozlu M, Coskun B, Cayan S, et al. Inhibition of poly(adenosine diphosphate-ribose) polymerase decreases long-term histologic damage in testicular ischemia-reperfusion injury. Urology. Apr. 2004;63(4):791-5. X-2, X-3. [pmid: 15072913].
305 Brabrand S, Fossa SD, Cvancarova M, et al. Androgen substitution with testosterone undecanoate in survivors of bilateral testicular cancer requires individually-adjusted injection intervals. BJU International. April. 2011;107(7):1080-1087. X-2, X-3. [pmid: 20825398].
306 Bracken RB, Johnson DE, Frazier OH. The role of surgery following chemotherapy in stage III germ cell naoplasms. Journal of Urology. 1983;129(1):39-43. X-2, X-3. [pmid: 6298475].
307 Bracken RB, Smith KD. Is semen cryopreservation helpful in testicular cancer?. Urology. Jun. 1980;15(6):581-3. X-2, X-3. [pmid: 7394985].
308 Braga LH, Lorenzo AJ, Pippi Salle JL, et al. Patency of the “third inguinal ring” in children with unilateral cryptorchidism: fact or fiction?. Eur J Pediatr Surg. Aug. 2008;18(4):237-40. X-4, X-5, X-6. [pmid: 18704894].
309 Bramwell RG, Bullen C, Radford P. Caudal block for postoperative analgesia in children. Anaesthesia. Oct. 1982;37(10):1024-8. X-2, X-3. [pmid: 6127970].
310 Brancati F, D’Avanzo MG, Digilio MC, et al. KBG syndrome in a cohort of Italian patients. American Journal of Medical Genetics. 01. Dec. 2004;131 A(2):144-149. X-2, X-3. [pmid: 15523620].
311 Branscheid D, Krysa S, Wollkopf G, et al. Does ND-YAG laser extend the indications for resection of pulmonary metastases?. Eur J Cardiothorac Surg. 1992;6(11):590-6. discussion 597. X-2, X-3. [pmid: 1280452].
312 Braun MM, Caporaso NE, Page WF, et al. Prevalence of a history of testicular cancer in a cohort of elderly twins. Acta Genet Med Gemellol (Roma). 1995;44(3–4):189-92. X-2. [pmid: 8739730].
313 Brauner R, Caltabiano P, Rappaport R, et al. Leydig cell insufficiency after testicular irradiation for acute lymphoblastic leukemia. Horm Res. 1988;30(2–3):111-4. X-2, X-3. [pmid: 3248774].
314 Brauner R, Neve M, Allali S, et al. Clinical, biological and genetic analysis of anorchia in 26 boys. PLoS ONE. 2011;6(8):e23292. X-2, X-3. [pmid: 21853106].
315 Braunstein J, Afshar K, MacNeily AE. Cryptorchidism: the veracity of online information accessible to the public. J Pediatr Surg. Oct. 2007;42(10):1745-8. X-2, X-3. [pmid: 17923207].
316 Bredael JJ, Vugrin D, Whitmore WF Jr. Selected experience with surgery and combination chemotherapy in the treatment of nonseminomatous testis tumors. J Urol. May. 1983;129(5):985-8. X-2, X-3. [pmid: 6854776].
317 Breman AM, Ramocki MB, Kang SHL, et al. MECP2 duplications in six patients with complex sex chromosome rearrangements. European Journal of Human Genetics. April. 2011;19(4):409-415. X-2, X-3. [pmid: 21119712].
318 Bremholm Rasmussen T, Ingerslev HJ, Hostrup H. Bilateral spontaneous descent of the testis after the age of 10: subsequent effects on fertility. Br J Surg. Aug. 1988;75(8):820-3. X-2, X-3. [pmid: 2901893].
319 Bren A, Kandus A. Our experience with epoetins in treating renal anemia. Ther Apher Dial. Jun. 2005;9(3):202-4. X-1, X-2, X-3. [pmid: 15966988].
320 Brennemann W, Brensing KA, Leipner N, et al. Attempted protection of spermatogenesis from irradiation in patients with seminoma by D-Tryptophan-6 luteinizing hormone releasing hormone. Clin Investig. Nov. 1994;72(11):838-42. X-2, X-3.
321 Brennemann W, Stoffel-Wagner B, Helmers A, et al. Gonadal function of patients treated with cisplatin based chemotherapy for germ cell cancer. J Urol. Sep. 1997;158(3 Pt 1):844-50. X-2, X-3. [pmid: 9258096].
322 Brennemann W, Stoffel-Wagner B, Wichers M, et al. Pretreatment follicle-stimulating hormone: a prognostic serum marker of spermatogenesis status in patients treated for germ cell cancer. J Urol. Jun. 1998;159(6):1942-6. X-2, X-3. [pmid: 9598493].
323 Breslow NE, Beckwith JB. Epidemiological features of Wilms’ tumor: results of the National Wilms’ Tumor Study. J Natl Cancer Inst. Mar. 1982;68(3):429-36. X-2, X-3. [pmid: 6278194].
324 Breslow NE, Collins AJ, Ritchey ML, et al. End stage renal disease in patients with Wilms tumor: results from the National Wilms Tumor Study Group and the United States Renal Data System. J Urol. Nov. 2005;174(5):1972-5. X-2, X-3. [pmid: 16217371].
325 Breyer BN, DiSandro M, Baskin LS, et al. Obesity does not decrease the accuracy of testicular examination in anesthetized boys with cryptorchidism. J Urol. Feb. 2009;181(2):830-4. X-3, X-4, X-5, X-6. [pmid: 19095266].
326 Briggs TP, Anson KM, Jones A, et al. Urological day case surgery in elderly and medically unfit patients using sedoanalgesia: What are the limits?. British Journal of Urology. 1995;75(6):708-711. X-2, X-3. [pmid: 7613824].
327 Brodie A, Inkster S, Yue W. Aromatase expression in the human male. Mol Cell Endocrinol. Jun. 10. 2001;178(1–2):23-8. X-2, X-3. [pmid: 11403890].
328 Brook NR, Harper SJ, Waller JR, et al. A consecutive series of 70 laparoscopic donor nephrectomies demonstrates the safety of this new operation. Transplant Proc. Mar. 2005;37(2):627-8. X-2, X-3. [pmid: 15848479].
329 Brown DL, Benson CB, Doherty FJ, et al. Cystic testicular mass caused by dilated rete testis: sonographic findings in 31 cases. AJR Am J Roentgenol. Jun. 1992;158(6):1257-9. X-2, X-3. [pmid: 1590118].
330 Brown JJ, Wacogne I, Fleckney S, et al. Achieving early surgery for undescended testes: quality improvement through a multifaceted approach to guideline implementation. Child Care Health Dev. Mar. 2004;30(2):97-102. X-4, X-5, X-6. [pmid: 14961862].
331 Brown JM, Hammers LW, Barton JW, et al. Quantitative Doppler assessment of acute scrotal inflammation. Radiology. Nov. 1995;197(2):427-31. X-2, X-3. [pmid: 7480687].
332 Brown LM, Pottern LM, Hoover RN. Testicular cancer in young men: the search for causes of the epidemic increase in the United States. J Epidemiol Community Health. Dec. 1987;41(4):349-54. X-2, X-3. [pmid: 2901454].
333 Brugnon F, Janny L, Artonne C, et al. Activated caspases in thawed epididymal and testicular spermatozoa of patients with congenital bilateral absence of the vas deferens and intracytoplasmic sperm injection outcome. Fertil Steril. Aug. 2009;92(2):557-64. X-2, X-3. [pmid: 18774565].
334 Bruijnen CJ, Vogels HD, Beasley SW. Review of the extent to which orchidopexy is performed at the optimal age: implications for health services. ANZ J Surg. Nov. 2008;78(11):1006-9. X-4, X-5, X-6. [pmid: 18959702].
335 Bruning G, Dierichs R, Stumpel C, et al. Sertoli cell nuclear changes in human testicular biopsies as revealed by three dimensional reconstruction. Andrologia. Nov–Dec. 1993;25(6):311-6. X-2, X-3. [pmid: 7904133].
336 Bruun E, Frimodt-Moller C, Giwercman A, et al. Testicular biopsy as an outpatient procedure in screening for carcinoma-in-situ: complications and the patient’s acceptance. Int J Androl. Feb. 1987;10(1):199-202. X-2, X-3. [pmid: 2884186].
337 Brydoy M, Fossa SD, Klepp O, et al. Paternity following treatment for testicular cancer. J Natl Cancer Inst. Nov. 2. 2005;97(21):1580-8. X-2, X-3. [pmid: 16264178].
338 Brydoy M, Fossa SD, Klepp O, et al. Paternity and testicular function among testicular cancer survivors treated with two to four cycles of cisplatin-based chemotherapy. Eur Urol. Jul. 2010;58(1):134-40. X-2, X-3. [pmid: 20395037].
339 Brydoy M, Oldenburg J, Klepp O, et al. Observational study of prevalence of long-term Raynaud-like phenomena and neurological side effects in testicular cancer survivors. J Natl Cancer Inst. Dec. 16. 2009;101(24):1682-95. X-2, X-3. [pmid: 19940282].
340 Buch B, Galan JJ, Lara M, et al. Absence of de novo Y-chromosome microdeletions in male children conceived through intracytoplasmic sperm injection. Fertil Steril. Dec. 2004;82(6):1679-80. X-2, X-3. [pmid: 15589879].
341 Buchanan GR, Boyett JM, Pollock BH, et al. Improved treatment results in boys with overt testicular relapse during or shortly after initial therapy for acute lymphoblastic leukemia. A Pediatric Oncology group study. Cancer. Jul. 1. 1991;68(1):48-55. X-2, X-3. [pmid: 2049752].
342 Buchholz NP, Biyabani R, Herzig MJU, et al. Persistent mullerian duct syndrome. European Urology. 1998;34(3):230-232. X-2, X-3. [pmid: 9732199].
343 Buchter D, Behre HM, Kliesch S, et al. Pulsatile GnRH or human chorionic gonadotropin/human menopausal gonadotropin as effective treatment for men with hypogonadotropic hypogonadism: a review of 42 cases. Eur J Endocrinol. Sep. 1998;139(3):298-303. X-2, X-3. [pmid: 9758439].
344 Buckett WM, Chian RC, Holzer H, et al. Obstetric outcomes and congenital abnormalities after in vitro maturation, in vitro fertilization, and intracytoplasmic sperm injection. Obstetrics and Gynecology. Oct. 2007;110(4):885-891. X-3. [pmid: 17906024].
345 Buffat C, Patrat C, Merlet F, et al. ICSI outcomes in obstructive azoospermia: influence of the origin of surgically retrieved spermatozoa and the cause of obstruction. Hum Reprod. Apr. 2006;21(4):1018-24. X-2, X-3. [pmid: 16361290].
346 Bujan L, Mieusset R, Mansat A, et al. Testicular size in infertile men: relationship to semen characteristics and hormonal blood levels. Br J Urol. Dec. 1989;64(6):632-7. X-2, X-3. [pmid: 2516757].
347 Bujons A, Sfulcini JC, Pascual M, et al. Prepubertal testicular tumours and efficacy of testicular preserving surgery. BJU Int. Jun. 2011;107(11):1812-6. X-2, X-3. [pmid: 21040368].
348 Bukowski TP, Wacksman J, Billmire DA, et al. Testicular autotransplantation: A 17-year review of an effective approach to the management of the intra-abdominal testis. Journal of Urology. 1995;154(21):558-561. X-4, X-5, X-6. [pmid: 7609136].
349 Bukowski TP, Wacksman J, Billmire DA, et al. Testicular autotransplantation for the intra-abdominal testis. Microsurgery. 1995;16(5):290-5. X-4, X-5, X-6. [pmid: 7565018].
350 Bunin GR, Felice MA, Davidson W, et al. Medical radiation exposure and risk of retinoblastoma resulting from new germline RB1 mutation. International Journal of Cancer. 01. May. 2011;128(10):2393-2404. X-2, X-3.
351 Burgu B, Aydogdu O, Huang R, et al. Journal of Urology. [Conference Abstract]. April. Conference: 2011 Annual Meeting of the American Urological Association, AUA. Washington DC United States. Conference Start: 20110514 Conference End: 20110519. Conference Publication: (var.pagings). 2011;185(4 SUPPL 1):e228. X-3.
352 Burjonrappa SC, Al Hazmi H, Barrieras D, et al. Laparoscopic orchidopexy: the easy way to go. J Pediatr Surg. Nov. 2009;44(11):2168-72. X-4, X-5, X-6. [pmid: 19944228].
353 Burkardt DD, Rosenfeld JA, Helgeson ML, et al. Distinctive phenotype in 9 patients with deletion of chromosome 1q24-q25. American Journal of Medical Genetics, Part A. June. 2011;155(6):1336-1351. X-2, X-3. [pmid: 21548129].
354 Burke AP, Mostofi FK. Intratubular malignant germ cells in testicular biopsies: clinical course and identification by staining for placental alkaline phosphatase. Mod Pathol. Nov. 1988;1(6):475-9. X-2, X-3. [pmid: 2851788].
355 Burton BK, Schulz CJ, Burd LI. Limb anomalies associated with chorionic villus sampling. Obstet Gynecol. May. 1992;79(5 ( Pt 1)):726-30. X-2, X-3. [pmid: 1565357].
356 Busoni P, Crescioli M, Agostino R, et al. Vomiting and common paediatric surgery. Paediatr Anaesth. 2000;10(6):639-43. X-2, X-3. [pmid: 11119197].
357 Bussen S, Sutterlin M, Steck T, et al. Semen parameters in patients with unilateral testicular cancer compared to patients with other malignancies. Arch Gynecol Obstet. Mar. 2004;269(3):196-8. X-2, X-3. [pmid: 12898144].
358 Butler JV, Whittington JE, Holland AJ, et al. Prevalence of, and risk factors for, physical ill-health in people with Prader-Willi syndrome: A population-based study. Developmental Medicine and Child Neurology. 2002;44(4):248-255. X-2, X-3. [pmid: 11995893].
359 Butler MG. Prader-willi syndrome: Obesity due to genomic imprinting. Current Genomics. 2011;12(3):204-215. X-2, X-3. [pmid: 22043168].
360 Butler MG, Thompson T. Prader-Willi syndrome clinical and genetic findings. Endocrinologist. 2000;10(4 SUPPL 1):3S-16S. X-1, X-2, X-3.
361 Byrd W, Bennett MJ, Carr BR, et al. Regulation of biologically active dimeric inhibin A and B from infancy to adulthood in the male. J Clin Endocrinol Metab. Aug. 1998;83(8):2849-54. X-2, X-3. [pmid: 9709958].
362 Caesar RE, Kaplan GW. Incidence of the bell-clapper deformity in an autopsy series. Urology. Jul. 1994;44(1):114-6. X-2, X-3. [pmid: 7913779].
363 Caesar RE, Kaplan GW. The incidence of the cremasteric reflex in normal boys. J Urol. Aug. 1994;152(2 Pt 2):779-80. X-2, X-3. [pmid: 7912745].
364 Cai LQ, Fratianni CM, Gautier T, et al. Dihydrotestosterone regulation of semen in male pseudohermaphrodites with 5 alpha-reductase-2 deficiency. J Clin Endocrinol Metab. Aug. 1994;79(2):409-14. X-2, X-3. [pmid: 8045956].
365 Cai Y, Zhang XC, Chen HQ, et al. Differentiation of murine embryonic stem cells into hematopoietic stem cells induced by stromal cells in human aorta-gonad-mesonephros region and hematopoietic reconstitution in vivo. Journal of Clinical Rehabilitative Tissue Engineering Research. September. 2011;15(36):6776-6780. X-2, X-3.
366 Cakan M, Altug U. Induction of spermatogenesis by inguinal varicocele repair in azoospermic men. Arch Androl. May–Jun. 2004;50(3):145-50. X-2, X-3. [pmid: 15204679].
367 Caldamone AA, Al-Juburi A, Cockett AT. The varicocele: elevated serotonin and infertility. J Urol. May. 1980;123(5):683-5. X-2, X-3. [pmid: 7420556].
368 Caldamone AA, Amaral JF. Laparoscopic stage 2 Fowler-Stephens orchiopexy. Journal of Urology. 1994;152(4):1253-1256. X-4, X-5, X-6. [pmid: 7915337].
369 Caldamone AA, Rabinowitz R. Outpatient orchiopexy. J Urol. Feb. 1982;127(2):286-8. X-4, X-5, X-6. [pmid: 6121059].
370 Calestroupat JP, Sanchez-Salas R, Cathelineau X, et al. Postchemotherapy laparoscopic retroperitoneal lymph node dissection in nonseminomatous germ-cell tumor. J Endourol. Apr. 2009;23(4):645-50. X-2, X-3. [pmid: 19335332].
371 Calleary JG, Masood J, Hill JT. Chronic epididymitis: is epididymectomy a valid surgical treatment?. Int J Androl. Oct. 2009;32(5):468-72. X-2, X-3. [pmid: 18380787].
372 Callery CD, Holmes EC, Vernon S, et al. Resection of pulmonary metastases from nonseminomatous testicular tumors. Correlation of clinical and histological features with treatment outcome. Cancer. Mar. 15. 1983;51(6):1152-8. X-2, X-3. [pmid: 6821870].
373 Callewaert PR, Rahnama’i MS, Biallosterski BT, et al. Scrotal approach to both palpable and impalpable undescended testes: should it become our first choice?. Urology. Jul. 2010;76(1):73-6. X-4, X-5, X-6. [pmid: 20156655].
374 Callewaert PRH, Van Kerrebroeck P. New insights into perinatal testicular torsion. European Journal of Pediatrics. June. 2010;169(6):705-712. X-2, X-3. [pmid: 19856186].
375 Campagnola S, Fasoli L, Flessati P, et al. Vas deferens anomalies in paediatric age. Minerva Pediatr. Jul–Aug. 1999;51(7–8):265-9. X-2, X-3. [pmid: 10634059].
376 Canale D, Bartelloni M, Negroni A, et al. Zinc in human semen. Int J Androl. Dec. 1986;9(6):477-80. X-2, X-3. [pmid: 3570537].
377 Canales BK, Zapzalka DM, Ercole CJ, et al. Prevalence and effect of varicoceles in an elderly population. Urology. Sep. 2005;66(3):627-631. X-2, X-3. [pmid: 16140091].
378 Canavese F, Lala R, Valfre L, et al. Effectiveness of primary inguinal orchiopexy as treatment of non-palpable testes in the first two years of age. Minerva Pediatr. Jun. 2010;62(3):245-8. X-4, X-5, X-6. [pmid: 20467375].
379 Cantwell BMJ, Mannix KA, Harris AL. Back pain - A presentation of metastatic testicular germ cell tumours. Lancet. 1987;1(8527):262-264. X-2, X-3. [pmid: 2880077].
380 Cap J, Foltinova A, Misikova Z. Prognostic significance of testicular relapse in boys with acute lymphoblastic leukemia. Neoplasma. 1992;39(2):115-8. X-2, X-3. [pmid: 1528308].
381 Capello SA, Giorgi LJ Jr, Kogan BA. Orchiopexy practice patterns in New York State from 1984 to 2002. J Urol. Sep. 2006;176(3):1180-3. X-4, X-5, X-6. [pmid: 16890721].
382 Caraway NP, Fanning CV, Amato RJ, et al. Fine-needle aspiration cytology of seminoma: a review of 16 cases. Diagn Cytopathol. Jun. 1995;12(4):327-33. X-2, X-3. [pmid: 7544720].
383 Carbone DJ Jr, Shah A, Thomas AJ Jr, et al. Partial obstruction, not antisperm antibodies, causing infertility after vasovasostomy. J Urol. Mar. 1998;159(3):827-30. X-2, X-3. [pmid: 9474160].
384 Carbone P, Giordano F, Nori F, et al. The possible role of endocrine disrupting chemicals in the aetiology of cryptorchidism and hypospadias: A population-based case-control study in rural Sicily. International Journal of Andrology. Feb. 2007;30(1):3-13. X-3. [pmid: 16824044].
385 Carcavilla A, Alonso M, Ezquieta B, et al. An XX male with an intratubular undifferentiated germ cell neoplasia. Fertil Steril. Nov. 2008;90(5):2005 e3-5. X-2, X-3. [pmid: 18701099].
386 Carizza C, Antiba A, Palazzi J, et al. Testicular maldescent and infertility. Andrologia. May–Jun. 1990;22(3):285-8. X-2. [pmid: 1978611].
387 Carlsen E, Giwercman A, Keiding N, et al. Declining semen quality and increasing incidence of testicular cancer: is there a common cause?. Environ Health Perspect. Oct. 1995;103(Suppl 7):137-9. X-1, X-2, X-3. [pmid: 8593860].
388 Carmignani L, Colombo R, Gadda F, et al. Conservative surgical therapy for leydig cell tumor. J Urol. Aug. 2007;178(2):507-11. discussion 511. X-2, X-3. [pmid: 17561156].
389 Carmignani L, Gadda F, Gazzano G, et al. High incidence of benign testicular neoplasms diagnosed by ultrasound. J Urol. Nov. 2003;170(5):1783-6. X-2, X-3. [pmid: 14532776].
390 Carmignani L, Gadda F, Mancini M, et al. Detection of testicular ultrasonographic lesions in severe male infertility. J Urol. Sep. 2004;172(3):1045-7. X-2, X-3. [pmid: 15311034].
391 Carmignani L, Morabito A, Gadda F, et al. Prognostic parameters in adult impalpable ultrasonographic lesions of the testicle. Journal of Urology. Sep. 2005;174(3):1035-1038. X-1, X-2. [pmid: 16094042].
392 Carmignani L, Salvioni R, Gadda F, et al. Long-term followup and clinical characteristics of testicular Leydig cell tumor: experience with 24 cases. J Urol. Nov. 2006;176(5):2040-3. discussion 2043. X-2, X-3. [pmid: 17070249].
393 Carney JA, Gordon H, Carpenter PC. The complex of myxomas, spotty pigmentation, and endocrine overactivity. Medicine. 1985;64(4):270-283. X-2, X-3. [pmid: 4010501].
394 Caron P, Chauvin S, Christin-Maitre S, et al. Resistance of hypogonadic patients with mutated GnRH receptor genes to pulsatile GnRH administration. J Clin Endocrinol Metab. Mar. 1999;84(3):990-6. X-2, X-3. [pmid: 10084584].
395 Carreno J, Rivas A, Granada A, et al. Exposure of young men to organochlorine pesticides in Southern Spain. Environ Res. Jan. 2007;103(1):55-61. X-2, X-3. [pmid: 16889768].
396 Carrillo A, Gershbein A, Glassberg KI, et al. Serum inhibin B levels and the response to gonadotropin stimulation test in pubertal boys with varicocele. J Urol. Sep. 1999;162(3 Pt 1):875-7. X-2, X-3. [pmid: 10458399].
397 Carruthers M. The paradox dividing testosterone deficiency symptoms and androgen assays: A closer look at the cellular and molecular mechanisms of androgen action. Journal of Sexual Medicine. Apr. 2008;5(4):998-1012. X-1, X-2, X-3. [pmid: 18221290].
398 Caruso AP, Walsh RA, Wolach JW, et al. Single scrotal incision orchiopexy for the palpable undescended testicle. J Urol. Jul. 2000;164(1):156-8. discussion 158–9. X-4, X-5, X-6. [pmid: 10840452].
399 Carver BS, Shayegan B, Eggener S, et al. Incidence of metastatic nonseminomatous germ cell tumor outside the boundaries of a modified postchemotherapy retroperitoneal lymph node dissection. J Clin Oncol. Oct. 1. 2007;25(28):4365-9. X-2, X-3. [pmid: 17906201].
400 Casalino DD, Kim R. Clinical importance of a unilateral striated pattern seen on sonography of the testicle. AJR Am J Roentgenol. Apr. 2002;178(4):927-30. X-2, X-3. [pmid: 11906874].
401 Casals T, Bassas L, Egozcue S, et al. Heterogeneity for mutations in the CFTR gene and clinical correlations in patients with congenital absence of the vas deferens. Hum Reprod. Jul. 2000;15(7):1476-83. X-2, X-3. [pmid: 10875853].
402 Casey RG, Aktar M, Hegarty P, et al. A prospective 10 year audit of a single Irish centre’s experience of retroperitoneal lymph node dissection for metastatic testis cancer. Surgeon. Oct. 2008;6(5):294-6. X-2, X-3. [pmid: 18939377].
403 Cass AS, Cass BP, Veeraraghavan K. Immediate exploration of the unilateral acute scrotum in young male subjects. J Urol. Dec. 1980;124(6):829-32. X-2, X-3. [pmid: 7441833].
404 Cass AS, Ferrara L, Wolpert J, et al. Bilateral testicular injury from external trauma. J Urol. Dec. 1988;140(6):1435-6. X-2, X-3. [pmid: 3193512].
405 Cass AS, Luxenberg M. Testicular injuries. Urology. Jun. 1991;37(6):528-30. X-2, X-3. [pmid: 2038785].
406 Cassidy SB, Driscoll DJ. Prader-Willi syndrome. European Journal of Human Genetics. 2009;17(1):3-13. X-1, X-2, X-3. [pmid: 18781185].
407 Cassio A, Cacciari E, D’Errico A, et al. Incidence of intratubular germ cell neoplasia in androgen insensitivity syndrome. Acta Endocrinol (Copenh). Oct. 1990;123(4):416-22. X-2, X-3. [pmid: 2173324].
408 Castro A, Codner E, Kaune H, et al. Absence of Y chromosome microdeletions in patients with cryptorchidism and hypospadias. J Pediatr Endocrinol Metab. Feb. 2004;17(2):143-8. X-3. [pmid: 15055347].
409 Castro-Magana M, Angulo M, Uy J. Elevated serum estradiol associated with increased androstenedione-testosterone ratio in adolescent males with varicocele and gynecomastia. Fertil Steril. Sep. 1991;56(3):515-8. X-2, X-3. [pmid: 1894030].
410 Castro-Nallar E, Bacallao K, Parada-Bustamante A, et al. Androgen receptor gene CAG and GGN repeat polymorphisms in Chilean men with primary severe spermatogenic failure. J Androl. Nov–Dec. 2010;31(6):552-9. X-2, X-3. [pmid: 20378930].
411 Cattolica EV, Karol JB, Rankin KN, et al. High testicular salvage rate in torsion of the spermatic cord. J Urol. Jul. 1982;128(1):66-8. X-2, X-3. [pmid: 7109074].
412 Caucci M, Barbatelli G, Cinti S. The retractile testis can be a cause of adult infertility. Fertil Steril. Dec. 1997;68(6):1051-8. X-2, X-3. [pmid: 9418696].
413 Cavicchia JC, Sacerdote FL, Ortiz L. The human blood-testis barrier in impaired spermatogenesis. Ultrastruct Pathol. May–Jun. 1996;20(3):211-8. X-2, X-3. [pmid: 8727063].
414 Cavusoglu YH, Karaman A, Karaman I, et al. Acute scrotum -- etiology and management. Indian J Pediatr. Mar. 2005;72(3):201-3. X-2, X-3. [pmid: 15812112].
415 Cayan S, Akbay E, Bozlu M, et al. The effect of varicocele repair on testicular volume in children and adolescents with varicocele. J Urol. Aug. 2002;168(2):731-4. X-2, X-3. [pmid: 12131361].
416 Cayan S, Akbay E, Bozlu M, et al. Diagnosis of pediatric varicoceles by physical examination and ultrasonography and measurement of the testicular volume: using the prader orchidometer versus ultrasonography. Urol Int. 2002;69(4):293-6. X-2, X-3. [pmid: 12444286].
417 Cayan S, Erdemir F, Ozbey I, et al. Can varicocelectomy significantly change the way couples use assisted reproductive technologies?. Journal of Urology. 2002;167(41):1749-1752. X-2, X-3. [pmid: 11912402].
418 Celayir AC, Sander S, Elicevik M. Timing of surgery in perineal ectopic testes: analysis of 16 cases. Pediatr Surg Int. Mar. 2001;17(2–3):167-8. X-2, X-3. [pmid: 11315279].
419 Celebi I, Tekgul S, Ozen HA, et al. Sequential bilateral germ cell tumours of the testis. Int Urol Nephrol. 1995;27(2):183-7. X-2, X-3. [pmid: 7591576].
420 Celen MK, Ulug M, Ayaz C, et al. Brucellar epididymo-orchitis in southeastern part of Turkey: An 8 year experience. Brazilian Journal of Infectious Diseases. Jan. 2010;14(1):109-115. X-2, X-3. [pmid: 20428665].
421 Celik AS, Memmi N, Celebi F, et al. Impact of slit and nonslit mesh technique on testicular perfusion and volume in the early and late postoperative period of the totally extraperitoneal preperitoneal technique in patients with inguinal hernia. Am J Surg. Aug. 2009;198(2):287-91. X-2, X-3. [pmid: 19362282].
422 Celiktas M, Aikimbaev K, Aridogan IA, et al. The effect of retroperitoneal fat tissue thickness on testicular venous drainage. Urol Int. 2009;83(1):92-7. X-2, X-3. [pmid: 19641367].
423 Cendron M, Schned AR, Ellsworth PI. Histological evaluation of the testicular nubbin in the vanishing testis syndrome. J Urol. Sep. 1998;160(3 Pt 2):1161-2. discussion 1163. X-2, X-3. [pmid: 9719300].
424 Cespedes RD, Caballero RL, Peretsman SJ, et al. Cryptic presentations of germ cell tumors. J Am Coll Surg. Mar. 1994;178(3):261-5. X-2, X-3. [pmid: 8149018].
425 Ceuppens H, Derom F, Anne T. Two-stage orchiopexy. Acta Chir Belg. Jul–Aug. 1981;80(4):205-11. X-4, X-5, X-6. [pmid: 6117167].
426 Chakraborty J, Hikim AP, Jhunjhunwala JS. Quantitative evaluation of testicular biopsies from men with unilateral torsion of spermatic cord. Urology. Feb. 1985;25(2):145-50. X-2, X-3. [pmid: 2578694].
427 Chakraborty J, Sinha Hikim AP, Jhunjhunwala JS. Stagnation of blood in the microvasculature of the affected and contralateral testes of men with short-term torsion of the spermatic cord. J Androl. Sep–Oct. 1985;6(5):291-9. X-2, X-3. [pmid: 4055528].
428 Chan KL, Tam PKH. Technical refinements in laparoscopic repair of childhood inguinal hernias. Surgical Endoscopy. Jun. 2004;18(6):957-960. X-2, X-3. [pmid: 15095082].
429 Chan KW, Ma LT. Eosinophilic granular cells in a cryptorchid testis. Arch Pathol Lab Med. Sep. 1987;111(9):877-9. X-2, X-3. [pmid: 2888449].
430 Chan PT, Wright EJ, Goldstein M. Incidence and postoperative outcomes of accidental ligation of the testicular artery during microsurgical varicocelectomy. J Urol. Feb. 2005;173(2):482-4. X-2, X-3. [pmid: 15643221].
431 Chan YM, de Guillebon A, Lang-Muritano M, et al. GNRH1 mutations in patients with idiopathic hypogonadotropic hypogonadism. Proc Natl Acad Sci U S A. Jul. 14. 2009;106(28):11703-8. X-2, X-3. [pmid: 19567835].
432 Chatzidarellis E, Makrilia N, Giza L, et al. Effects of taxane-based chemotherapy on inhibin B and gonadotropins as biomarkers of spermatogenesis. Fertil Steril. Jul. 2010;94(2):558-63. X-2, X-3. [pmid: 19765702].
433 Che M, Tamboli P, Ro JY, et al. Bilateral testicular germ cell tumors: twenty-year experience at M. D. Anderson Cancer Center. Cancer. Sep. 15. 2002;95(6):1228-33. X-2, X-3. [pmid: 12216089].
434 Cheikhelard A, Morel Y, Thibaud E, et al. Long-Term Followup and Comparison Between Genotype and Phenotype in 29 Cases of Complete Androgen Insensitivity Syndrome. Journal of Urology. October. 2008;180(4):1496-1501. X-2, X-3. [pmid: 18710728].
435 Chen C. Varicocele in male factor infertility: role of laparoscopic varicocelectomy. Int Surg. Sep–Oct. 2006;91(5 Suppl):S90-4. X-2, X-3. [pmid: 17436610].
436 Chen CP, Wang W, Lin SP, et al. Perinatal findings in a male fetus with congenital megacystis and anorectal malformations. Fetal Diagn Ther. Nov–Dec. 1998;13(6):348-51. X-2, X-3. [pmid: 9933817].
437 Chen KL, Wu HC, Chen YW, et al. International Journal of Urology. [Conference Abstract]. August. Conference: 10th Asian Congress of Urology of the Urological Association of Asia. Taipei Taiwan (Republic of China). Conference Start: 20100827 Conference End: 20100831. Conference Publication: (var.pagings). 2010;17:A337. X-2, X-3.
438 Chen P, John S. Ultrasound of the acute scrotum. Applied Radiology. Mar. 2006;35(3):8-17. X-1, X-2, X-3.
439 Chertin B, Koulikov D, Alberton J, et al. The use of laparoscopy in intersex patients. Pediatr Surg Int. May. 2006;22(5):405-8. X-2, X-3. [pmid: 16521001].
440 Chew G, Hutson JM. Incidence of cryptorchidism and ascending testes in trisomy 21: a 10 year retrospective review. Pediatr Surg Int. Oct. 2004;20(10):744-7. X-2, X-3. [pmid: 15517292].
441 Chia SE. Endocrine disruptors and male reproductive function--a short review. Int J Androl. Suppl 2. 2000;23:45-6. X-1, X-2, X-3. [pmid: 10849494].
442 Chiba K, Ishikawa T, Yamaguchi K, et al. The efficacy of adult orchidopexy as a treatment of male infertility: our experience of 20 cases. Fertil Steril. Oct. 2009;92(4):1337-9. X-2, X-3. [pmid: 19439289].
443 Chilvers C, Pike MC, Forman D, et al. Apparent doubling of frequency of undescended testis in England and Wales in 1962–81. Lancet. Aug. 11. 1984;2(8398):330-2. X-3. [pmid: 6146873].
444 Chin T, Liu C, Wei C. The morphology of the contralateral internal inguinal rings is age-dependent in children with unilateral inguinal hernia. J Pediatr Surg. Dec. 1995;30(12):1663-5. X-2, X-3. [pmid: 8749918].
445 Chinnaswamy P, Malladi V, Jani KV, et al. Laparoscopic inguinal hernia repair in children. JSLS. Oct–Dec. 2005;9(4):393-8. X-2, X-3. [pmid: 16381352].
446 Cho HY, Lee BH, Choi HJ, et al. Renal manifestations of Dent disease and Lowe syndrome. Pediatr Nephrol. Feb. 2008;23(2):243-9. X-2, X-3. [pmid: 18038239].
447 Cho SH, Min SK, Lee ST. Associations of ultrasonographic features with scrotal pain after vasectomy. Korean Journal of Urology. November. 2011;52(11):782-786. X-2, X-3. [pmid: 22195269].
448 Choi H, Kim KM, Koh SK, et al. A survey of externally recognizable genitourinary anomalies in Korean newborns. Korean Urological Association. J Korean Med Sci. Mar. 1989;4(1):13-21. X-2, X-3. [pmid: 2789734].
449 Chou YH, Tsau YK, Lin KH, et al. Malignant urinary tract tumor in childhood. J Formos Med Assoc. Nov. 1991;90(11):1113-8. X-2, X-3. [pmid: 1687060].
450 Chowbey PK, Garg N, Sharma A, et al. Prospective randomized clinical trial comparing lightweight mesh and heavyweight polypropylene mesh in endoscopic totally extraperitoneal groin hernia repair. Surg Endosc. Dec. 2010;24(12):3073-9. X-2, X-3. [pmid: 20490567].
451 Chowdhary ND, Besina S, Kadri SM, et al. Prepubertal testicular tumours in Kashmir--a histopathological report of 15 cases. J Indian Med Assoc. Nov. 2004;102(11):620-2. X-2, X-3. [pmid: 15868871].
452 Chowdhary ND, Khan AR. Bilateral tumors of the testis. JK Practitioner. 1997;4(4):292-294. X-2, X-3.
453 Chowdhary SK, Lander AD, Buick RG, et al. The primary management of testicular maldescent in gastroschisis. Pediatr Surg Int. Jul. 2001;17(5–6):359-60. X-2, X-3. [pmid: 11527165].
454 Choyke PL, Glenn GM, Wagner JP, et al. Epididymal cystadenomas in von Hippel-Lindau disease. Urology. Jun. 1997;49(6):926-31. X-2, X-3. [pmid: 9187702].
455 Christensen JD, Dogra VS. The Undescended Testis. Seminars in Ultrasound, CT and MRI. Aug. 2007;28(4):307-316. X-1, X-2, X-3.
456 Christensen TB, Daugaard G, Geertsen PF, et al. Effect of chemotherapy on carcinoma in situ of the testis. Ann Oncol. Jun. 1998;9(6):657-60. X-2, X-3. [pmid: 9681081].
457 Christiansen P, Skakkebaek NE. Pulsatile gonadotropin-releasing hormone treatment of men with idiopathic hypogonadotropic hypogonadism. Horm Res. 2002;57(1–2):32-6. X-2, X-3. [pmid: 12006717].
458 Chu CC, Chou CY, Hsu TM, et al. Intraoperative laparoscopy in unilateral hernia repair to detect a contralateral patent processus vaginalis. Pediatric Surgery International. 1993;8(5):385-388. X-2, X-3.
459 Chung JJ, Kim MJ, Lee T, et al. Sonographic findings in tuberculous epididymitis and epididymo-orchitis. J Clin Ultrasound. Sep. 1997;25(7):390-4. X-2, X-3. [pmid: 9282805].
460 Chung SD, Wu CC, Lin VC, et al. Minilaparoscopic varicocelectomy with preservation of testicular artery and lymphatic vessels by using intracorporeal knot-tying technique: five-year experience. World J Surg. Aug. 2011;35(8):1785-90. X-2, X-3. [pmid: 21523498].
461 Ciftci AO, Bingol-Kologlu M, Senocak ME, et al. Testicular tumors in children. J Pediatr Surg. Dec. 2001;36(12):1796-801. X-2, X-3. [pmid: 11733909].
462 Cil B, Peynircioglu B, Canyigit M, et al. Peripheral vascular applications of the Amplatzer vascular plug. Diagn Interv Radiol. Mar. 2008;14(1):35-9. X-2, X-3. [pmid: 18306144].
463 Ciovirnache M, Florea I, Popa M, et al. Morphotypic aspects in the cryptorchidic child. Endocrinologie. Jan–Mar. 1987;25(1):45-53. X-3. [pmid: 2883720].
464 Claahsen-van der Grinten HL, Otten BJ, Hermus AR, et al. Testicular adrenal rest tumors in patients with congenital adrenal hyperplasia can cause severe testicular damage. Fertil Steril. Mar. 2008;89(3):597-601. X-2, X-3. [pmid: 17543962].
465 Claahsen-van der Grinten HL, Otten BJ, Sweep FC, et al. Testicular tumors in patients with congenital adrenal hyperplasia due to 21-hydroxylase deficiency show functional features of adrenocortical tissue. J Clin Endocrinol Metab. Sep. 2007;92(9):3674-80. X-2, X-3. [pmid: 17595257].
466 Claahsen-van der Grinten HL, Otten BJ, Takahashi S, et al. Testicular adrenal rest tumors in adult males with congenital adrenal hyperplasia: evaluation of pituitary-gonadal function before and after successful testis-sparing surgery in eight patients. J Clin Endocrinol Metab. Feb. 2007;92(2):612-5. X-2, X-3. [pmid: 17090637].
467 Claahsen-van der Grinten HL, Sweep FC, Blickman JG, et al. Prevalence of testicular adrenal rest tumours in male children with congenital adrenal hyperplasia due to 21-hydroxylase deficiency. Eur J Endocrinol. Sep. 2007;157(3):339-44. X-2, X-3. [pmid: 17766717].
468 Clarnette TD, Hutson JM. Is the ascending testis actually ‘stationary’? Normal elongation of the spermatic cord is prevented by a fibrous remnant of the processus vaginalis. Pediatr Surg Int. Feb. 1997;12(2–3):155-7. X-1, X-3.
469 Clarnette TD, Rowe D, Hasthorpe S, et al. Incomplete disappearance of the processus vaginalis as a cause of ascending testis. J Urol. May. 1997;157(5):1889-91. X-4, X-5, X-6. [pmid: 9112556].
470 Classen J, Dieckmann K, Bamberg M, et al. Radiotherapy with 16 Gy may fail to eradicate testicular intraepithelial neoplasia: preliminary communication of a dose-reduction trial of the German Testicular Cancer Study Group. Br J Cancer. Mar. 24. 2003;88(6):828-31. X-2, X-3. [pmid: 12644817].
471 Classen J, Souchon R, Hehr T, et al. Treatment of early stage testicular seminoma. Journal of Cancer Research and Clinical Oncology. 2001;127(8):475-481. X-2, X-3. [pmid: 11501746].
472 Clausen OP, Giwercman A, Jorgensen N, et al. DNA distributions in maldescended testes: hyperdiploid aneuploidy without evidence of germ cell neoplasia. Cytometry. 1991;12(1):77-81. X-2, X-3. [pmid: 1671832].
473 Clavijo RI, Rose-Nussbaumer J, Turek PJ. Clinically symptomatic vasitis: clinical correlations in a rare condition. Syst Biol Reprod Med. Dec. 2010;56(6):445-9. X-2, X-3. [pmid: 20964559].
474 Clayman RV, Kavoussi LR, Anderson KR. Laparoscopic urology: past, present, and future. World J Surg. Jan–Feb. 1993;17(1):57-62. X-1. [pmid: 8123065].
475 Cline KJ, Mata JA, Venable DD, et al. Penetrating trauma to the male external genitalia. J Trauma. Mar. 1998;44(3):492-4. X-2, X-3. [pmid: 9529176].
476 Cockburn AG, Vugrin D, Batata M. Second primary germ cell tumors in patients with seminoma of the testis. Journal of Urology. 1983;130(2):357-359. X-2, X-3. [pmid: 6876292].
477 Codesal J, Nistal M, Queizan A, et al. Number and DNA content of hypertrophic spermatogonia in normal and cryptorchid human testes. Arch Androl. Sep–Oct. 1992;29(2):157-62. X-2, X-3. [pmid: 1360789].
478 Codesal J, Paniagua R, Queizan A, et al. Cytophotometric DNA quantification in human spermatogonia of cryptorchid testes. J Urol. Feb. 1993;149(2):382-5. X-3, X-4, X-5, X-6. [pmid: 8093909].
479 Cohen MM Jr, Kreiborg S. Visceral anomalies in the Apert syndrome. American Journal of Medical Genetics. 1993;45(6):758-760. X-2, X-3. [pmid: 8456856].
480 Cohen TD, Kay R, Knipper N. Reoperation for cryptorchid testis in prepubertal child. Urology. Oct. 1993;42(4):437-9. X-4, X-5, X-6. [pmid: 8105600].
481 Cohen Z, Shinhar D, Kurzbart E, et al. Laparoscopic and thoracoscopic surgery in children and adolescents: a 3-year experience. Pediatr Surg Int. Jul. 1997;12(5–6):356-9. X-4, X-5, X-6. [pmid: 9244098].
482 Colacurci N, Cardone A, De Franciscis P, et al. Laparoscopic hysterectomy in a case of male pseudohermaphroditism with persistent Mullerian duct derivatives. Hum Reprod. Feb. 1997;12(2):272-4. X-2, X-3. [pmid: 9070709].
483 Colao A, De Rosa M, Sarnacchiaro F, et al. Chronic treatment with CV 205–502 restores the gonadal function in hyperprolactinemic males. Eur J Endocrinol. Nov. 1996;135(5):548-52. X-2, X-3. [pmid: 8980156].
484 Colleselli K, Poisel S, Schachtner W, et al. Nerve-preserving bilateral retroperitoneal lymphadenectomy: anatomical study and operative approach. J Urol. Aug. 1990;144(2 Pt 1):293-7. discussion 297–8. X-2, X-3. [pmid: 2374194].
485 Colls BM, Harvey VJ, Skelton L, et al. Bilateral germ cell testicular tumors in New Zealand: experience in Auckland and Christchurch 1978–1994. J Clin Oncol. Jul. 1996;14(7):2061-5. X-2, X-3. [pmid: 8683237].
486 Colpi GM, Carmignani L, Nerva F, et al. Testicular-sparing microsurgery for suspected testicular masses. BJU Int. Jul. 2005;96(1):67-9. X-2, X-3. [pmid: 15963123].
487 Colpi GM, Negri L, Scroppo FI, et al. Epididymal ultrasonographic findings in case of obstructive pathology. Acta Chir Hung. 1994;34(3–4):299-302. X-2, X-3. [pmid: 7618382].
488 Comhaire F, Kunnen M, Nahoum C. Radiological anatomy of the internal spermatic vein(s) in 200 retrograde venograms. Int J Androl. Jun. 1981;4(3):379-87. X-2, X-3. [pmid: 7263093].
489 Comiter CV, Benson CJ, Capelouto CC, et al. Nonpalpable intratesticular masses detected sonographically. J Urol. Oct. 1995;154(4):1367-9. X-2, X-3. [pmid: 7658540].
490 Connolly SS, D’Arcy FT, Gough N, et al. Carefully selected intratesticular lesions can be safely managed with serial ultrasonography. BJU Int. Nov. 2006;98(5):1005-7. discussion 1007. X-2, X-3. [pmid: 17034602].
491 Coogan CL, Foster RS, Simmons GR, et al. Bilateral testicular tumors: management and outcome in 21 patients. Cancer. Aug. 1. 1998;83(3):547-52. X-2, X-3. [pmid: 9690548].
492 Cook MB, Graubard BI, Rubertone MV, et al. Perinatal factors and the risk of testicular germ cell tumors. Int J Cancer. Jun. 1. 2008;122(11):2600-6. X-2, X-3. [pmid: 18324625].
493 Cooke A, Tolmie JL, Colgan JM, et al. Detection of an unbalanced translocation (4;14) in a mildly retarded father and son by flow cytometry. Hum Genet. Aug. 1989;83(1):83-7. X-2, X-3. [pmid: 2570022].
494 Cooper K, Govender D. Adenomatous hyperplasia of the rete testis in the undescended testis. J Pathol. Dec. 1990;162(4):333-4. X-2, X-3. [pmid: 1705285].
495 Coran AG, Polley TZ Jr. Surgical management of ambiguous genitalia in the infant and child. J Pediatr Surg. Jul. 1991;26(7):812-20. X-2, X-3. [pmid: 1895191].
496 Cornel EB, Karthaus HF. Manual derotation of the twisted spermatic cord. BJU Int. Apr. 1999;83(6):672-4. X-2, X-3. [pmid: 10233577].
497 Corner NB, Bissett RJ, Hull JB, et al. Orchidopexy in a military hospital. J R Army Med Corps. Feb. 1990;136(1):50-2. X-4, X-5, X-6. [pmid: 1969480].
498 Cornwall GA, Orgebin-Crist MC, Hann SR. The CRES gene: a unique testis-regulated gene related to the cystatin family is highly restricted in its expression to the proximal region of the mouse epididymis. Mol Endocrinol. Oct. 1992;6(10):1653-64. X-2, X-3. [pmid: 1280328].
499 Corona G, Petrone L, Fisher AD, et al. Six-month administration of 1% testosterone gel is able to restore erectile function in hypogonadal patients with erectile dysfunction. Archivio Italiano di Urologia e Andrologia. September. 2008;80(3):103-108. X-2, X-3. [pmid: 19009866].
500 Corona G, Petrone L, Paggi F, et al. Sexual dysfunction in subjects with Klinefelter’s syndrome. Int J Androl. Aug. 1. 2010;33(4):574-80. X-2, X-3. [pmid: 19780865].
501 Corrie D, Mueller EJ, Thompson IM. Management of ultrasonically detected nonpalpable testis masses. Urology. 1991;38(5):429-431. X-3, X-4, X-5, X-6. [pmid: 1949452].
502 Cortada X, Kousseff BG. Cryptorchidism in mental retardation. J Urol. Apr. 1984;131(4):674-6. X-2, X-3. [pmid: 6142964].
503 Cortes D. Cryptorchidism - Aspects of pathogenesis, histology and treatment. Scandinavian Journal of Urology and Nephrology, Supplement. 1998;32(196):1-54. X-3, X-4, X-5, X-6. [pmid: 9561565].
504 Cortes D, Brandt B, Thorup J. Direct mixed antiglobulin reaction (MAR) test in semen at follow-up after testicular biopsy of maldescended testes operated in puberty. Z Kinderchir. Aug. 1990;45(4):227-8. X-4, X-5, X-6. [pmid: 1978450].
505 Cortes D, Kjellberg EM, Breddam M, et al. The true incidence of cryptorchidism in Denmark. J Urol. Jan. 2008;179(1):314-8. X-3. [pmid: 18006016].
506 Cortes D, Thorup J. Histology of testicular biopsies taken at operation for bilateral maldescended testes in relation to fertility in adulthood. Br J Urol. Sep. 1991;68(3):285-91. X-4, X-5, X-6. [pmid: 1680519].
507 Cortes D, Thorup J, Hogdall E, et al. The relation of germ cells per tubule in testes, serum inhibin B and FSH in cryptorchid boys. Pediatr Surg Int. Feb. 2007;23(2):163-9. X-4, X-5, X-6. [pmid: 17171380].
508 Cortes D, Thorup J, Lindenberg S, et al. Infertility despite surgery for cryptorchidism in childhood can be classified by patients with normal or elevated follicle-stimulating hormone and identified at orchidopexy. BJU Int. May. 2003;91(7):670-4. X-4, X-5, X-6. [pmid: 12699482].
509 Cortes D, Thorup JM, Beck BL. Quantitative histology of germ cells in the undescended testes of human fetuses, neonates and infants. J Urol. Sep. 1995;154(3):1188-92. X-2, X-3. [pmid: 7637086].
510 Cortes D, Thorup JM, Beck BL, et al. Cryptorchidism as a caudal developmental field defect. A new description of cryptorchidism associated with malformations and dysplasias of the kidneys, the ureters and the spine from T10 to S5. APMIS. Oct. 1998;106(10):953-8. X-3. [pmid: 9833697].
511 Cortes D, Thorup JM, Lindenberg S. Fertility potential after unilateral orchiopexy: simultaneous testicular biopsy and orchiopexy in a cohort of 87 patients. J Urol. Mar. 1996;155(3):1061-5. X-4, X-5, X-6. [pmid: 8583565].
512 Cortes D, Thorup JM, Nielsen OH, et al. Cryptorchidism in boys with imperforate anus. J Pediatr Surg. Apr. 1995;30(4):631-5. X-3. [pmid: 7595851].
513 Cortes D, Thorup JM, Visfeldt J, et al. Is infertility after surgery for cryptorchidism congenital or acquired?. Pediatr Surg Int. Nov. 1998;14(1–2):6-8. X-2, X-3. [pmid: 9880685].
514 Corvin S, Sturm W, Anastasiadis A, et al. Laparoscopic management of the adult nonpalpable testicle. Urol Int. 2005;75(4):337-9. X-2. [pmid: 16327302].
515 Coskun G, Apaydin M, Sarsilmaz A, et al. Pediatric Radiology. [Conference Abstract]. June. Conference: European Society of Paediatric Radiology 46th Annual Meeting and 32nd Postgraduate Course. Istanbul Turkey. Conference Start: 20090531 Conference End: 20090604. Conference Publication: (var.pagings). 2009;39:S572. X-2, X-3.
516 Coskun O, Cem Gul H, Mert G, et al. Brucellar epididymo-orchitis: A retrospective study. Trakya Universitesi Tip Fakultesi Dergisi. 2009;26(3):220-225. X-2, X-3.
517 Costa WS, Sampaio FJ, Favorito LA, et al. Testicular migration: remodeling of connective tissue and muscle cells in human gubernaculum testis. J Urol. May. 2002;167(5):2171-6. X-2, X-3. [pmid: 11956474].
518 Coughlin MT, Bellinger MF, Lee PA. Age at unilateral orchiopexy: effect on hormone levels and sperm count in adulthood. J Urol. Sep. 1999;162(3 Pt 2):986-8. discussion 989. X-2, X-3. [pmid: 10458417].
519 Coughlin MT, LaPorte RE, O’Leary LA, et al. How accurate is male recall of reproductive information?. Am J Epidemiol. Oct. 15. 1998;148(8):806-9. X-2, X-3. [pmid: 9786236].
520 Coupland CA, Chilvers CE, Davey G, et al. Risk factors for testicular germ cell tumours by histological tumour type. United Kingdom Testicular Cancer Study Group. Br J Cancer. Aug. 1999;80(11):1859-63. X-2, X-3. [pmid: 10468310].
521 Coutts SM, Fulton N, Anderson RA. Environmental toxicant-induced germ cell apoptosis in the human fetal testis. Hum Reprod. Nov. 2007;22(11):2912-8. X-2, X-3. [pmid: 17890726].
522 Cox MJ, Coplen DE, Austin PF. The incidence of disorders of sexual differentiation and chromosomal abnormalities of cryptorchidism and hypospadias stratified by meatal location. J Urol. Dec. 2008;180(6):2649-52. discussion 2652. X-3, X-4, X-5, X-6. [pmid: 18951572].
523 Cozzi DA, Mele E, Ceccanti S, et al. Infantile abdominoscrotal hydrocele: a not so benign condition. J Urol. Dec. 2008;180(6):2611-5. discussion 2615. X-2, X-3. [pmid: 18950814].
524 Craft IL, Khalifa Y, Boulos A, et al. Factors influencing the outcome of in-vitro fertilization with percutaneous aspirated epididymal spermatozoa and intracytoplasmic sperm injection in azoospermic men. Hum Reprod. Jul. 1995;10(7):1791-4. X-2, X-3. [pmid: 8582981].
525 Crawford RD. The case for iron repletion as a promoter in testicular cancer. Medical Hypotheses. Aug. 1998;51(2):129-132. X-1, X-2, X-3. [pmid: 9881819].
526 Crellin AM, Hudson BV, Bennett MH, et al. Non-Hodgkin’s lymphoma of the testis. Radiother Oncol. May. 1993;27(2):99-106. X-2, X-3. [pmid: 8356234].
527 Crino A, Schiaffini R, Ciampalini P, et al. Hypogonadism and pubertal development in Prader-Willi syndrome. Eur J Pediatr. May. 2003;162(5):327-33. X-2, X-3. [pmid: 12692714].
528 Crosignani PG, Rubin BL. Optimal use of infertility diagnostic tests and treatments. The ESHRE Capri Workshop Group. Hum Reprod. Mar. 2000;15(3):723-32. X-1, X-2, X-3. [pmid: 10686227].
529 Cuevas-Covarrubias SA, Kofman-Alfaro SH, Palencia AB, et al. Accuracy of the clinical diagnosis of recessive X-linked ichthyosis vs ichthyosis vulgaris. J Dermatol. Sep. 1996;23(9):594-7. X-3. [pmid: 8916657].
530 Culha M, Mutlu N, Acar O, et al. Comparison of testicular volumes before and after varicocelectomy. Urol Int. Aug. 1998;60(4):220-3. X-2, X-3. [pmid: 9701734].
531 Czeizel A, Erodi E, Toth J. An epidemiological study on undescended testis. J Urol. Oct. 1981;126(4):524-7. X-3. [pmid: 6116808].
532 Czeizel AE, Kazy Z, Puho E. A population-based case-control teratological study of oral nystatin treatment during pregnancy. Scandinavian Journal of Infectious Diseases. 2003;35(11–12):830-835. X-2, X-3. [pmid: 14723358].
533 Czeizel AE, Kazy Z, Vargha P. A case-control teratological study of vaginal natamycin treatment during pregnancy. Reproductive Toxicology. Jul. 2003;17(4):387-391. X-2, X-3. [pmid: 12849848].
534 Czeizel AE, Kazy Z, Vargha P. A population-based case-control teratological study of vaginal econazole treatment during pregnancy. European Journal of Obstetrics Gynecology and Reproductive Biology. 10. Dec. 2003;111(2):135-140. X-2, X-3.
535 Czeizel AE, Puho E, Bartfai Z, et al. A Possible Association between Oral Aminophylline Treatment during Pregnancy and Skeletal Congenital Abnormalities. Clinical Drug Investigation. 2003;23(12):803-816. X-2, X-3. [pmid: 17536894].
536 Czeizel AE, Rockenbauer M, Sorensen HT, et al. A population-based case-control teratologic study of oral chloramphenicol treatment during pregnancy. Eur J Epidemiol. Apr. 2000;16(4):323-7. X-3. [pmid: 10959939].
537 Czeizel AE, Toth M, Rockenbauer M. No teratogenic effect after clotrimazole therapy during pregnancy. Epidemiology. Jul. 1999;10(4):437-40. X-3. [pmid: 10401880].
538 Czeizel AE, Vargha P. Case-control study of teratogenic potential of thiethylperazine, an anti-emetic drug. BJOG: An International Journal of Obstetrics and Gynaecology. 01. May. 2003;110(5):497-499. X-2, X-3. [pmid: 12742335].
539 Da Conceicao MJ, Coelho L. Caudal anaesthesia with 0.375% ropivacaine or 0.375% bupivacaine in paediatric patients. Br J Anaesth. Apr. 1998;80(4):507-8. X-3. [pmid: 9640159].
540 Dada R, Gupta NP, Kucheria K. AZF microdeletions associated with idiopathic and non-idiopathic cases with cryptorchidism and varicocele. Asian J Androl. Dec. 2002;4(4):259-63. X-2, X-3. [pmid: 12508125].
541 Dada R, Gupta NP, Kucheria K. Cytogenetic and molecular analysis of male infertility: Y chromosome deletion during nonobstructive azoospermia and severe oligozoospermia. Cell Biochem Biophys. 2006;44(1):171-7. X-2, X-3. [pmid: 16456245].
542 Dadfar M, Ahangarpour A, Habiby A, et al. Pre-operative serum level of inhibin B as a predictor of spermatogenesis improvement after varicocelectomy. Urol J. Spring. 2010;7(2):110-4. X-2, X-3. [pmid: 20535698].
543 Dadfar MR. Orchidopexy for retractile testes in infertile men: a prospective clinical study. Urol J. Summer. 2007;4(3):164-8. X-2, X-3. [pmid: 17987580].
544 Daehlin L, Tomic R, Damber JE. Depressed testosterone release from testicular tissue in vitro after withdrawal of oestrogen treatment in patients with prostatic carcinoma. Scand J Urol Nephrol. 1988;22(1):11-3. X-2, X-3. [pmid: 3387906].
545 Daehlin L, Ulstein M, Thorsen T, et al. Follow-up after torsion of the spermatic cord. Scand J Urol Nephrol Suppl. 1996;179:139-42. X-2, X-3. [pmid: 8908680].
546 Dalmau J, Graus F, Villarejo A, et al. Clinical analysis of anti-Ma2-associated encephalitis. Brain. Aug. 2004;127(Pt 8):1831-44. X-2, X-3. [pmid: 15215214].
547 Damgaard IN, Jensen TK, Boisen KA, et al. Cryptorchidism and maternal alcohol consumption during pregnancy. Environmental Health Perspectives. Feb. 2007;115(2):272-277. X-3. [pmid: 17384777].
548 Damgaard IN, Jensen TK, Petersen JH, et al. Risk factors for congenital cryptorchidism in a prospective birth cohort study. PLoS One. 2008;3(8):e3051. X-3. [pmid: 18725961].
549 Dan L, Lifang Y, Guangxiu L. Expression and possible functions of a novel gene SPATA12 in human testis. J Androl. Jul–Aug. 2007;28(4):502-12. X-2, X-3. [pmid: 17251597].
550 Dandapat MC, Padhi NC, Patra AP. Effect of hydrocele on testis and spermatogenesis. Br J Surg. Nov. 1990;77(11):1293-4. X-2, X-3. [pmid: 2253014].
551 Daniel C, Fizazi K, Culine S, et al. Metachronous gonadal and extragonadal primaries, or late relapse of germ cell tumor?. Urologic Oncology. 2001;6(2):49-52. X-2, X-3. [pmid: 11166620].
552 Daniels IR, Layer GT. How should gynaecomastia be managed?. ANZ J Surg. Apr. 2003;73(4):213-6. X-2, X-3. [pmid: 12662229].
553 Daniels IR, Layer GT. Testicular tumours presenting as gynaecomastia. Eur J Surg Oncol. Jun. 2003;29(5):437-9. X-2, X-3. [pmid: 12798747].
554 Danner C, Frick J. Cryptorchidism in adults. Urol Int. 1983;38(6):351-3. X-2. [pmid: 6140787].
555 Daoud MS, Dahl PR, Su WP. Noonan syndrome. Semin Dermatol. Jun. 1995;14(2):140-4. X-1, X-3. [pmid: 7640194].
556 Das KM, Prasad K, Szmigielski W, et al. Intratesticular varicocele: evaluation using conventional and Doppler sonography. AJR Am J Roentgenol. Oct. 1999;173(4):1079-83. X-2, X-3. [pmid: 10511183].
557 Das S, Amar AD. The impact of laparoscopy on modern urologic practice. Urol Clin North Am. Aug. 1988;15(3):537-40. X-3. [pmid: 2900568].
558 Datta MW, Ulbright TM, Young RH. Renal cell carcinoma metastatic to the testis and its adnexa: A report of five cases including three that accounted for the initial clinical presentation. International Journal of Surgical Pathology. 2001;9(1):49-56. X-2, X-3. [pmid: 11469344].
559 Daudin M, Bieth E, Bujan L, et al. Congenital bilateral absence of the vas deferens: clinical characteristics, biological parameters, cystic fibrosis transmembrane conductance regulator gene mutations, and implications for genetic counseling. Fertil Steril. Dec. 2000;74(6):1164-74. X-2, X-3. [pmid: 11119745].
560 Daugaard G, Giwercman A, Skakkebaek NE. Should the other testis be biopsied?. Seminars in Urologic Oncology. 1996;14(1):8-12. X-1, X-2, X-3. [pmid: 8833382].
561 Daugaard G, Karas V, Sommer P. Inguinal metastases from testicular cancer. BJU Int. Apr. 2006;97(4):724-6. X-2, X-3. [pmid: 16536762].
562 Daugaard G, Rorth M, von der Maase H, et al. Management of extragonadal germ-cell tumors and the significance of bilateral testicular biopsies. Ann Oncol. Apr. 1992;3(4):283-9. X-2, X-3. [pmid: 1327076].
563 Davey RB. Undescended testes: early versus late maldescent. Pediatr Surg Int. Feb. 1997;12(2–3):165-7. X-4, X-5, X-6.
564 Davidson S, Brish M, Zer A, et al. Plasma testosterone and beta HCG levels in the first twenty-four hours of life in neonates with cryptorchidism. Eur J Pediatr. Mar. 1981;136(1):87-9. X-3. [pmid: 6111456].
565 Davies MC, Liao LM, Wilcox DT, et al. Anorectal malformations: What happens in adulthood?. BJU International. August. 2010;106(3):398-404. X-3. [pmid: 19888969].
566 Davies N, Wheeler RA, Griffiths DM, et al. Opsite skin closure in day case paediatric surgery: is a subcuticular suture necessary?. J R Coll Surg Edinb. Dec. 1995;40(6):386-7. X-3, X-4, X-5, X-6. [pmid: 8583442].
567 Dawson C. Testicular cancer: seek advice early. J Fam Health Care. 2002;12(1):3. X-1, X-2, X-3. [pmid: 12415769].
568 Day R, Beckett B, Donnai D, et al. A clinical and genetic study of the Say/Barber/Biesecker/Young-Simpson type of Ohdo syndrome. Clinical Genetics. 2008;74(5):434-444. X-3. [pmid: 18798845].
569 de Almeida JC, Llerena JC Jr, Molina Gomes D, et al. G-11 staining in Turner’s syndrome with mos 45,X/46,X,r(?). Ann Genet. 1985;28(1):37-41. X-2, X-3. [pmid: 2409888].
570 de Arruda HO, Paula AAP, Suarez R, et al. Can selective retroperitoneal lymphadenectomy be better than unilateral retroperitoneal lymphadenectomy?. International Braz J Urol. Sep. 2003;29(5):412-417. X-2, X-3. [pmid: 15745585].
571 de Bruin MJ, Oosterhof GO, Debruyne FM. Nerve-sparing retroperitoneal lymphadenectomy for low stage testicular cancer. Br J Urol. Mar. 1993;71(3):336-9. X-2, X-3. [pmid: 8386581].
572 De Bruin MJFM, Oosterhof GON, Debruyne FMJ. Nerve sparing retroperitoneal lymphadenectomy in low stage non-seminomatous germ celltumors of the testis. Acta Chirurgica Austriaca. 1993;25(1):29-31. X-2, X-3.
573 de Gouveia Brazao CA, Pierik FH, Oosterhuis JW, et al. Bilateral testicular microlithiasis predicts the presence of the precursor of testicular germ cell tumors in subfertile men. J Urol. Jan. 2004;171(1):158-60. X-2, X-3. [pmid: 14665866].
574 De Grazia E, Gattuccio F, Fatta G, et al. Epididymo-testicular anomalies in the undescended testis. How important is their effect on infertility?. Acta Eur Fertil. Mar. 1982;13(1):1-17. X-3. [pmid: 6126982].
575 de Lima GR, da Silveira RA, de Cerqueira JB, et al. Single-incision multiport laparoscopic orchidopexy: initial report. J Pediatr Surg. Oct. 2009;44(10):2054-6. X-4, X-5, X-6. [pmid: 19853773].
576 De Miguel MP, Marino JM, Gonzalez-Peramato P, et al. Epididymal growth and differentiation are altered in human cryptorchidism. J Androl. Mar–Apr. 2001;22(2):212-25. X-3. [pmid: 11229795].
577 De Miguel MP, Regadera J, Martinez-Garcia F, et al. Oncostatin M in the normal human testis and several testicular disorders. J Clin Endocrinol Metab. Feb. 1999;84(2):768-74. X-3. [pmid: 10022451].
578 De Muinck Keizer-Schrama SM, Hazebroek FW, Drop SL, et al. Hormonal evaluation of boys born with undescended testes during their first year of life. J Clin Endocrinol Metab. Jan. 1988;66(1):159-64. X-3. [pmid: 2891719].
579 De Rosa M, Lupoli G, Mennitti M, et al. Congenital bilateral anorchia: clinical, hormonal and imaging study in 12 cases. Andrologia. Sep–Oct. 1996;28(5):281-5. X-2, X-3. [pmid: 8893097].
580 De Sanctis V, Marsella M. Unilateral asymptomatic testis enlargement in children and adolescents. Georgian Med News. Apr. 2011;(193):25-9. X-2, X-3. [pmid: 21617270].
581 De Schepper J, Verlinde F, Cortvrindt R, et al. Serum inhibin B in normal term-born male and female neonates during the first week of life. Eur J Pediatr. Jun. 2000;159(6):465-9. X-2, X-3. [pmid: 10867856].
582 de Vries BB, White SM, Knight SJ, et al. Clinical studies on submicroscopic subtelomeric rearrangements: a checklist. J Med Genet. Mar. 2001;38(3):145-50. X-3. [pmid: 11238680].
583 Dean A, Macleod D, Smith L, et al. International Journal of Andrology. [Conference Abstract]. October. Conference: 6th European Congress of Andrology. Athens Greece. Conference Start: 20100929 Conference End: 20101001. Conference Publication: (var.pagings). 2010;33:39. X-2, X-3.
584 Decastro GJ, Shabsigh A, Poon SA, et al. Adolescent varicocelectomy--is the potential for catch-up growth related to age and/or Tanner stage?. J Urol. Jan. 2009;181(1):322-7. discussion 327. X-2, X-3. [pmid: 19013614].
585 DeCou JM, Gauderer MW. Inguinal hernia in infants with very low birth weight. Semin Pediatr Surg. May. 2000;9(2):84-7. X-3. [pmid: 10807229].
586 Dede M, Pabuccu R, Yagci G, et al. Extragonadal yolk sac tumor in pelvic localization. a case report and literature review. Gynecologic Oncology. Mar. 2004;92(3):989-991. X-2, X-3. [pmid: 14984973].
587 Del Vecchio MT, Epistolato MC, Tripodi SA, et al. Intratubular germ cell neoplasia of unclassified type. Analytical and Quantitative Cytology and Histology. Jun. 2006;28(3):157-170. X-1, X-2, X-3. [pmid: 16786725].
588 Dellicour S, Hall S, Chandramohan D, et al. The safety of artemisinins during pregnancy: A pressing question. Malaria Journal. 2007;6(15). X-1, X-2, X-3.
589 Denamur E, Bocquet N, Baudouin V, et al. WT1 splice-site mutations are rarely associated with primary steroid-resistant focal and segmental glomerulosclerosis. Kidney Int. May. 2000;57(5):1868-72. X-2, X-3. [pmid: 10792605].
590 DePalma L, Carter D, Weiss RM. Epididymal and vas deferens immaturity in cryptorchidism. J Urol. Nov. 1988;140(5 Pt 2):1194-6. X-3, X-4, X-5, X-6. [pmid: 2903259].
591 Depue RH. Cryptorchidism, and epidemiologic study with emphasis on the relationship to central nervous system dysfunction. Teratology. Apr. 1988;37(4):301-5. X-3. [pmid: 2899361].
592 Depue RH, Pike MC, Henderson BE. Estrogen exposure during gestation and risk of testicular cancer. J Natl Cancer Inst. Dec. 1983;71(6):1151-5. X-2, X-3. [pmid: 6140323].
593 Desai CS, Prabhu RY, Supe AN. Laparoscopic orchidectomy for undescended testis in adults. J Postgrad Med. Jan–Mar. 2002;48(1):25-6. X-4, X-5, X-6. [pmid: 12082322].
594 Dessanti A, Falchetti D, Iannuccelli M, et al. Cryptorchidism with short spermatic vessels: staged orchiopexy preserving spermatic vessels. J Urol. Sep. 2009;182(3):1163-7. X-4, X-5, X-6. [pmid: 19625047].
595 Dessens AB, Cohen-Kettenis PT, Mellenbergh GJ, et al. Association of prenatal phenobarbital and phenytoin exposure with genital anomalies and menstrual disorders. Teratology. Oct. 2001;64(4):181-8. X-2, X-3. [pmid: 11598924].
596 Dewan PA. Paediatric surgery in Cambodia. Med J Aust. Dec. 4–18. 1995;163(11–12):640-2. X-3. [pmid: 8538566].
597 Di Tonno F, Tavolini IM, Belmonte P, et al. Lessons from 52 patients with leydig cell tumor of the testis: the GUONE (North-Eastern Uro-Oncological Group, Italy) experience. Urol Int. 2009;82(2):152-7. X-2, X-3. [pmid: 19322000].
598 Diamond DA, Caldamone AA. The value of laparoscopy for 106 impalpable testes relative to clinical presentation. J Urol. Aug. 1992;148(2 Pt 2):632-4. X-4, X-5, X-6. [pmid: 1353545].
599 Diamond DA, Caldamone AA, Elder JS. Prevalence of the vanishing testis in boys with a unilateral impalpable testis: is the side of presentation significant?. J Urol. Aug. 1994;152(2 Pt 1):502-3. X-3. [pmid: 7912290].
600 Diamond DA, Zurakowski D, Bauer SB, et al. Relationship of varicocele grade and testicular hypotrophy to semen parameters in adolescents. J Urol. Oct. 2007;178(4 Pt 2):1584-8. X-2, X-3. [pmid: 17707046].
601 Diav-Citrin O, Shechtman S, Bar-Oz B, et al. Pregnancy outcome after in utero exposure to valproate: Evidence of dose relationship in teratogenic effect. CNS Drugs. 2008;22(4):325-334. X-2, X-3. [pmid: 18336060].
602 Diav-Citrin O, Shechtman S, Halberstadt Y, et al. Pregnancy outcome after in utero exposure to angiotensin converting enzyme inhibitors or angiotensin receptor blockers. Reproductive Toxicology. May. 2011;31(4):540-545. X-2, X-3. [pmid: 21338666].
603 Dieckmann KP, Besserer A, Loy V. Low-dose radiation therapy for testicular intraepithelial neoplasia. J Cancer Res Clin Oncol. 1993;119(6):355-9. X-2, X-3. [pmid: 8383689].
604 Dieckmann KP, Boeckmann W, Brosig W, et al. Bilateral testicular germ cell tumors. Report of nine cases and review of the literature. Cancer. Mar. 15. 1986;57(6):1254-8. X-2, X-3. [pmid: 3002601].
605 Dieckmann KP, Heinemann V, Frey U, et al. How harmful is contralateral testicular biopsy? - An analysis of serial imaging studies and a prospective evaluation of surgical complications. European Urology. Oct. 2005;48(4):662-672. X-2, X-3. [pmid: 16009484].
606 Dieckmann KP, Linke J, Pichlmeier U, et al. Spermatogenesis in the contralateral testis of patients with testicular germ cell cancer: histological evaluation of testicular biopsies and a comparison with healthy males. BJU Int. May. 2007;99(5):1079-85. X-2, X-3. [pmid: 17244285].
607 Dieckmann KP, Loy V. Management of contralateral testicular intraepithelial neoplasia in patients with testicular germ-cell tumor. World J Urol. 1994;12(3):131-5. X-2, X-3. [pmid: 7951338].
608 Dieckmann KP, Loy V. Intratesticular effects of cisplatin-based chemotherapy. Eur Urol. 1995;28(1):25-30. X-2, X-3. [pmid: 8521890].
609 Dieckmann KP, Loy V. Prevalence of contralateral testicular intraepithelial neoplasia in patients with testicular germ cell neoplasms. J Clin Oncol. Dec. 1996;14(12):3126-32. X-2, X-3. [pmid: 8955658].
610 Dieckmann KP, Loy V. The value of the biopsy of the contralateral testis in patients with testicular germ cell cancer: the recent German experience. APMIS. Jan. 1998;106(1):13-20. discussion 20–3. X-2, X-3. [pmid: 9524558].
611 Dieckmann KP, Loy V, Buttner P. Prevalence of bilateral testicular germ cell tumours and early detection based on contralateral testicular intra-epithelial neoplasia. Br J Urol. Mar. 1993;71(3):340-5. X-2, X-3. [pmid: 8386582].
612 Diez Garcia R, Banuelos A, Marin C, et al. Peno-scrotal transposition. Eur J Pediatr Surg. Aug. 1995;5(4):222-5. X-2, X-3. [pmid: 7577861].
613 Dilek ON, Yucel A, Akbulut G, et al. Are there adverse effects of herniorrhaphy techniques on testicular perfusion? Evaluation by color Doppler ultrasonography. Urol Int. 2005;75(2):167-9. X-2, X-3. [pmid: 16123572].
614 Diniz G, Barutcuoglu M, Unalp A, et al. Evaluation of the relationship between urogenital abnormalities and neuromuscular disorders. Eastern Journal of Medicine. 2008;13(1–2):19-24. X-2, X-3.
615 Dissaneevate P, Warne GL, Zacharin MR. Clinical evaluation in isolated hypogonadotrophic hypogonadism (Kallmann syndrome). J Pediatr Endocrinol Metab. Sep–Oct. 1998;11(5):631-8. X-2, X-3. [pmid: 9829214].
616 Djahangirian O, Ouimet A, Saint-Vil D. Timing and surgical management of neonatal testicular torsions. J Pediatr Surg. May. 2010;45(5):1012-5. X-2, X-3. [pmid: 20438944].
617 Do M, Liatsikos E, Beatty J, et al. Laparoendoscopic single-site extraperitoneal inguinal hernia repair: initial experience in 10 patients. J Endourol. Jun. 2011;25(6):963-8. X-2, X-3. [pmid: 21542772].
618 Docimo SG, Moore RG, Adams J, et al. Laparoscopic orchiopexy for the high palpable undescended testis: preliminary experience. J Urol. Oct. 1995;154(4):1513-5. X-4, X-5, X-6. [pmid: 7658581].
619 Dohle GR, Ramos L, Pieters MH, et al. Surgical sperm retrieval and intracytoplasmic sperm injection as treatment of obstructive azoospermia. Hum Reprod. Mar. 1998;13(3):620-3. X-2, X-3. [pmid: 9572422].
620 Dohle GR, van Roijen JH, Pierik FH, et al. Subtotal obstruction of the male reproductive tract. Urol Res. Mar. 2003;31(1):22-4. X-2, X-3. [pmid: 12624659].
621 Dohle GR, Veeze HJ, Overbeek SE, et al. The complex relationships between cystic fibrosis and congenital bilateral absence of the vas deferens: Clinical, electrophysiological and genetic data. Human Reproduction. 1999;14(2):371-374. X-2, X-3. [pmid: 10099982].
622 Doig CM. Use of laparoscopy in children with impalpable testes. Int J Androl. Dec. 1989;12(6):420-2. X-4, X-5, X-6. [pmid: 2576244].
623 Dominguez C, Martinez Verduch M, Estornell F, et al. Histological study in contralateral testis of prepubertal children following unilateral testicular torsion. Eur Urol. 1994;26(2):160-3. X-2, X-3. [pmid: 7957473].
624 Domini R, Lima M, Domini M. Microvascular autotransplantation of the testis: the “refluo” technique. Eur J Pediatr Surg. Oct. 1997;7(5):288-91. X-3, X-4, X-5, X-6. [pmid: 9402488].
625 Donaldson KM, Tong SY, Hutson JM. Prevalence of late orchidopexy is consistent with some undescended testes being acquired. Indian J Pediatr. Nov–Dec. 1996;63(6):725-9. X-4, X-5, X-6. [pmid: 10830052].
626 Dondero F, Radicioni A, Gandini L, et al. Immunoglobulins in human seminal plasma. Andrologia. May–Jun. 1984;16(3):228-36. X-2, X-3. [pmid: 6147107].
627 Donkol RH, Salem T. Paternity after varicocelectomy: preoperative sonographic parameters of success. J Ultrasound Med. May. 2007;26(5):593-9. X-2, X-3. [pmid: 17460001].
628 Donnell SC, Rickwood AM, Jee LD, et al. Congenital testicular maldescent: significance of the complete hernial sac. Br J Urol. Jun. 1995;75(6):702-3. X-4, X-5, X-6. [pmid: 7613822].
629 Donohue JP, Rowland RG, Kopecky K, et al. Correlation of computerized tomographic changes and histological findings in 80 patients having radical retroperitoneal lymph node dissection after chemotherapy for testis cancer. J Urol. Jun. 1987;137(6):1176-9. X-2, X-3. [pmid: 3035236].
630 Doppman JL, Travis WD, Nieman L, et al. Cushing syndrome due to primary pigmented nodular adrenocortical disease: findings at CT and MR imaging. Radiology. Aug. 1989;172(2):415-20. X-2, X-3. [pmid: 2748822].
631 Doria-Rose VP, Biggs ML, Weiss NS. Subfertility and the risk of testicular germ cell tumors (United States). Cancer Causes Control. Aug. 2005;16(6):651-6. X-2, X-3. [pmid: 16049803].
632 Draghici I, Draghici L, Popescu M, et al. Exploratory laparoscopy--diagnosis method in pediatric surgery pathology. J Med Life. Jul–Sep. 2009;2(3):288-95. X-3. [pmid: 20112473].
633 Drinkard CR, Shatin D, Clouse J. Postmarketing surveillance of medications and pregnancy outcomes: clarithromycin and birth malformations. Pharmacoepidemiol Drug Saf. Dec. 2000;9(7):549-56. X-3. [pmid: 11338912].
634 Drop SL, Odink RJ, Rouwe C, et al. The effect of treatment with an LH-RH agonist (Buserelin) on gonadal activity growth and bone maturation in children with central precocious puberty. Eur J Pediatr. May. 1987;146(3):272-8. X-2, X-3. [pmid: 3109919].
635 Dudley AG, Sweeney DD, Docimo SG. Orchiopexy after prior inguinal surgery: a distal approach. J Urol. Jun. 2011;185(6):2340-3. X-4, X-5, X-6. [pmid: 21511304].
636 Duman L, Demirci M, Tanyel FC. Heart rate variability analysis reveals a shift in autonomic balance towards an increase in parasympathetic tonus in boys with undescended testis. Eur J Pediatr Surg. May. 2010;20(3):150-2. X-3. [pmid: 20084601].
637 Dunkel L, Hirvonen V, Erkkila K. Clinical aspects of male germ cell apoptosis during testis development and spermatogenesis. Cell Death and Differentiation. Apr. 1997;4(3):171-179. X-1, X-2, X-3. [pmid: 16465226].
638 Dunkel L, Perheentupa J, Apter D. Kinetics of the steroidogenic response to single versus repeated doses of human chorionic gonadotropin in boys in prepuberty and early puberty. Pediatr Res. Jan. 1985;19(1):1-4. X-3. [pmid: 2857482].
639 Dunkel L, Perheentupa J, Tapanainen J, et al. Hypergonadotropic hypogonadism in newborn males with primary testicular failure. Acta Paediatr Scand. Nov. 1984;73(6):740-4. X-3. [pmid: 6441447].
640 Dunkel L, Taskinen S, Hovatta O, et al. Germ cell apoptosis after treatment of cryptorchidism with human chorionic gonadotropin is associated with impaired reproductive function in the adult. J Clin Invest. Nov. 1. 1997;100(9):2341-6. X-2, X-3. [pmid: 9410913].
641 Dunn WK, McMillan PJ, Sokal M, et al. The value of repeated chest radiographs in the follow-up of patients with germ cell testicular tumours. Br J Radiol. Dec. 1991;64(768):1109-12. X-2, X-3. [pmid: 1773269].
642 Dursun A, Ermis B, Numanoglu V, et al. Bilateral multicystic renal dysplasia with potter sequence. A case with penile agenesis. Saudi Med J. Nov. 2006;27(11):1745-7. X-2, X-3. [pmid: 17106555].
643 Dusek L, Abrahamova J, Lakomy R, et al. Multivariate analysis of risk factors for testicular cancer: a hospital-based case-control study in the Czech Republic. Neoplasma. 2008;55(4):356-68. X-2, X-3. [pmid: 18505349].
644 Dutra RA, Boscollo ACP, Melo EC, et al. Clinical importance and prevalence of testicular microlithiasis in pediatric patients. Acta Cirurgica Brasileira. Sept./Oct. 2011;26(5):387-390. X-3. [pmid: 21952663].
645 Dutt N, Bates AW, Baithun SI. Secondary neoplasms of the male genital tract with different patterns of involvement in adults and children. Histopathology. Oct. 2000;37(4):323-31. X-2, X-3. [pmid: 11012739].
646 Dutta S, Albanese C. Transcutaneous laparoscopic hernia repair in children: a prospective review of 275 hernia repairs with minimum 2-year follow-up. Surg Endosc. Jan. 2009;23(1):103-7. X-2, X-3. [pmid: 18528614].
647 Duvie SO. Histological changes in the testis following adult orchidopexy for unilateral cryptorchidism. Arch Androl. 1984;12(2–3):231-4. X-2. [pmid: 6150688].
648 Eardley I, Saw KC, Whitaker RH. Surgical outcome of orchidopexy. II. Trapped and ascending testes. Br J Urol. Feb. 1994;73(2):204-6. X-4, X-5, X-6. [pmid: 7907522].
649 Eaton SH, Cendron MA, Estrada CR, et al. Intermittent testicular torsion: diagnostic features and management outcomes. J Urol. Oct. 2005;174(4 Pt 2):1532-5. discussion 1535. X-2, X-3. [pmid: 16148646].
650 Ebert AK, Bals-Pratsch M, Seifert B, et al. Genital and reproductive function in males after functional reconstruction of the exstrophy-epispadias complex--long-term results. Urology. Sep. 2008;72(3):566-9. discussion 569–70. X-2, X-3. [pmid: 18585763].
651 Eddy AA, Mauer SM. Pseudohermaphroditism, glomerulopathy and Wilms tumor (Drash syndrome): Frequency in end-stage renal failure. Journal of Pediatrics. 1985;106(4):584-587. X-2, X-3. [pmid: 2984395].
652 Edey AJ, Sidhu PS. Male infertility: Role of imaging in the diagnosis and management. Imaging. 2008;20(2):139-146. X-3.
653 Eggener SE, Lotan Y, Cheng EY. Magnetic resonance angiography for the nonpalpable testis: A cost and cancer risk analysis. Journal of Urology. May. 2005;173(5):1745-1749. X-1. [pmid: 15821574].
654 Ehrlich RM, Lesavoy MA, Fine RN. Total abdominal wall reconstruction in the prune belly syndrome. J Urol. Jul. 1986;136(1 Pt 2):282-5. X-3. [pmid: 2941594].
655 Ehrlich Y, Konichezky M, Yossepowitch O, et al. Multifocality in testicular germ cell tumors. J Urol. Mar. 2009;181(3):1114-9. discussion 1119–20. X-2, X-3. [pmid: 19150559].
656 Ehrlich Y, Yossepowitch O, Kedar D, et al. Distribution of nodal metastases after chemotherapy in nonseminomatous testis cancer: a possible indication for limited dissection. BJU Int. Jun. 2006;97(6):1221-4. X-2, X-3. [pmid: 16686715].
657 Eifler JB Jr, King P, Schlegel PN. Incidental testicular lesions found during infertility evaluation are usually benign and may be managed conservatively. J Urol. Jul. 2008;180(1):261-4. discussion 265. X-2, X-3. [pmid: 18499177].
658 Eigenmann J, Bandhauer K, Tomamichel G. Seminal carnitine concentration in obstructive azoospermia. Eur Urol. 1994;26(2):134-6. X-2, X-3. [pmid: 7957467].
659 Eijsbouts SW, de Muinck Keizer-Schrama SM, Hazebroek FW. Further evidence for spontaneous descent of acquired undescended testes. J Urol. Oct. 2007;178(4 Pt 2):1726-9. X-3, X-4, X-5, X-6. [pmid: 17707013].
660 Eil C, Crawford JD, Donahoe PK, et al. Fibroblast androgen receptors in patients with genitourinary anomalies. J Androl. Sep–Oct. 1984;5(5):313-20. X-2, X-3. [pmid: 6501082].
661 Ein SH, Njere I, Ein A. Six thousand three hundred sixty-one pediatric inguinal hernias: a 35-year review. J Pediatr Surg. May. 2006;41(5):980-6. X-2, X-3. [pmid: 16677897].
662 Ein SH, Shandling B, Wesson D, et al. Esophageal atresia with distal tracheoesophageal fistula: associated anomalies and prognosis in the 1980s. J Pediatr Surg. Oct. 1989;24(10):1055-9. X-2, X-3. [pmid: 2809951].
663 Einstein DM, Paushter DM, Singer AA, et al. Fibrotic lesions of the testicle: sonographic patterns mimicking malignancy. Urol Radiol. 1992;14(3):205-10. X-2, X-3. [pmid: 1290214].
664 Eisenberger MA, Blumenstein BA, Crawford ED, et al. Bilateral orchiectomy with or without flutamide for metastatic prostate cancer. N Engl J Med. Oct. 8. 1998;339(15):1036-42. X-2, X-3. [pmid: 9761805].
665 Ekeh AP, Walusimbi M, Brigham E, et al. The Prevalence of Incidental Findings on Abdominal Computed Tomography Scans of Trauma Patients. Journal of Emergency Medicine. May. 2010;38(4):484-489. X-2, X-3. [pmid: 19232878].
666 Ekenze SO, Ikechukwu RN, Oparaocha DC. Surgically correctable congenital anomalies: prospective analysis of management problems and outcome in a developing country. J Trop Pediatr. Apr. 2006;52(2):126-31. X-3, X-4, X-5, X-6. [pmid: 16169860].
667 Eklund A, Rudberg C, Smedberg S, et al. Short-term results of a randomized clinical trial comparing Lichtenstein open repair with totally extraperitoneal laparoscopic inguinal hernia repair. British Journal of Surgery. September. 2006;93(9):1060-1068. X-2, X-3. [pmid: 16862612].
668 El Gohary MA. Non-descent of the testis: An overlooked laparoscopic finding. J Pediatr Urol. Oct. 2008;4(5):364-6. X-4, X-5, X-6. [pmid: 18790421].
669 El Moussaif N, Haddad NE, Iraqi N, et al. 45,X/46,XY mosaicisme: Report of five cases and clinical review. Annales d’Endocrinologie. June. 2011;72(3):239-243. X-3. [pmid: 21640978].
670 El-Bayoumi MA, Hamada TA, El-Mokaddem HH. Male infertility: etiologic factors in 385 consecutive cases. Andrologia. Jul–Aug. 1982;14(4):333-9. X-2, X-3. [pmid: 6127042].
671 El-Dakhly MR, Tawadrous GA, Mostafa T, et al. Assessment of seminal plasma laminin in fertile and infertile men. Asian J Androl. Jan. 2007;9(1):63-7. X-2, X-3. [pmid: 17187158].
672 el-Demiry MI, Hargreave TB, Busuttil A, et al. Immunocompetent cells in human testis in health and disease. Fertil Steril. Sep. 1987;48(3):470-9. X-2, X-3. [pmid: 2957238].
673 Elder JS. Epididymal anomalies associated with hydrocele/hernia and cryptorchidism: implications regarding testicular descent. J Urol. Aug. 1992;148(2 Pt 2):624-6. X-3, X-4, X-5, X-6. [pmid: 1353542].
674 Elder JS. Two-stage Fowler-Stephens orchiopexy in the management of intra-abdominal testes. J Urol. Oct. 1992;148(4):1239-41. X-4, X-5, X-6. [pmid: 1357193].
675 Elder JS. Laparoscopy for impalpable testes: significance of the patent processus vaginalis. J Urol. Aug. 1994;152(2 Pt 2):776-8. X-4, X-5, X-6. [pmid: 7912744].
676 Elder JS, Keating MA, Duckett JW. Infant testicular prostheses. J Urol. Jun. 1989;141(6):1413-5. X-2, X-3. [pmid: 2566689].
677 Eldrup J, Steven K. Influence of orchidopexy for cryptorchidism on subsequent fertility. Br J Surg. Apr. 1980;67(4):269-70. X-3, X-4, X-5, X-6. [pmid: 6104527].
678 Elemen L, Sozubir S, Bulut M. An old technique for surgery of ‘high’ undescended testis revisited. J Pediatr Urol. Oct. 2008;4(5):330-2. X-4, X-5, X-6. [pmid: 18790413].
679 Elert A, Jahn K, Heidenreich A, et al. Population-based investigation of familial undescended testis and its association with other urogenital anomalies. Journal of Pediatric Urology. Dec. 2005;1(6):403-407. X-3. [pmid: 18947580].
680 El-Gohary MA. The role of laparoscopy in the management of impalpable testes. Pediatr Surg Int. Jul. 1997;12(5–6):463-5. X-4, X-5, X-6. [pmid: 9244131].
681 El-Gohary MA. Laparoscopic management of persistent mullerian duct syndrome. Pediatric Surgery International. Sep. 2003;19(7):533-536. X-4, X-5, X-6. [pmid: 13680290].
682 El-Haggar S, El-Ashmawy S, Attia A, et al. Beta-endorphin in serum and seminal plasma in infertile men. Asian J Androl. Nov. 2006;8(6):709-12. X-2, X-3. [pmid: 16751995].
683 Elliott M, Jones JC, Jones R, et al. An inter-district audit of the school entry medical examination in Cheshire. Public Health. May. 1994;108(3):203-10. X-2, X-3. [pmid: 8036263].
684 El-Moula MG, Izaki H, El-Anany F, et al. Laparoscopy and intersex: Report of 5 cases of male pseudohermaphroditism. Journal of Medical Investigation. Feb. 2008;55(1–2):147-150. X-4, X-5, X-6. [pmid: 18319558].
685 Elsawi MM, Pryor JP, Klufio G, et al. Genital tract function in men with Noonan syndrome. Journal of Medical Genetics. Jun. 1994;31(6):468-470. X-2, X-3. [pmid: 7915331].
686 El-Senoussi MA, Bissada NK, El-Akkad S. Epidemiology and clinical characteristics of testicular tumors in Saudi Arabia: King Faisal Specialist Hospital and Research Centre experience. Journal of Surgical Oncology. 1987;35(1):39-41. X-2, X-3. [pmid: 3033400].
687 El-Zahaby HM. Is the prolongation of QTc interval in infants during sevoflurane anaesthesia related to the speed of induction or to the duration of exposure?. Egyptian Journal of Anaesthesia. Jan. 2004;20(1):53-57. X-2, X-3.
688 Emir H, Ayik B, Elicevik M, et al. Histological evaluation of the testicular nubbins in patients with nonpalpable testis: assessment of etiology and surgical approach. Pediatr Surg Int. Jan. 2007;23(1):41-4. X-3. [pmid: 17031713].
689 Emir L, Sunay M, Yalbuzdag O, et al. Hormonal and pathologic changes after chemoablation of testes with hypertonic saline solution as a treatment method alternative to orchiectomy in patients with hormone sensitive metastatic prostatic cancer. Urol Oncol. Mar–Apr. 2011;29(2):212-7. X-2, X-3. [pmid: 19272797].
690 Emond JP, Houle JG. Orchiopexy with a thimble. J Urol. Dec. 1985;134(6):1176-8. X-4, X-5, X-6. [pmid: 2865380].
691 Endo M, Watanabe T, Nakano M, et al. Laparoscopic completely extraperitoneal repair of inguinal hernia in children: a single-institute experience with 1,257 repairs compared with cut-down herniorrhaphy. Surg Endosc. Aug. 2009;23(8):1706-12. X-2, X-3. [pmid: 19343444].
692 Engeler DS, Hosli PO, John H, et al. Early orchiopexy: prepubertal intratubular germ cell neoplasia and fertility outcome. Urology. Jul. 2000;56(1):144-8. X-4, X-5, X-6. [pmid: 10869645].
693 Erk A, Ozeren S, Ozbay O, et al. Persistent mullerian duct syndrome. A case report. J Reprod Med. Feb. 1999;44(2):135-8. X-2, X-3. [pmid: 10853446].
694 Erpenbach KH. Systemic treatment with interferon-alpha 2B: an effective method to prevent sterility after bilateral mumps orchitis. J Urol. Jul. 1991;146(1):54-6. X-2, X-3. [pmid: 2056606].
695 Esposito C, Damiano R, Gonzalez Sabin MA, et al. Laparoscopy-assisted orchidopexy: an ideal treatment for children with intra-abdominal testes. J Endourol. Nov. 2002;16(9):659-62. X-4, X-5, X-6. [pmid: 12490019].
696 Esposito C, Mastroianni L, Gonzalez-Sabin MA, et al. The value and the advantages of videosurgery in the management of pediatric varicoceles. Italian Journal of Pediatrics. Oct. 2003;29(5):354-357. X-2, X-3.
697 Esposito C, Mattioli G, Monguzzi GL, et al. Complications and conversions of pediatric videosurgery: the Italian multicentric experience on 1689 procedures. Surg Endosc. May. 2002;16(5):795-8. X-4, X-5, X-6. [pmid: 11997824].
698 Esposito C, Monguzzi G, Gonzalez-Sabin MA, et al. Results and complications of laparoscopic surgery for pediatric varicocele. J Pediatr Surg. May. 2001;36(5):767-9. X-2, X-3. [pmid: 11329585].
699 Esposito C, Monguzzi GL, Gonzalez-Sabin MA, et al. Laparoscopic treatment of pediatric varicocele: a multicenter study of the italian society of video surgery in infancy. J Urol. Jun. 2000;163(6):1944-6. X-2, X-3. [pmid: 10799235].
700 Esposito C, Valla JS, Yeung CK. Current indications for laparoscopy and retroperitoneoscopy in pediatric urology. Surgical Endoscopy. Nov. 2004;18(11):1559-1564. X-1, X-2. [pmid: 15931494].
701 Esposito C, Vallone G, Savanelli A, et al. Long-term outcome of laparoscopic Fowler-Stephens orchiopexy in boys with intra-abdominal testis. J Urol. Apr. 2009;181(4):1851-6. X-4, X-5, X-6. [pmid: 19233407].
702 Esposito C, Vallone G, Settimi A, et al. Laparoscopic orchiopexy without division of the spermatic vessels: can it be considered the procedure of choice in cases of intraabdominal testis?. Surg Endosc. Jul. 2000;14(7):658-60. X-4, X-5, X-6. [pmid: 10948304].
703 Esteves SC, Glina S. Recovery of spermatogenesis after microsurgical subinguinal varicocele repair in azoospermic men based on testicular histology. Int Braz J Urol. Nov–Dec. 2005;31(6):541-8. X-2, X-3. [pmid: 16386122].
704 Evans AE, D’Angio GJ, Snyder H. Selecting initial therapy for pediatric genitourinary cancers. Cancer. Aug. 1. 1987;60(3 Suppl):480-9. X-1, X-2, X-3. [pmid: 3036332].
705 Evenson DP, Klein FA, Whitmore WF, et al. Flow cytometric evaluation of sperm from patients with testicular carcinoma. J Urol. Dec. 1984;132(6):1220-5. X-2, X-3. [pmid: 6209425].
706 Ezra N, Afari A, Wong J. Pelvic and scrotal trauma: CT and triage of patients. Abdominal Imaging. July. 2009;34(4):541-544. X-2, X-3. [pmid: 18543018].
707 Facchinetti F, Bracci R, Sardelli S. Possible testicular 3beta-hydroxysteroid dehydrogenase deficiency in chryptorchid neonates. Archives of Andrology. 1983;10(3):253-259. X-3. [pmid: 6136257].
708 Fagerli J, Schneck FX, Lee PA, et al. Absence of microdeletions in the Y chromosome in patients with a history of cryptorchidism and azoospermia or oligospermia. Fertil Steril. Apr. 1999;71(4):697-700. X-2, X-3. [pmid: 10202881].
709 Fahlenkamp D, Rassweiler J, Fornara P, et al. Complications of laparoscopic procedures in urology: experience with 2,407 procedures at 4 German centers. J Urol. Sep. 1999;162(3 Pt 1):765-70. discussion 770–1. X-4, X-5, X-6. [pmid: 10458362].
710 Fahlenkamp D, Winfield HN, Schonberger B, et al. Role of laparoscopic surgery in pediatric urology. Eur Urol. 1997;32(1):75-84. X-4, X-5, X-6. [pmid: 9266236].
711 Fakhry J, Khoury A, Barakat K. The hypoechoic band: a normal finding on testicular sonography. AJR Am J Roentgenol. Aug. 1989;153(2):321-3. X-2, X-3. [pmid: 2665452].
712 Fallat ME, Skoog SJ, Belman AB, et al. The prune belly syndrome: a comprehensive approach to management. J Urol. Sep. 1989;142(3):802-5. X-4, X-5, X-6. [pmid: 2769864].
713 Fallon B, Welton M, Hawtrey C. Congenital anomalies associated with cryptorchidism. J Urol. Jan. 1982;127(1):91-3. X-3, X-4, X-5, X-6. [pmid: 6120246].
714 Farkas I, Szollosi J. Relationships between serum FSH level and the size of testis in azoospermic patients. Int Urol Nephrol. 1986;18(2):175-9. X-2, X-3. [pmid: 3087903].
715 Farooq O, Bashirur R. Recurrent inguinal hernia repair by open preperitoneal approach. J Coll Physicians Surg Pak. May. 2005;15(5):261-5. X-2, X-3. [pmid: 15907233].
716 Farr SA, Littlefield JL, Fletcher JW, et al. Testicular circulatory isolation in man: comparison of radionuclide angiography with Doppler evaluation. J Surg Oncol. Sep. 1993;54(1):57-9. X-2, X-3. [pmid: 8397326].
717 Favorito LA, Cavalcante AG, Babinski MA. Study on the incidence of testicular and epididymal appendages in patients with cryptorchidism. Int Braz J Urol. Jan–Feb. 2004;30(1):49-52. X-3. [pmid: 15707517].
718 Favorito LA, Cavalcante AL, Babinski MA. Study of the incidence of testicular and epididymal appendages in patients with cryptorchidism. International Braz J Urol. Jan. 2004;30(1):49-52. X-3. [pmid: 15707517].
719 Favorito LA, Costa WS, Sampaio FJ. Relationship between the persistence of the processus vaginalis and age in patients with cryptorchidism. Int Braz J Urol. Jan–Feb. 2005;31(1):57-61. X-3. [pmid: 15763011].
720 Favorito LA, Hidalgo A Jr, Pazos HM, et al. Stereological and morphometric analysis of collagen and seminiferous tubules in testes of patients with cryptorchidism submitted or not to treatment with human chorionic gonadotrophin. Int Braz J Urol. Nov–Dec. 2005;31(6):562-6. discussion 567–8. X-3. [pmid: 16386127].
721 Favorito LA, Klojda CA, Sampaio FJ. Congenital absence of the testis in human fetuses and in cryptorchid patients. Int J Urol. Dec. 2004;11(12):1110-3. X-3. [pmid: 15663684].
722 Favorito LA, Klojda CAB, Costa WS, et al. Is there a relationship with anomalous insertions of the distal gubernaculum testis and testicular ectopia? Analysis in human fetuses and patients with cryptorchidism. Journal of Urology. 01. Aug. 2003;170(21):554-557. X-2, X-3. [pmid: 12853828].
723 Favorito LA, Sampaio FJ, Javaroni V, et al. Proximal insertion of gubernaculum testis in normal human fetuses and in boys with cryptorchidism. J Urol. Sep. 2000;164(3 Pt 1):792-4. X-3. [pmid: 10953158].
724 Feber KM, Kass EJ. Varicocelectomy in adolescent boys: long-term experience with the Palomo procedure. J Urol. Oct. 2008;180(4 Suppl):1657-9. discussion 1659–60. X-2, X-3. [pmid: 18708215].
725 Fedder J. History of cryptorchidism and ejaculate volume as simple predictors for the presence of testicular sperm. Syst Biol Reprod Med. Jun. 2011;57(3):154-61. X-2, X-3. [pmid: 21284574].
726 Fedder J, Cruger D, Oestergaard B, et al. Etiology of azoospermia in 100 consecutive nonvasectomized men. Fertil Steril. Nov. 2004;82(5):1463-5. X-2, X-3. [pmid: 15533383].
727 Feitz WFJ, De Vries JDM. Pediatric urology and the daily medical practice: Way apart?. European Urology. 1995;28(2):158-160. X-2, X-3. [pmid: 8529743].
728 Feng S, Bogatcheva NV, Truong A, et al. Developmental expression and gene regulation of insulin-like 3 receptor RXFP2 in mouse male reproductive organs. Biol Reprod. Oct. 2007;77(4):671-80. X-2, X-3. [pmid: 17615407].
729 Fenichel P, Bstandig B, Roger C, et al. Unilateral testicular tumour associated to congenital adrenal hyperplasia: Failure of specific tumoral molecular markers to discriminate between adrenal rest and leydigioma. Ann Endocrinol (Paris). Nov. 2008;69(5):453-8. X-2, X-3. [pmid: 18620332].
730 Fenig DM, Snyder HM 3rd, Wu HY, et al. The histopathology of iatrogenic cryptorchid testis: an insight into etiology. J Urol. Apr. 2001;165(4):1258-61. X-3. [pmid: 11257697].
731 Ferguson-Smith MA. Putting medical genetics into practice. General Pathology and Pathological Anatomy. 2011;(12):1-23. X-1, X-2, X-3.
732 Ferlin A, Bogatcheva NV, Gianesello L, et al. Insulin-like factor 3 gene mutations in testicular dysgenesis syndrome: clinical and functional characterization. Mol Hum Reprod. Jun. 2006;12(6):401-6. X-3. [pmid: 16687567].
733 Ferlin A, Foresta C. Insulin-like factor 3: a novel circulating hormone of testicular origin in humans. Ann N Y Acad Sci. May. 2005;1041:497-505. X-2, X-3. [pmid: 15956751].
734 Ferlin A, Garolla A, Bettella A, et al. Androgen receptor gene CAG and GGC repeat lengths in cryptorchidism. European Journal of Endocrinology. Mar. 2005;152(3):419-425. X-2. [pmid: 15757859].
735 Ferlin A, Pepe A, Gianesello L, et al. New roles for INSL3 in adults. Ann N Y Acad Sci. Apr. 2009;1160:215-8. X-2, X-3. [pmid: 19416191].
736 Ferlin A, Simonato M, Bartoloni L, et al. The INSL3-LGR8/GREAT ligand-receptor pair in human cryptorchidism. J Clin Endocrinol Metab. Sep. 2003;88(9):4273-9. X-3. [pmid: 12970298].
737 Ferlin A, Zuccarello D, Garolla A, et al. Mutations in INSL3 and RXFP2 genes in cryptorchid boys. Ann N Y Acad Sci. Apr. 2009;1160:213-4. X-3. [pmid: 19416190].
738 Fernandez MF, Olmos B, Granada A, et al. Human exposure to endocrine-disrupting chemicals and prenatal risk factors for cryptorchidism and hypospadias: a nested case-control study. Environ Health Perspect. Dec. 2007;115(Suppl 1):8-14. X-3. [pmid: 18174944].
739 Ferrara P, Rossodivita A, Ruggiero A, et al. Cryptorchidism associated with meningomyelocele. J Paediatr Child Health. Feb. 1998;34(1):44-6. X-3. [pmid: 9568940].
740 Ferreira U, Netto Junior NR, Esteves SC, et al. Comparative study of the fertility potential of men with only one testis. Scand J Urol Nephrol. 1991;25(4):255-9. X-3. [pmid: 1685802].
741 Ferrer FA, Cadeddu JA, Schulam P, et al. Orchiopexy using 2 mm. laparoscopic instruments: 2 techniques for delivering the testis into the scrotum. J Urol. Jul. 2000;164(1):160-1. X-4, X-5, X-6. [pmid: 10840453].
742 Ferro F, Caterino S, Lais A. Testicular prosthesis in children: a simplified insertion technique. Eur Urol. 1991;19(3):230-2. X-2, X-3. [pmid: 1677334].
743 Ficarra V, Caleffi G, Mofferdin A, et al. Penetrating trauma to the scrotum and the corpora cavernosa caused by gunshot. Urologia Internationalis. Sep. 1999;62(3):192-194. X-2, X-3. [pmid: 10529675].
744 Fideleff H, Boquete H, Saskyn N, et al. Pubertal varicocele: correlation between clinical, Doppler, and hormonal findings. Fertil Steril. Mar. 1993;59(3):693-5. X-2, X-3. [pmid: 8458482].
745 Fideleff HL, Boquete HR, Suarez MG, et al. Controversies in the evolution of paediatric-adolescent varicocele: clinical, biochemical and histological studies. Eur J Endocrinol. Dec. 2000;143(6):775-81. X-2, X-3. [pmid: 11124861].
746 Filippi G, Pecile V, Rinaldi A, et al. Fragile-X mutation and Klinefelter syndrome: a reappraisal. Am J Med Genet. May–Jun. 1988;30(1–2):99-107. X-2, X-3. [pmid: 3177482].
747 Fillion C, Malassine A, Tahri-Joutei A, et al. Immunoreactive arginine vasopressin in the testis: Immunocytochemical localization and testicular content in normal and in experimental cryptorchid mouse. Biology of Reproduction. 1993;48(4):786-792. X-2, X-3. [pmid: 8097932].
748 Finkel DM, Phillips JL, Snyder PJ. Stimulation of spermatogenesis by gonadotropins in men with hypogonadotropic hypogonadism. N Engl J Med. Sep. 12. 1985;313(11):651-5. X-2, X-3. [pmid: 3927163].
749 Fiorelli C, Daniele G, Meliani E, et al. Surgical correction of failed orchiopexy in non pediatric age. Acta Urologica Italica. 1999;13(1):23-25. X-4, X-5, X-6.
750 Fisch H, Hyun G, Hensle TW. Testicular growth and gonadotrophin response associated with varicocele repair in adolescent males. BJU Int. Jan. 2003;91(1):75-8. X-2, X-3. [pmid: 12614255].
751 Fisher JS, Macpherson S, Marchetti N, et al. Human ‘testicular dysgenesis syndrome’: a possible model using in-utero exposure of the rat to dibutyl phthalate. Hum Reprod. Jul. 2003;18(7):1383-94. X-2, X-3. [pmid: 12832361].
752 Flati G, Porowska B, Flati D, et al. Improvement in the fertility rate after placement of microsurgical shunts in men with recurrent varicocele. Fertil Steril. Dec. 2004;82(6):1527-31. X-2, X-3. [pmid: 15589854].
753 Fogdestam I, Fall M, Nilsson S. Microsurgical epididymovasostomy in the treatment of occlusive azoospermia. Fertil Steril. Nov. 1986;46(5):925-9. X-2, X-3. [pmid: 3781009].
754 Fonger JD, Filler RM, Rider WD, et al. Testicular tumours in maldescended testes. Can J Surg. Jul. 1981;24(4):353-5. X-2, X-3. [pmid: 6115708].
755 Fonzo D, Manenti M, Varengo M, et al. Andrological and hormonal findings in subjects with ductus deferens agenesia. Andrologia. 1983;15(Spec No):614-8. X-2, X-3. [pmid: 6421195].
756 Foppiani L, Bernasconi D, Del Monte P, et al. Leydig cell tumour-induced bilateral gynaecomastia in a young man: endocrine abnormalities. Andrologia. Feb. 2005;37(1):36-9. X-2, X-3. [pmid: 15644061].
757 Foppiani L, Cavani S, Piredda S, et al. Lack of evidence of a genetic origin in the impaired spermatogenesis of a patient cohort with low-grade varicocele. J Endocrinol Invest. Apr. 2001;24(4):217-23. X-2, X-3. [pmid: 11383907].
758 Ford TF, Parkinson MC, Pryor JP. The undescended testis in adult life. Br J Urol. Apr. 1985;57(2):181-4. X-2, X-3. [pmid: 2859071].
759 Foresta C, Bettella A, Ferlin A, et al. Evidence for a stimulatory role of follicle-stimulating hormone on the spermatogonial population in adult males. Fertil Steril. Apr. 1998;69(4):636-42. X-2, X-3. [pmid: 9548151].
760 Foresta C, Bettella A, Merico M, et al. Use of recombinant human follicle-stimulating hormone in the treatment of male factor infertility. Fertil Steril. Feb. 2002;77(2):238-44. X-2, X-3. [pmid: 11821078].
761 Foresta C, Bettella A, Rossato M, et al. Inhibin B plasma concentrations in oligozoospermic subjects before and after therapy with follicle stimulating hormone. Hum Reprod. Apr. 1999;14(4):906-12. X-2, X-3. [pmid: 10221217].
762 Foresta C, Bettella A, Vinanzi C, et al. A novel circulating hormone of testis origin in humans. J Clin Endocrinol Metab. Dec. 2004;89(12):5952-8. X-2, X-3. [pmid: 15579743].
763 Foresta C, De Carlo E, Mioni R, et al. Sperm nuclear chromatin heterogeneity in infertile subjects. Andrologia. Jul–Aug. 1989;21(4):384-90. X-2, X-3. [pmid: 2571313].
764 Foresta C, Ferlin A. Role of INSL3 and LGR8 in cryptorchidism and testicular functions. Reprod Biomed Online. Sep. 2004;9(3):294-8. X-2, X-3. [pmid: 15353080].
765 Foresta C, Ferlin A, Garolla A, et al. High frequency of well-defined Y-chromosome deletions in idiopathic Sertoli cell-only syndrome. Hum Reprod. Feb. 1998;13(2):302-7. X-2, X-3. [pmid: 9557827].
766 Foresta C, Garolla A, Bettella A, et al. Doppler ultrasound of the testis in azoospermic subjects as a parameter of testicular function. Hum Reprod. Nov. 1998;13(11):3090-3. X-2, X-3. [pmid: 9853862].
767 Foresta C, Indino M, Mioni R, et al. Evidence of sperm nuclear chromatin heterogeneity in ex-cryptorchid subjects. Andrologia. Mar–Apr. 1987;19(2):148-52. X-2, X-3. [pmid: 2891322].
768 Foresta C, Moro E, Garolla A, et al. Y chromosome microdeletions in cryptorchidism and idiopathic infertility. J Clin Endocrinol Metab. Oct. 1999;84(10):3660-5. X-3. [pmid: 10523011].
769 Foresta C, Varotto A. Assessment of testicular cytology by fine needle aspiration as a diagnostic parameter in the evaluation of the oligospermic subject. Fertil Steril. Nov. 1992;58(5):1028-33. X-2, X-3. [pmid: 1426354].
770 Foresta C, Varotto A. Immunocytochemical localization of epidermal growth factor receptors in human testis from infertile subjects. Fertil Steril. May. 1994;61(5):941-8. X-2, X-3. [pmid: 8174734].
771 Foresta C, Varotto A, Scandellari C. Assessment of testicular cytology by fine needle aspiration as a diagnostic parameter in the evaluation of the azoospermic subject. Fertil Steril. Apr. 1992;57(4):858-65. X-2, X-3. [pmid: 1555700].
772 Foresta C, Zorzi M, Rossato M, et al. Sperm nuclear instability and staining with aniline blue: abnormal persistence of histones in spermatozoa in infertile men. Int J Androl. Aug. 1992;15(4):330-7. X-2, X-3. [pmid: 1516982].
773 Formanek A, Rusnak B, Zollikofer C, et al. Embolization of the spermatic vein for treatment of infertility: a new approach. Radiology. May. 1981;139(2):315-21. X-2, X-3. [pmid: 7220874].
774 Fornara P, Doehn C, Seyfarth M, et al. Why is urological laparoscopy minimally invasive?. Eur Urol. Mar. 2000;37(3):241-50. X-2, X-3. [pmid: 10720847].
775 Forsberg L, Dale L, Hoiem L, et al. Computed tomography in early stages of testicular carcinoma. Size of normal retroperitoneal lymph nodes and lymph nodes in patients with metastases in stage II A. A SWENOTECA study: Swedish-Norwegian Testicular Cancer Project. Acta Radiol Diagn (Stockh). Sep–Oct. 1986;27(5):569-74. X-2, X-3. [pmid: 3026141].
776 Forti G, Facchinetti F, Sardelli S, et al. Spermatic and peripheral venous plasma concentrations of progesterone, 17 alpha-hydroxyprogesterone, and 20 alpha-dihydroprogesterone in prepubertal boys. J Clin Endocrinol Metab. Apr. 1983;56(4):831-4. X-3, X-4, X-5, X-6. [pmid: 6833463].
777 Forti G, Facchinetti F, Sardelli S, et al. Spermatic and peripheral venous plasma concentrations of dehydroepiandrosterone sulfate in prepubertal and pubertal boys. J Steroid Biochem. Jan. 1983;18(1):29-32. X-3, X-4, X-5, X-6. [pmid: 6134865].
778 Fossa SD, Aabyholm T, Vespestad S, et al. Semen quality after treatment for testicular cancer. Eur Urol. 1993;23(1):172-6. X-2, X-3. [pmid: 8477777].
779 Fossa SD, Aass N, Heilo A, et al. Testicular carcinoma in situ in patients with extragonadal germ-cell tumours: the clinical role of pretreatment biopsy. Ann Oncol. Sep. 2003;14(9):1412-8. X-2, X-3. [pmid: 12954581].
780 Fossa SD, Chen J, Schonfeld SJ, et al. Risk of contralateral testicular cancer: a population-based study of 29,515 U.S. men. J Natl Cancer Inst. Jul. 20. 2005;97(14):1056-66. X-2, X-3. [pmid: 16030303].
781 Fossa SD, Klepp O, Ous S, et al. Unilateral retroperitoneal lymph node dissection in patients with non-seminomatous testicular tumor in clinical stage I. Eur Urol. 1984;10(1):17-23. X-2, X-3. [pmid: 6698081].
782 Fossa SD, Opjordsmoen S, Haug E. Androgen replacement and quality of life in patients treated for bilateral testicular cancer. Eur J Cancer. Aug. 1999;35(8):1220-5. X-2, X-3. [pmid: 10615233].
783 Fossa SD, Ous S, Abyholm T, et al. Post-treatment fertility in patients with testicular cancer. I. Influence of retroperitoneal lymph node dissection on ejaculatory potency. Br J Urol. Apr. 1985;57(2):204-9. X-2, X-3. [pmid: 2580586].
784 Fossa SD, Ous S, Stenwig AE, et al. Distribution of retroperitoneal lymph node metastases in patients with non-seminomatous testicular cancer in clinical stage I. Eur Urol. 1990;17(2):107-12. X-2, X-3. [pmid: 2155789].
785 Fossa SD, Silde J, Theodorsen L, et al. Pre-treatment DNA ploidy of sperm cells as a predictive parameter of post-treatment spermatogenesis in patients with testicular cancer. Br J Urol. Sep. 1994;74(3):359-65. X-2, X-3. [pmid: 7953268].
786 Foster CM, Feuillan P, Padmanabhan V, et al. Ovarian function in girls with McCune-Albright syndrome. Pediatr Res. Sep. 1986;20(9):859-63. X-2, X-3. [pmid: 3092175].
787 Foster RS, Donohue JP, Bihrle R. Stage A nonseminomatous testis carcinoma: rationale and results of nerve-sparing retroperitoneal lymphadenectomy. Urol Int. 1991;46(3):294-7. X-2, X-3. [pmid: 1656577].
788 Fowler JE Jr, Platoff GE, Kubrock CA, et al. Commercial radioimmunoassay for beta subunit of human chorionic gonadotropin: falsely positive determinations due to elevated serum luteinizing hormone. Cancer. Jan. 1. 1982;49(1):136-9. X-2, X-3. [pmid: 6797716].
789 Fraietta R, Spaine DM, Bertolla RP, et al. Individual and seminal characteristics of patients with testicular germ cell tumors. Fertil Steril. Nov. 2010;94(6):2107-12. X-2, X-3. [pmid: 20117767].
790 Fram RJ, Garnick MB, Retik A. The spectrum of genitourinary abnormalities in patients with cryptorchidism, with emphasis on testicular carcinoma. Cancer. Nov. 15. 1982;50(10):2243-6. X-3. [pmid: 6127155].
791 Franca MM, Jorge AA, Carvalho LR, et al. Novel heterozygous nonsense GLI2 mutations in patients with hypopituitarism and ectopic posterior pituitary lobe without holoprosencephaly. J Clin Endocrinol Metab. Nov. 2010;95(11):E384-91. X-2, X-3. [pmid: 20685856].
792 Franc-Guimond J, Kryger J, Gonzalez R. Experience with the Bailez technique for laparoscopic access in children. J Urol. Sep. 2003;170(3):936-8. X-4, X-5, X-6. [pmid: 12913745].
793 Franco I, Kogan S, Fisher J, et al. Genitourinary malformations associated with agenesis of the corpus callosum. J Urol. May. 1993;149(5):1119-21. X-2, X-3. [pmid: 8483226].
794 Franneby U, Sandblom G, Nyren O, et al. Self-reported adverse events after groin hernia repair, a study based on a national register. Value Health. Sep–Oct. 2008;11(5):927-32. X-2, X-3. [pmid: 18489521].
795 Frates MC, Benson CB, DiSalvo DN, et al. Solid extratesticular masses evaluated with sonography: pathologic correlation. Radiology. Jul. 1997;204(1):43-6. X-2, X-3. [pmid: 9205221].
796 Freiha FS, Shortliffe LD, Rouse RV, et al. The extent of surgery after chemotherapy for advanced germ cell tumors. J Urol. Nov. 1984;132(5):915-7. X-2, X-3. [pmid: 6208386].
797 Freund I, Zenzes MT, Muller RP, et al. Testicular function in eight patients with seminoma after unilateral orchidectomy and radiotherapy. Int J Androl. Apr. 1987;10(2):447-55. X-2, X-3. [pmid: 3112028].
798 Frey P, Bianchi A. Microvascular orchiopexy. Eur J Pediatr. Suppl 2. 1987;146:S51-2. X-3, X-4, X-5, X-6. [pmid: 2891524].
799 Frey P, Bianchi A. Microvascular autotransplantation of intra-abdominal testes. Prog Pediatr Surg. 1989;23:115-25. X-3, X-4, X-5, X-6. [pmid: 2567042].
800 Friedman RM. The role of the testicles in male psychological development. Journal of the American Psychoanalytic Association. 1996;44(1):201-253. X-1, X-2, X-3. [pmid: 8717484].
801 Friedman RM, Lopez FJ, Tucker JA, et al. Fertility after cryptorchidism: a comparative analysis of early orchidopexy with and without concomitant hormonal therapy in the young male rat. J Urol. Jan. 1994;151(1):227-33. X-2, X-3. [pmid: 7902876].
802 Frydelund-Larsen L, Krausz C, Leffers H, et al. Inhibin B: a marker for the functional state of the seminiferous epithelium in patients with azoospermia factor C microdeletions. J Clin Endocrinol Metab. Dec. 2002;87(12):5618-24. X-2, X-3. [pmid: 12466362].
803 Fuchs E, Hatch T, Seifert A. Extragonadal germ cell tumor: The preoperative urological evaluation. Journal of Urology. 1987;137(5):993-995. X-2, X-3. [pmid: 3033336].
804 Fujisawa M, Yamazaki I, Dobashi M, et al. Serum inhibin pro alphaC in infertile men. Arch Androl. Nov–Dec. 2001;47(3):191-4. X-2, X-3. [pmid: 11695842].
805 Fuller AF Jr, Budzik GP, Krane IM, et al. Mullerian inhibiting substance inhibition of a human endometrial carcinoma cell line xenografted in nude mice. Gynecol Oncol. Jan. 1984;17(1):124-32. X-2, X-3. [pmid: 6546372].
806 Funke S, Flach E, Kiss I, et al. Male reproductive tract abnormalities: more common after assisted reproduction?. Early Hum Dev. Sep. 2010;86(9):547-50. X-3. [pmid: 20674196].
807 Furman WL, Fontanesi J, Hustu O, et al. Testicular relapse in children with acute nonlymphoblastic leukemia. Cancer. 1990;66(10):2095-2098. X-2, X-3. [pmid: 2224763].
808 Gabel P, Jensen MS, Andersen HR, et al. The risk of cryptorchidism among sons of women working in horticulture in Denmark: A cohort study. Environmental Health: A Global Access Science Source. 2011;10(1 100). X-2, X-3.
809 Galan JJ, Guarducci E, Nuti F, et al. Molecular analysis of estrogen receptor alpha gene AGATA haplotype and SNP12 in European populations: potential protective effect for cryptorchidism and lack of association with male infertility. Hum Reprod. Feb. 2007;22(2):444-9. X-2, X-3. [pmid: 17099213].
810 Gallagher RP, Huchcroft S, Phillips N, et al. Physical activity, medical history, and risk of testicular cancer (Alberta and British Columbia, Canada). Cancer Causes Control. Sep. 1995;6(5):398-406. X-2, X-3. [pmid: 8547537].
811 Galvin DJ, Bredin H. The role of laparoscopy in the management of the impalpable testicle. Ir J Med Sci. Apr–Jun. 2002;171(2):73-5. X-4, X-5, X-6. [pmid: 12173892].
812 Ganem JP, Workman KR, Shaban SF. Testicular microlithiasis is associated with testicular pathology. Urology. Jan. 1999;53(1):209-213. X-2, X-3. [pmid: 9886614].
813 Garcia-Gonzalez R, Pinto J, Val-Bernal JF. Testicular metastases from solid tumors: an autopsy study. Ann Diagn Pathol. Apr. 2000;4(2):59-64. X-2, X-3. [pmid: 10760317].
814 Garcia-Rodriguez J, Garcia-Martin M, Nogueras-Ocana M, et al. Exposure to pesticides and cryptorchidism: geographical evidence of a possible association. Environ Health Perspect. Oct. 1996;104(10):1090-5. X-3, X-4, X-5, X-6. [pmid: 8930551].
815 Garel L, Dubois J, Azzie G, et al. Preoperative manual detorsion of the spermatic cord with Doppler ultrasound monitoring in patients with intravaginal acute testicular torsion. Pediatr Radiol. Jan. 2000;30(1):41-4. X-2, X-3. [pmid: 10663509].
816 Garibyan H. Use of laparoscopy for the localization of impalpable testes. Neth J Surg. Apr. 1987;39(2):68-71. X-4, X-5, X-6. [pmid: 2884601].
817 Garibyan H, Hazebroek FW, Schulkes JA, et al. Microvascular surgical orchiopexy in the treatment of high-lying undescended testes. Br J Urol. Jun. 1984;56(3):326-9. X-4, X-5, X-6. [pmid: 6152716].
818 Garland SM, Ault KA, Gall SA, et al. Pregnancy and infant outcomes in the clinical trials of a human papillomavirus type 6/11/16/18 vaccine: A combined analysis of five randomized controlled trials. Obstetrics and Gynecology. December. 2009;114(6):1179-1188. X-3. [pmid: 19935017].
819 Garlantezec R, Monfort C, Rouget F, et al. Maternal occupational exposure to solvents and congenital malformations: A prospective study in the general population. Occupational and Environmental Medicine. July. 2009;66(7):456-463. X-3. [pmid: 19541806].
820 Garolla A, Ferlin A, Vinanzi C, et al. Molecular analysis of the androgen receptor gene in testicular cancer. Endocr Relat Cancer. Sep. 2005;12(3):645-55. X-2, X-3. [pmid: 16172197].
821 Gaspari L, Paris F, Philibert P, et al. ‘Idiopathic’ partial androgen insensitivity syndrome in 28 newborn and infant males: impact of prenatal exposure to environmental endocrine disruptor chemicals?. Eur J Endocrinol. Oct. 2011;165(4):579-87. X-2, X-3. [pmid: 21788424].
822 Gat Y, Bachar GN, Everaert K, et al. Induction of spermatogenesis in azoospermic men after internal spermatic vein embolization for the treatment of varicocele. Hum Reprod. Apr. 2005;20(4):1013-7. X-2, X-3. [pmid: 15618245].
823 Gat Y, Bachar GN, Zukerman Z, et al. Varicocele: a bilateral disease. Fertil Steril. Feb. 2004;81(2):424-9. X-2, X-3. [pmid: 14967384].
824 Gat Y, Gornish M, Chakraborty J, et al. Azoospermia and maturation arrest: malfunction of valves in erect poster of humans leads to hypoxia in sperm production site. Andrologia. Dec. 2010;42(6):389-94. X-2, X-3. [pmid: 21105890].
825 Gat Y, Gornish M, Navon U, et al. Right varicocele and hypoxia, crucial factors in male infertility: fluid mechanics analysis of the impaired testicular drainage system. Reprod Biomed Online. Oct. 2006;13(4):510-5. X-2, X-3. [pmid: 17007671].
826 Gat Y, Gornish M, Perlow A, et al. Azoospermia and Sertoli-cell-only syndrome: hypoxia in the sperm production site due to impairment in venous drainage of male reproductive system. Andrologia. Oct. 2010;42(5):314-21. X-2, X-3. [pmid: 20860630].
827 Gat Y, Zukerman Z, Chakraborty J, et al. Varicocele, hypoxia and male infertility. Fluid Mechanics analysis of the impaired testicular venous drainage system. Hum Reprod. Sep. 2005;20(9):2614-9. X-2, X-3. [pmid: 15932914].
828 Gat Y, Zukerman ZV, Bachar GN, et al. Adolescent varicocele: is it a unilateral disease?. Urology. Oct. 2003;62(4):742-6. discussion 746–7. X-2, X-3. [pmid: 14550455].
829 Gatti JM, Kirsch AJ, Troyer WA, et al. Increased incidence of hypospadias in small-for-gestational age infants in a neonatal intensive-care unit. BJU Int. Apr. 2001;87(6):548-50. X-2, X-3. [pmid: 11298055].
830 Gauderer MW. Gastroschisis and extraabdominal ectopic testis: simultaneous repair. J Pediatr Surg. Jul. 1987;22(7):657-9. X-2, X-3. [pmid: 2886577].
831 Gaudino R, Cavarzere P, Camilot M, et al. Prepubertal serum inhibin B in cryptorchid infants and in monorchid boys with compensatory testicular hypertrophy. Fertil Steril. Dec. 2008;90(6):2217-21. X-3. [pmid: 18191850].
832 Gaudio E, Paggiarino D, Carpino F. Structural and ultrastructural modifications of cryptorchid human testes. J Urol. Feb. 1984;131(2):292-6. X-3. [pmid: 6142123].
833 Gauwitz MD, Zagars GK. Treatment of seminoma arising in cryptorchid testes. Int J Radiat Oncol Biol Phys. 1992;24(1):153-9. X-3. [pmid: 1355081].
834 Gazzera C, Rampado O, Savio L, et al. Radiological treatment of male varicocele: technical, clinical, seminal and dosimetric aspects. Radiol Med. Apr. 2006;111(3):449-58. X-2, X-3. [pmid: 16683090].
835 Geczi L, Gomez F, Bak M, et al. The incidence, prognosis, clinical and histological characteristics, treatment, and outcome of patients with bilateral germ cell testicular cancer in Hungary. J Cancer Res Clin Oncol. May. 2003;129(5):309-15. X-2, X-3. [pmid: 12748851].
836 Geczi L, Gomez F, Horvath Z, et al. Three-year results of the first educational and early detection program for testicular cancer in Hungary. Oncology. 2001;60(3):228-34. X-2, X-3. [pmid: 11340374].
837 Geiger J, Epelman M, Darge K. The fountain sign: a novel color Doppler sonographic finding for the diagnosis of acute idiopathic scrotal edema. J Ultrasound Med. Aug. 2010;29(8):1233-7. X-2, X-3. [pmid: 20660458].
838 Gentile DP, Cockett AT. The effect of varicocelectomy on testicular volume in 89 infertile adult males with varicoceles. Fertil Steril. Jul. 1992;58(1):209-11. X-2, X-3. [pmid: 1624010].
839 Georgiadis E, Papandreou L, Evangelopoulou C, et al. Incidence of gynaecomastia in 954 young males and its relationship to somatometric parameters. Ann Hum Biol. Nov–Dec. 1994;21(6):579-87. X-2, X-3. [pmid: 7840497].
840 Gerber GS, Bissada NK, Hulbert JC, et al. Laparoscopic retroperitoneal lymphadenectomy: multi-institutional analysis. J Urol. Oct. 1994;152(4):1188-91. discussion 1191–2. X-2, X-3. [pmid: 8072092].
841 Gerber GS, Rukstalis DB, Levine LA, et al. Current and future roles of laparoscopic surgery in urology. Urology. Jan. 1993;41(1 Suppl):5-9. X-1, X-2, X-3. [pmid: 7678363].
842 Gerber GS, Stockton BR. Laparoscopy. Journal of Endourology. Oct. 2005;19(8):931-933. X-1, X-2, X-3. [pmid: 16253053].
843 Germa-Lluch JR, Garcia del Muro X, Maroto P, et al. Clinical pattern and therapeutic results achieved in 1490 patients with germ-cell tumours of the testis: the experience of the Spanish Germ-Cell Cancer Group (GG). Eur Urol. Dec. 2002;42(6):553-62. discussion 562–3. X-2, X-3. [pmid: 12477650].
844 Gerscovich EO. High-resolution ultrasonography in the diagnosis of scrotal pathology: I. Normal scrotum and benign disease. Journal of Clinical Ultrasound. 1993;21(6):355-373. X-1. [pmid: 8227378].
845 Gershbein AB, Horowitz M, Glassberg KI. The adolescent varicocele I: left testicular hypertrophy following varicocelectomy. J Urol. Oct. 1999;162(4):1447-9. X-2, X-3. [pmid: 10492236].
846 Gershman ST, Stolley PD. A case-control study of testicular cancer using Connecticut tumour registry data. International Journal of Epidemiology. 1988;17(4):738-742. X-2, X-3. [pmid: 3225080].
847 Gervain M, Palmai S. The management of retained testis based on our investigations. Acta Chir Hung. 1988;29(2):117-29. X-3, X-4, X-5, X-6. [pmid: 2902720].
848 Geysenbergh B, De Catte L, Vogels A. Can fetal ultrasound result in prenatal diagnosis of Prader-Willi syndrome?. Genetic Counseling. 2011;22(2):207-216. X-2, X-3. [pmid: 21848014].
849 Ghazzal AM. Inguinal hernias and genital abnormalities in young Jordanian males. East Mediterr Health J. May–Jul. 2006;12(3–4):483-8. X-2, X-3. [pmid: 17037720].
850 Gheri G, Sgambati E, Thyrion GD, et al. The oligosaccharidic content of the glycoconjugates of the prepubertal descended and undescended testis: lectin histochemical study. Ital J Anat Embryol. Apr–Jun. 2004;109(2):69-84. X-2, X-3. [pmid: 15481156].
851 Ghizzoni L, Mastorakos G, Vottero A, et al. Corticotropin-releasing hormone (CRH) inhibits steroid biosynthesis by cultured human granulosa-lutein cells in a CRH and interleukin-1 receptor-mediated fashion. Endocrinology. Nov. 1997;138(11):4806-11. X-2, X-3. [pmid: 9348209].
852 Giachini C, Nuti F, Marinari E, et al. Partial AZFc deletions in infertile men with cryptorchidism. Hum Reprod. Sep. 2007;22(9):2398-403. X-3. [pmid: 17609244].
853 Giagulli VA, Vermeulen A. Leydig cell function in infertile men with idiopathic oligospermic infertility. J Clin Endocrinol Metab. Jan. 1988;66(1):62-7. X-2, X-3. [pmid: 2891722].
854 Giannattasio A, De Rosa M, Smeraglia R, et al. Glutathione peroxidase (GPX) activity in seminal plasma of healthy and infertile males. Journal of Endocrinological Investigation. Dec. 2002;25(11):983-986. X-2, X-3. [pmid: 12553559].
855 Gibbons JJ, Parra RO, Andriole GL, et al. Testicular circulatory isolation: a phase I study. Surg Oncol. Dec. 1992;1(6):413-6. X-2, X-3. [pmid: 1341279].
856 Gidai J, Acs N, Banhidy F, et al. No association found between use of very large doses of diazepam by 112 pregnant women for a suicide attempt and congenital abnormalities in their offspring. Toxicol Ind Health. Feb–Mar. 2008;24(1–2):29-39. X-2, X-3. [pmid: 18818179].
857 Gililland A, Carlan SJ, Greenbaum LD, et al. Undescended testicle and a meconium-filled hemiscrotum: prenatal ultrasound appearance. Ultrasound Obstet Gynecol. Aug. 2002;20(2):200-2. X-3, X-4, X-5, X-6. [pmid: 12153675].
858 Gill IS, Ross JH, Sung GT, et al. Needlescopic surgery for cryptorchidism: the initial series. J Pediatr Surg. Oct. 2000;35(10):1426-30. X-4, X-5, X-6. [pmid: 11051142].
859 Girardin CM, Lemyre E, Alos N, et al. Comparison of adolescents with Klinefelter syndrome according to the circumstances of diagnosis: Amniocentesis versus clinical signs. Hormone Research. August. 2009;72(2):98-105. X-2, X-3. [pmid: 19690427].
860 Giseke S, Glass M, Tapadar P, et al. A true laparoscopic herniotomy in children: evaluation of long-term outcome. J Laparoendosc Adv Surg Tech A. Mar. 2010;20(2):191-4. X-2, X-3. [pmid: 19943782].
861 Giusti G, Beltrami P, Tallarigo C, et al. Unilateral laparoscopic retroperitoneal lymphadenectomy for clinical stage I nonseminomatous testicular cancer. J Endourol. Dec. 1998;12(6):561-6. X-2, X-3. [pmid: 9895263].
862 Giwercman A, Berthelsen JG, Muller J, et al. Screening for carcinoma-in-situ of the testis. Int J Androl. Feb. 1987;10(1):173-80. X-2, X-3. [pmid: 2884183].
863 Giwercman A, Thomsen JK, Hertz J, et al. Prevalence of carcinoma in situ of the testis in 207 oligozoospermic men from infertile couples: prospective study of testicular biopsies. BMJ. Oct. 18. 1997;315(7114):989-91. X-2, X-3. [pmid: 9365296].
864 Giwercman A, von der Maase H, Berthelsen JG, et al. Localized irradiation of testes with carcinoma in situ: effects on Leydig cell function and eradication of malignant germ cells in 20 patients. J Clin Endocrinol Metab. Sep. 1991;73(3):596-603. X-2, X-3. [pmid: 1908483].
865 Glanzmann C, Schultz G, Lutolf UM. Long-term morbidity of adjuvant infradiaphragmatic irradiation in patients with testicular cancer and implications for the treatment of stage I seminoma. Radiotherapy and Oncology. 1991;22(1):12-18. X-2, X-3. [pmid: 1947208].
866 Glassberg KI, Badalato GM, Poon SA, et al. Evaluation and management of the persistent/recurrent varicocele. Urology. May. 2011;77(5):1194-8. X-2, X-3. [pmid: 21256543].
867 Glassow F. Inguinal hernia repair using local anaesthesia. Ann R Coll Surg Engl. Nov. 1984;66(6):382-7. X-2, X-3. [pmid: 6391342].
868 Glavind K, Lauritsen NR, Klove-Mogensen M, et al. The effect of vasectomy on the production of plasma luteinizing hormone and follicle stimulating hormone in man. Int Urol Nephrol. 1990;22(6):553-9. X-2, X-3. [pmid: 2128770].
869 Go RS, Gundrum JD. Uncertainty and discordance in the staging and prognosis of diffuse large B-cell lymphoma with isolated bilateral testicular involvement. American Journal of Hematology. November. 2009;84(11):762-763. X-2, X-3. [pmid: 19856427].
870 Gokcora IH. Low inguinal groove incision for indirect inguinal hernias in girls: a preliminary report on an incisional proposal. J Am Coll Surg. Oct. 1996;183(4):384-6. X-2, X-3. [pmid: 8843268].
871 Gokcora IH, Yagmurlu A. A novel incision for groin pathologies in children: the low inguinal groove approach. Hernia. Sep. 2003;7(3):146-9. X-4, X-5, X-6. [pmid: 12802620].
872 Goldblatt PJ, Gunning WT. Ultrastructure of the interstitial cells of Leydig, stimulated and unstimulated. Ann Clin Lab Sci. Nov–Dec. 1985;15(6):441-50. X-2, X-3. [pmid: 2865929].
873 Goldstein M, Eid JF. Elevation of intratesticular and scrotal skin surface temperature in men with varicocele. J Urol. Sep. 1989;142(3):743-5. X-2, X-3. [pmid: 2769853].
874 Goldstein M, Gilbert BR, Dicker AP, et al. Microsurgical inguinal varicocelectomy with delivery of the testis: an artery and lymphatic sparing technique. J Urol. Dec. 1992;148(6):1808-11. X-2, X-3. [pmid: 1433614].
875 Goldwasser B, Weissenberg R, Lunenfeld B, et al. Semen quality and hormonal status of patients following testicular torsion. Andrologia. May–Jun. 1984;16(3):239-43. X-2, X-3. [pmid: 6431848].
876 Goluboff ET, Chang DT, Kirsch AJ, et al. Incidence of external spermatic veins in patients undergoing inguinal varicocelectomy. Urology. Dec. 1994;44(6):893-6. X-2, X-3. [pmid: 7985318].
877 Gomez-Roman JJ, Mayorga M, Mira C, et al. Glandular inclusions in inguinal hernia sacs: a clinicopathological study of six cases. Pediatr Pathol. Nov–Dec. 1994;14(6):1043-9. X-2, X-3. [pmid: 7855006].
878 Gong Y, Han XD. Effect of nonylphenol on steroidogenesis of rat Leydig cells. J Environ Sci Health B. 2006;41(5):705-15. X-2, X-3. [pmid: 16785177].
879 Gonzalez Buitrago JM, Miralles JM, Munoz MH, et al. Seminal plasma creatine kinase activity in fertility studies. Arch Androl. Dec. 1980;5(4):355-60. X-2, X-3. [pmid: 7447536].
880 Gonzalez-Andrade F, Lopez-Pulles R. Congenital malformations in Ecuadorian children: Urgent need to create a National Registry of Birth Defects. Application of Clinical Genetics. 2010;3:29-39. X-3.
881 Gordon M, Cervellione RM, Morabito A, et al. 20 years of transcrotal orchidopexy for undescended testis: Results and outcomes. Journal of Pediatric Urology. 2010;6(5):506-512. X-4, X-5, X-6. [pmid: 19942483].
882 Gorlov IP, Kamat A, Bogatcheva NV, et al. Mutations of the GREAT gene cause cryptorchidism. Hum Mol Genet. Sep. 15. 2002;11(19):2309-18. X-3. [pmid: 12217959].
883 Gorsler CM, Schier F. Laparoscopic herniorrhaphy in children. Surg Endosc. Apr. 2003;17(4):571-3. X-2, X-3. [pmid: 12582768].
884 Goto H, Kanematsu A, Yoshimura K, et al. Preoperative diagnosis of congenital segmental giant megaureter presenting as a fetal abdominal mass. J Pediatr Surg. Jan. 2010;45(1):269-71. X-2, X-3. [pmid: 20105619].
885 Gotoh M, Miyake K, Mitsuya H. Leydig cell hyperplasia in cryptorchid patients: quantitative evaluation of Leydig cells in undescended and contralateral scrotal testes. Urol Res. 1984;12(3):159-64. X-2, X-3. [pmid: 6148797].
886 Gotoh M, Miyake K, Mitsuya H. Elastic fibers in tunica propria of undescended and contralateral scrotal testes from cryptorchid patients. Urology. Oct. 1987;30(4):359-63. X-3. [pmid: 2889283].
887 Gotoh M, Miyake K, Mitsuya H. A study of cryptorchidism. III: The histochemistry of complex carbohydrates in the testes of cryptorchid patients. Hinyokika Kiyo. Jun. 1987;33(6):905-14. X-3. [pmid: 2890287].
888 Gotoh M, Miyake K, Mitsuya H, et al. Cytoplasmic inclusion bodies in Leydig cells from the testes of postpubertal cryptorchid patients. Int J Androl. Jun. 1983;6(3):221-8. X-3. [pmid: 6136466].
889 Goulis DG, Iliadou PK, Tsametis C, et al. Serum anti-Mullerian hormone levels differentiate control from subfertile men but not men with different causes of subfertility. Gynecol Endocrinol. Mar. 2008;24(3):158-60. X-2, X-3. [pmid: 17926161].
890 Goulis DG, Tsametis C, Iliadou PK, et al. Serum inhibin B and anti-Mullerian hormone are not superior to follicle-stimulating hormone as predictors of the presence of sperm in testicular fine-needle aspiration in men with azoospermia. Fertil Steril. Apr. 2009;91(4):1279-84. X-2, X-3. [pmid: 18321497].
891 Govaerts L, Monnens L, Tegelaers W. Cerebro-hepato-renal syndrome of Zellweger: Clinical symptoms and relevant laboratory findings in 16 patients. European Journal of Pediatrics. 1982;139(2):125-128. X-2, X-3. [pmid: 7151832].
892 Gozdasoglu S, Cavdar AO, Babacan E, et al. Late effects of chemoradiotherapy in pediatric Hodgkin’s disease. J Chemother. Oct. 1995;7(5):463-6. X-2, X-3. [pmid: 8596134].
893 Grady RW, Mitchell ME, Carr MC. Laparoscopic and histologic evaluation of the inguinal vanishing testis. Urology. Nov. 1998;52(5):866-869. X-4, X-5, X-6. [pmid: 9801116].
894 Grangeia A, Carvalho F, Fernandes S, et al. A novel missense mutation P1290S at exon-20 of the CFTR gene in a Portuguese patient with congenital bilateral absence of the vas deferens. Fertility and Sterility. Feb. 2005;83(2):448-451. X-2, X-3. [pmid: 15705389].
895 Grant CS, Carney JA, Carpenter PC, et al. Primary pigmented nodular adrenocortical disease: diagnosis and management. Surgery. Dec. 1986;100(6):1178-84. X-2, X-3. [pmid: 3787476].
896 Gray LE Jr, Ostby J, Furr J, et al. Perinatal exposure to the phthalates DEHP, BBP, and DINP, but not DEP, DMP, or DOTP, alters sexual differentiation of the male rat. Toxicol Sci. Dec. 2000;58(2):350-65. X-2, X-3. [pmid: 11099647].
897 Green DM, Breslow NE, Beckwith JB, et al. Screening of children with hemihypertrophy, aniridia, and Beckwith-Wiedemann syndrome in patients with Wilms tumor: a report from the National Wilms Tumor Study. Med Pediatr Oncol. 1993;21(3):188-92. X-2, X-3. [pmid: 8095320].
898 Green NE, Lowery ER, Thomas R. Orthopaedic aspects of prune belly syndrome. Journal of Pediatric Orthopaedics. 1993;13(4):496-501. X-2, X-3. [pmid: 8370783].
899 Greene S, Zachmann M, Manella B, et al. Comparison of two tests to recognize or exclude 5 alpha-reductase deficiency in prepubertal children. Acta Endocrinol (Copenh). Jan. 1987;114(1):113-7. X-2, X-3. [pmid: 2880442].
900 Greene SA, Frank M, Zachmann M, et al. Growth and sexual development in children with meningomyelocele. Eur J Pediatr. Jul. 1985;144(2):146-8. X-2, X-3. [pmid: 2864250].
901 Greenfield SP, Seville P, Wan J. Experience with varicoceles in children and young adults. J Urol. Oct. 2002;168(4 Pt 2):1684-8. discussion 1688. X-2, X-3. [pmid: 12352334].
902 Greenswag LR. Adults with Prader-Willi syndrome: a survey of 232 cases. Dev Med Child Neurol. Apr. 1987;29(2):145-52. X-2, X-3. [pmid: 3582784].
903 Grigor KM, Giwercman A. Hormones and growth factors in germ cell neoplasia: general discussion. Eur Urol. 1993;23(1):89-92. X-1, X-2, X-3. [pmid: 8386661].
904 Grigor KM, Rorth M. Should the contralateral testis be biopsied? Round table discussion. Eur Urol. 1993;23(1):129-35. X-2, X-3. [pmid: 8477772].
905 Grimbizis G, Mikos T, Pantazis K, et al. ThinPrep are superior to conventional smears in the cytological diagnosis of subfertile men by testicular fine-needle aspiration. Diagnostic Cytopathology. Jan. 2008;36(1):1-7. X-2, X-3. [pmid: 18064691].
906 Grinspon RP, Bedecarras P, Ballerini MG, et al. Early onset of primary hypogonadism revealed by serum anti-Mullerian hormone determination during infancy and childhood in trisomy 21. Int J Androl. Oct. 2011;34(5 Pt 2):e487-98. X-2, X-3. [pmid: 21831236].
907 Grober ED, O’Brien J, Jarvi KA, et al. Preservation of testicular arteries during subinguinal microsurgical varicocelectomy: clinical considerations. J Androl. Sep–Oct. 2004;25(5):740-3. X-2, X-3. [pmid: 15292104].
908 Grunberger I, Suhrland MJ, Greco MA, et al. Effects of ultrasound on ultrastructure of human testes. Urology. Sep. 1987;30(3):201-2. X-2, X-3. [pmid: 3629760].
909 Grundy RG, Pritchard J, Baraitser M, et al. Perlman and Wiedemann-Beckwith syndromes: two distinct conditions associated with Wilms’ tumour. Eur J Pediatr. Dec. 1992;151(12):895-8. X-2, X-3. [pmid: 1361910].
910 Guarino N, Tadini B, Bianchi M. The adolescent varicocele: the crucial role of hormonal tests in selecting patients with testicular dysfunction. J Pediatr Surg. Jan. 2003;38(1):120-3. discussion 120–3. X-2, X-3. [pmid: 12592633].
911 Guarino N, Tadini B, Camardi P, et al. The incidence of associated urological abnormalities in children with renal ectopia. J Urol. Oct. 2004;172(4 Pt 2):1757-9. discussion 1759. X-2, X-3. [pmid: 15371807].
912 Guerin JF, Rozycka M, Lenczowski S, et al. Objective evaluation of fibrosis in human testicular biopsies by analysis based on optical diffractometry. Acta Anat (Basel). 1986;125(2):88-92. X-2, X-3. [pmid: 3953256].
913 Guerra Junior G, de Mello MP, Assumpcao JG, et al. True hermaphrodites in the southeastern region of Brazil: a different cytogenetic and gonadal profile. J Pediatr Endocrinol Metab. Jul–Aug. 1998;11(4):519-24. X-2, X-3. [pmid: 9777572].
914 Gul A, Cebeci A, Erol O, et al. Prenatal diagnosis of 13q-syndrome in a fetus with Dandy-Walker malformation. Obstetrics and Gynecology. May. 2005;105(5 II):1227-1229. X-2, X-3. [pmid: 15863591].
915 Guminska A, Oszukowska E, Kuzanski W, et al. Less advanced testicular dysgenesis is associated by a higher prevalence of germ cell neoplasia. Int J Androl. Feb. 2010;33(1):e153-62. X-2, X-3. [pmid: 19719533].
916 Gundy S, Babosa M, Baki M, et al. Increased predisposition to cancer in brothers and offspring of testicular tumor patients. Pathol Oncol Res. 2004;10(4):197-203. X-2, X-3. [pmid: 15619639].
917 Gunel M, Cavkaytar S, Ceylaner G, et al. Azoospermia and cryptorchidism in a male with a de novo reciprocal t(Y;16) translocation. Genet Couns. 2008;19(3):277-80. X-2, X-3. [pmid: 18990982].
918 Gupta N, Rajwanshi A, Srinivasan R, et al. Pathology of supraclavicular lymphadenopathy in Chandigarh, north India: an audit of 200 cases diagnosed by needle aspiration. Cytopathology. Apr. 2006;17(2):94-6. X-2, X-3. [pmid: 16548994].
919 Gurbuz N, Ozbay B, Aras B, et al. Do microdeletions in the AZF region of the Y chromosome accompany cryptorchidism in Turkish children?. International Urology and Nephrology. September. 2008;40(3):577-581. X-3. [pmid: 18075781].
920 Gurkaynak M, Akyol F, Zorlu F, et al. Stage I testicular seminoma: para-aortic and iliac irradiation with reduced dose after orchiectomy. Urol Int. 2003;71(4):385-8. X-2, X-3. [pmid: 14646438].
921 Gurocak S, Yilmaz A, Alp E, et al. Inflammation and oxidative stress in testicular torsion: Do they deserve intensive treatment to save both guilty and innocent testes?. Urology. July. 2011;78(1):164-169. X-2, X-3. [pmid: 21420155].
922 Gustafson ML, Lee MM, Asmundson L, et al. Mullerian inhibiting substance in the diagnosis and management of intersex and gonadal abnormalities. J Pediatr Surg. Mar. 1993;28(3):439-44. X-3. [pmid: 8468660].
923 Gutierrez A, Campos A, Canizares FJ, et al. Anatomical and clinical correlation with histological and histometric patterns in cryptorchism. Br J Urol. Oct. 1993;72(4):506-9. X-3. [pmid: 7903194].
924 Haas GG Jr. Antibody-mediated causes of male infertility. Urol Clin North Am. Aug. 1987;14(3):539-50. X-2, X-3. [pmid: 2887052].
925 Haas RJ, Schmidt P, Gobel U, et al. Treatment of malignant testicular tumors in childhood: results of the German National Study 1982–1992. Med Pediatr Oncol. 1994;23(5):400-5. X-2, X-3. [pmid: 7521931].
926 Hack WW, Meijer RW, Bos SD, et al. A new clinical classification for undescended testis. Scand J Urol Nephrol. 2003;37(1):43-7. X-1, X-2, X-3. [pmid: 12745743].
927 Hack WWM, Goede J, van der Voort-Doedens LM, et al. Acquired undescended testis: Putting the pieces together. International Journal of Andrology. February. 2012;35(1):41-45. X-1, X-2, X-3. [pmid: 21651571].
928 Hacker-Kolm U, Kleinhans G, Gohde W. Flow cytometric analysis of the maldescended testis. Andrologia. Jul–Aug. 1985;17(4):389-94. X-3. [pmid: 2864883].
929 Haddy TB, Sandlund JT, Magrath IT. Testicular involvement in young patients with non-Hodgkin’s lymphoma. Am J Pediatr Hematol Oncol. Fall. 1988;10(3):224-9. X-2, X-3. [pmid: 3177811].
930 Hadjiathanasiou CG, Brauner R, Lortat-Jacob S, et al. True hermaphroditism: genetic variants and clinical management. J Pediatr. Nov. 1994;125(5 Pt 1):738-44. X-2, X-3. [pmid: 7965425].
931 Hadziselimovic F, Dessouky N. Differences in testicular development between 5alpha-reductase 2 deficiency and isolated bilateral cryptorchidism. J Urol. Sep. 2008;180(3):1116-20. X-2, X-3. [pmid: 18639287].
932 Hadziselimovic F, Duckett JW, Snyder HM 3rd, et al. Omphalocele, cryptorchidism, and brain malformations. J Pediatr Surg. Sep. 1987;22(9):854-6. X-2, X-3. [pmid: 2889822].
933 Hadziselimovic F, Emmons LR, Buser MW. A diminished postnatal surge of Ad spermatogonia in cryptorchid infants is additional evidence for hypogonadotropic hypogonadism. Swiss Med Wkly. Jun. 26. 2004;134(25–26):381-4. X-3. [pmid: 15340882].
934 Hadziselimovic F, Geneto R, Emmons LR. Increased apoptosis in the contralateral testes of patients with testicular torsion as a factor for infertility. J Urol. Sep. 1998;160(3 Pt 2):1158-60. X-2, X-3. [pmid: 9719299].
935 Hadziselimovic F, Geneto R, Emmons LR. Elevated placental estradiol: a possible etiological factor of human cryptorchidism. J Urol. Nov. 2000;164(5):1694-5. X-3. [pmid: 11025750].
936 Hadziselimovic F, Hadziselimovic NO, Demougin P, et al. EGR4 is a master gene responsible for fertility in cryptorchidism. Sex Dev. 2009;3(5):253-63. X-3. [pmid: 19828938].
937 Hadziselimovic F, Hadziselimovic NO, Demougin P, et al. Testicular gene expression in cryptorchid boys at risk of azoospermia. Sex Dev. 2011;5(2):49-59. X-3. [pmid: 21412036].
938 Hadziselimovic F, Herzog B. The importance of both an early orchidopexy and germ cell maturation for fertility. Lancet. 06. Oct. 2001;358(9288):1156-1157. X-3, X-4, X-5, X-6. [pmid: 11597673].
939 Hadziselimovic F, Herzog B, Liebundgut B, et al. Testicular and vascular changes in children and adults with varicocele. J Urol. Aug. 1989;142(2 Pt 2):583-5. discussion 603–5. X-2, X-3. [pmid: 2746782].
940 Hadziselimovic F, Snyder H, Duckett J, et al. Testicular histology in children with unilateral testicular torsion. J Urol. Jul. 1986;136(1 Pt 2):208-10. X-2, X-3. [pmid: 3723668].
941 Hadziselimovic F, Thommen L, Girard J, et al. The significance of postnatal gonadotropin surge for testicular development in normal and cryptorchid testes. J Urol. Jul. 1986;136(1 Pt 2):274-6. X-3. [pmid: 2873260].
942 Hafeez S, Sharma RA, Huddart RA, et al. Challenges in Treating Patients with Down’s Syndrome and Testicular Cancer with Chemotherapy and Radiotherapy: The Royal Marsden Experience. Clinical Oncology. Mar. 2007;19(2):135-142. X-2, X-3. [pmid: 17355110].
943 Hage JJ, Karim RB, van Diest PJ. Sparing a testis during vaginoplasty in male-to-female transsexuals: does it benefit our patients?. Plast Reconstr Surg. Jun. 2001;107(7):1772-5. X-2, X-3. [pmid: 11391198].
944 Hagen P, Buchholz MM, Eigenmann J, et al. Testicular dysplasia causing disturbance of spermiogenesis in patients with unilateral torsion of the testis. Urol Int. 1992;49(3):154-7. X-2, X-3. [pmid: 1466093].
945 Haghi M, Dewan A, Jones KL, et al. Endocrine abnormalities in patients with Jacobsen (11q-) syndrome. Am J Med Genet A. Aug. 15. 2004;129A(1):62-3. X-2, X-3. [pmid: 15266617].
946 Hagood PG, Mehan DJ, Worischeck JH, et al. Laparoscopic varicocelectomy: preliminary report of a new technique. J Urol. Jan. 1992;147(1):73-6. X-2, X-3. [pmid: 1530871].
947 Hahn EW, Feingold SM, Simpson L, et al. Recovery from aspermia induced by low-dose radiation in seminoma patients. Cancer. Jul. 15. 1982;50(2):337-40. X-2, X-3. [pmid: 7083140].
948 Halachmi S, El-Ghoneimi A, Bissonnette B, et al. Hemodynamic and respiratory effect of pediatric urological laparoscopic surgery: a retrospective study. J Urol. Oct. 2003;170(4 Pt 2):1651-4. discussion 1654. X-4, X-5, X-6. [pmid: 14501683].
949 Haleblian G, Kraklau D, Wilcox D, et al. Y-type urethral duplication in the male. BJU Int. Mar. 2006;97(3):597-602. X-2, X-3. [pmid: 16469034].
950 Hall S, Oates RD. Unilateral absence of the scrotal vas deferens associated with contralateral mesonephric duct anomalies resulting in infertility: Laboratory, physical and radiographic findings, and therapeutic alternatives. Journal of Urology. 1993;150(4):1161-1164. X-2, X-3. [pmid: 8371379].
951 Hallacoglu B, Matulewicz RS, Paltiel HJ, et al. Noninvasive assessment of testicular torsion in rabbits using frequency-domain near-infrared spectroscopy: prospects for pediatric urology. J Biomed Opt. Sep–Oct. 2009;14(5):054027. X-2, X-3. [pmid: 19895129].
952 Hallen M, Sandblom G, Nordin P, et al. Male infertility after mesh hernia repair: A prospective study. Surgery. Feb. 2011;149(2):179-84. X-2, X-3. [pmid: 20542309].
953 Halliday JL, Ukoumunne OC, Baker HWG, et al. Increased risk of blastogenesis birth defects, arising in the first 4 weeks of pregnancy, after assisted reproductive technologies. Human Reproduction. January. 2010;25(1):59-65. X-3. [pmid: 19850591].
954 Halme A, Kellokumpu-Lehtinen P, Lehtonen T, et al. Morphology of testicular germ cell tumours in treated and untreated cryptorchidism. Br J Urol. Jul. 1989;64(1):78-83. X-3, X-4, X-5, X-6. [pmid: 2569902].
955 Halperin LS, Olk RJ, Soubrane G, et al. Safety of fluorescein angiography during pregnancy. Am J Ophthalmol. May. 15. 1990;109(5):563-6. X-2, X-3. [pmid: 1970705].
956 Hamdy FC, Hastie KJ. Torsion of the testis: a new technique for fixation. Eur Urol. 1994;25(4):338-9. X-2, X-3. [pmid: 8056029].
957 Hamidinia A, Nold S, Amankwah KS. Localization and treatment of nonpalpable testes. Surgery Gynecology and Obstetrics. 1984;159(5):439-441. X-4, X-5, X-6.
958 Hamm B, Fobbe F, Loy V. Testicular cysts: differentiation with US and clinical findings. Radiology. Jul. 1988;168(1):19-23. X-2, X-3. [pmid: 3289090].
959 Hammar M, Berg AA, Kjessler B. In vitro metabolism of 3H-pregnenolone and 3H-progesterone by adult and prepubertal human testicular tissue before and during gonadotrophic treatment. Arch Androl. 1985;14(1):21-8. X-2, X-3. [pmid: 2864901].
960 Hammar M, Petersson F, Berg AA. In vitro conversion of progesterone in the human testis at different ages, pathophysiological conditions, and during treatment with estrogens or gonadotrophic hormones. Arch Androl. 1985;14(2–3):143-9. X-2, X-3. [pmid: 2865932].
961 Hammes B, Laitman CJ. Diethylstilbestrol (DES) update: Recommendations for the identification and management of DES-exposed individuals. Journal of Midwifery and Women’s Health. Jan. 2003;48(1):19-29. X-1, X-2, X-3.
962 Hammond S, Zhu R, Youngren KK, et al. Chromosome X modulates incidence of testicular germ cell tumors in Ter mice. Mamm Genome. Dec. 2007;18(12):832-8. X-2, X-3. [pmid: 18049836].
963 Hampl R, Lachman M, Novak Z, et al. Serum levels of steroid hormones in men with varicocele and oligospermia as compared to normozoospermic men. Experimental and Clinical Endocrinology. 1992;100(3):117-119. X-2, X-3. [pmid: 1305061].
964 Hampshire AJ, Blair ME, Crown NS, et al. Is pre-school child health surveillance an effective means of detecting key physical abnormalities?. British Journal of General Practice. Aug. 1999;49(445):630-633. X-3.
965 Han CH, Kang SH. Epididymal anomalies associated with patent processus vaginalis in hydrocele and cryptorchidism. J Korean Med Sci. Oct. 2002;17(5):660-2. X-3. [pmid: 12378019].
966 Hanna EJ, Nevin NC, Nelson J. Genetic study of congenital heart defects in Northern Ireland (1974–1978). J Med Genet. Nov. 1994;31(11):858-63. X-2, X-3. [pmid: 7853370].
967 Hansen M, Sullivan E, Jequier AM, et al. Practitioner reporting of birth defects in children born following assisted reproductive technology: Does it still have a role in surveillance of birth defects?. Human Reproduction. Feb. 2007;22(2):516-520. X-2, X-3. [pmid: 17021189].
968 Hansen PV, Glavind K, Panduro J, et al. Paternity in patients with testicular germ cell cancer: pretreatment and post-treatment findings. Eur J Cancer. 1991;27(11):1385-9. X-2, X-3. [pmid: 1835852].
969 Hansen PV, Trykker H, Andersen J, et al. Germ cell function and hormonal status in patients with testicular cancer. Cancer. Aug. 15. 1989;64(4):956-61. X-2, X-3. [pmid: 2545331].
970 Harding M, Hole D, Gillis C. The epidemiology of non-seminomatous germ cell tumours in the west of Scotland 1975–89. Br J Cancer. Dec. 1995;72(6):1559-62. X-2, X-3. [pmid: 8519678].
971 Hargreave TB, Elton RA, Webb JA, et al. Maldescended testes and fertility: a review of 68 cases. Br J Urol. Dec. 1984;56(6):734-9. X-2, X-3. [pmid: 6152546].
972 Harji DP, Singh M, Roberts T, et al. Spigelian hernia and cryptorchidism. Hernia. Apr. 2011;15(2):221-3. X-2, X-3. [pmid: 20217164].
973 Harland SJ, Cook PA, Fossa SD, et al. Intratubular germ cell neoplasia of the contralateral testis in testicular cancer: defining a high risk group. J Urol. Oct. 1998;160(4):1353-7. X-2, X-3. [pmid: 9751353].
974 Harper L, Michel JL, De Napoli-Cocci S. Should we perform orchidopexy for cryptorchidism in children with severe encephalopathy?. J Pediatr Urol. Jun. 2010;6(3):274-6. X-1, X-2, X-3. [pmid: 19800294].
975 Harris RD, Chouteau C, Partrick M, et al. Prevalence and significance of heterogeneous testes revealed on sonography: ex vivo sonographic-pathologic correlation. AJR Am J Roentgenol. Aug. 2000;175(2):347-52. X-2, X-3. [pmid: 10915673].
976 Harrison JD, Tweedie J, Wilson C, et al. Measurement of testicular blood flow at orchiopexy with a solid state laser. Surgery. Feb. 1991;109(2):160-2. X-3, X-4, X-5, X-6. [pmid: 1671538].
977 Harrison PT, Holmes P, Humfrey CD. Reproductive health in humans and wildlife: are adverse trends associated with environmental chemical exposure?. Sci Total Environ. Oct. 20. 1997;205(2–3):97-106. X-1, X-2, X-3. [pmid: 9372623].
978 Hasanzadeh H, Sharafi A, Allah Verdi M, et al. Assessment of absorbed dose to thyroid, parotid and ovaries in patients undergoing Gamma Knife radiosurgery. Phys Med Biol. Sep. 7. 2006;51(17):4375-83. X-2, X-3. [pmid: 16912387].
979 Hassan AB, Mead GM. Germ cell cancers in adult males are associated with a history of infantile pyloric stenosis. Eur J Cancer. May. 1997;33(6):970-2. X-2, X-3. [pmid: 9291823].
980 Hassan HC, Cullen IM, Casey RG, et al. Gynaecomastia: An endocrine manifestation of testicular cancer. Andrologia. Jun. 2008;40(3):152-157. X-2, X-3. [pmid: 18477201].
981 Haugnes HS, Wethal T, Aass N, et al. Cardiovascular risk factors and morbidity in long-term survivors of testicular cancer: a 20-year follow-up study. J Clin Oncol. Oct. 20. 2010;28(30):4649-57. X-2, X-3. [pmid: 20855830].
982 Hauser R, Temple-Smith PD, Southwick GJ, et al. Fertility in cases of hypergonadotropic azoospermia. Fertil Steril. Mar. 1995;63(3):631-6. X-2, X-3. [pmid: 7851598].
983 Hawkins DA, Taylor-Robinson D, Thomas BJ, et al. Microbiological survey of acute epididymitis. Genitourin Med. Oct. 1986;62(5):342-4. X-2, X-3. [pmid: 3095217].
984 Hayn MH, Herz DB, Bellinger MF, et al. Intermittent torsion of the spermatic cord portends an increased risk of acute testicular infarction. J Urol. Oct. 2008;180(4 Suppl):1729-32. X-2, X-3. [pmid: 18721937].
985 Heidenreich A, Bonfig R, Derschum W, et al. A conservative approach to bilateral testicular germ cell tumors. J Urol. Jan. 1995;153(1):10-3. X-2, X-3. [pmid: 7966739].
986 Heidenreich A, Bonfig R, Wilbert DM, et al. Risk factors for antisperm antibodies in infertile men. Am J Reprod Immunol. Mar–Apr. 1994;31(2–3):69-76. X-3. [pmid: 8049027].
987 Heidenreich A, Holtl W, Albrecht W, et al. Testis-preserving surgery in bilateral testicular germ cell tumours. Br J Urol. Feb. 1997;79(2):253-7. X-2, X-3. [pmid: 9052478].
988 Heidenreich A, Olbert P, Engelmann UH. Management of chronic testalgia by microsurgical testicular denervation. Eur Urol. Apr. 2002;41(4):392-7. X-2, X-3. [pmid: 12074809].
989 Heidenreich A, Pfister D, Witthuhn R, et al. Postchemotherapy Retroperitoneal Lymph Node Dissection in Advanced Testicular Cancer: Radical or Modified Template Resection. European Urology. January. 2009;55(1):217-226. X-2, X-3. [pmid: 18926622].
990 Heidenreich A, Weissbach L, Holtl W, et al. Organ sparing surgery for malignant germ cell tumor of the testis. J Urol. Dec. 2001;166(6):2161-5. X-2, X-3. [pmid: 11696727].
991 Heikkila J, Taskinen S, Toppari J, et al. Posterior urethral valves are often associated with cryptorchidism and inguinal hernias. J Urol. Aug. 2008;180(2):715-7. X-2, X-3. [pmid: 18554641].
992 Heikkila R, Heilo A, Stenwig AE, et al. Testicular ultrasonography and 18G biopty biopsy for clinically undetected cancer or carcinoma in situ in patients with germ cell tumours. Br J Urol. Feb. 1993;71(2):214-6. X-2, X-3. [pmid: 8384915].
993 Heimdal K, Olsson H, Tretli S, et al. Familial testicular cancer in Norway and southern Sweden. Br J Cancer. Apr. 1996;73(7):964-9. X-2, X-3. [pmid: 8611416].
994 Hemendinger R, Wang J, Malik S, et al. Sertoli cells improve survival of motor neurons in SOD1 transgenic mice, a model of amyotrophic lateral sclerosis. Exp Neurol. Dec. 2005;196(2):235-43. X-2, X-3. [pmid: 16242126].
995 Henderson J, Culkin D, Mata J, et al. Analysis of immunological alterations associated with testicular prostheses. Journal of Urology. 1995;154(5):1748-1751. X-2, X-3. [pmid: 7563338].
996 Hendry WF. The long-term results of surgery for obstructive azoospermia. Br J Urol. Dec. 1981;53(6):664-8. X-1, X-2, X-3. [pmid: 7317760].
997 Hendry WF. Clinical significance of unilateral testicular obstruction in subfertile males. Br J Urol. Dec. 1986;58(6):709-14. X-2, X-3. [pmid: 3801832].
998 Hendry WF, Levison DA, Parkinson MC, et al. Testicular obstruction: clinicopathological studies. Ann R Coll Surg Engl. Nov. 1990;72(6):396-407. X-2, X-3. [pmid: 2241062].
999 Hendry WF, Parslow JM, Parkinson MC, et al. Unilateral testicular obstruction: orchidectomy or reconstruction?. Hum Reprod. Mar. 1994;9(3):463-70. X-2, X-3. [pmid: 8006135].
1000 Hendry WF, Parslow JM, Stedronska J. Exploratory scrototomy in 168 azoospermic males. Br J Urol. Dec. 1983;55(6):785-91. X-2, X-3. [pmid: 6652453].
1001 Hendry WF, Parslow JM, Stedronska J, et al. The diagnosis of unilateral testicular obstruction in subfertile males. Br J Urol. Dec. 1982;54(6):774-9. X-2, X-3. [pmid: 7150940].
1002 Henley JD, Young RH, Wade CL, et al. Seminomas with exclusive intertubular growth: a report of 12 clinically and grossly inconspicuous tumors. Am J Surg Pathol. Sep. 2004;28(9):1163-8. X-2, X-3. [pmid: 15316315].
1003 Hensle TW, Burbige KA, Shepard BR, et al. Chemotherapy and its effect on testicular morphology in children. J Urol. Jun. 1984;131(6):1142-4. X-2, X-3. [pmid: 6726915].
1004 Hentrich MU, Brack NG, Schmid P, et al. Testicular germ cell tumors in patients with human immunodeficiency virus infection. Cancer. 15. May. 1996;77(10):2109-2116. X-2, X-3. [pmid: 8640678].
1005 Hermanek P, Sigel A. Necessary extent of lymph node dissection in testicular tumours. A histopathological investigation. Eur Urol. 1982;8(3):135-44. X-2, X-3. [pmid: 6281024].
1006 Hernes EH, Harstad K, Fossa. Changing incidence and delay of testicular cancer in southern Norway (1981–1992). Eur Urol. 1996;30(3):349-57. X-2, X-3. [pmid: 8931969].
1007 Herr HW. Does necrosis on frozen-section analysis of a mass after chemotherapy justify a limited retroperitoneal resection in patients with advanced testis cancer?. Br J Urol. Oct. 1997;80(4):653-7. X-2, X-3. [pmid: 9352708].
1008 Herr HW, Sheinfeld J. Is biopsy of the contralateral testis necessary in patients with germ cell tumors?. Journal of Urology. Oct. 1997;158(4):1331-1334. X-1, X-2, X-3. [pmid: 9302113].
1009 Hibi H, Ohori T, Yamada Y, et al. Probability of sperm recovery in non-obstructive azoospermic patients presenting with testes volume less than 10 ml/FSH level exceeding 20 mIU/ml. Arch Androl. May–Jun. 2005;51(3):225-31. X-2, X-3. [pmid: 16025862].
1010 Hikim AP, Chakraborty J, Jhunjhunwala JS. Unilateral torsion of spermatic cord in men: effect on Leydig cell. Urology. Jan. 1987;29(1):40-4. X-2, X-3. [pmid: 3798628].
1011 Hill SJ, Durham MM. Management of cryptorchidism and gastroschisis. Journal of Pediatric Surgery. September. 2011;46(9):1798-1803. X-4, X-5, X-6. [pmid: 21929993].
1012 Hindley RG, Chandra A, Saunders A, et al. Impalpable testis cancer. BJU Int. Oct. 2003;92(6):572-4. X-2, X-3. [pmid: 14511036].
1013 Hinting A, Soebadi DM, Santoso RI. Evaluation of the immunological cause of male infertility. Andrologia. Mar–Apr. 1996;28(2):123-6. X-2, X-3. [pmid: 8849047].
1014 Hiort O, Klauber G, Cendron M, et al. Molecular characterization of the androgen receptor gene in boys with hypospadias. Eur J Pediatr. May. 1994;153(5):317-21. X-2, X-3. [pmid: 8033918].
1015 Ho CH, Yang SS, Tsai YC. Minilaparoscopic high-ligation with the processus vaginalis undissected and left in situ is a safe, effective, and durable treatment for pediatric hydrocele. Urology. Jul. 2010;76(1):134-7. X-3. [pmid: 20451982].
1016 Ho D, Keneally JP. Analgesia following paediatric day-surgical orchidopexy and herniotomy. Paediatr Anaesth. 2000;10(6):627-31. X-4, X-5, X-6. [pmid: 11119195].
1017 Ho NK. Congenital malformations in Toa Payoh hospital--a 18 year experience (1972–1989). Ann Acad Med Singapore. Mar. 1991;20(2):183-9. X-2, X-3. [pmid: 1883174].
1018 Hobarth K, Susani M, Szabo N, et al. Incidence of testicular microlithiasis. Urology. Nov. 1992;40(5):464-7. X-2, X-3. [pmid: 1441049].
1019 Hobarth K, Szabo N, Klingler HC, et al. Sonographic appearance of testicular microlithiasis. Eur Urol. 1993;24(2):251-5. X-2, X-3. [pmid: 8375448].
1020 Hochberg Z, Chayen R, Reiss N, et al. Clinical, biochemical, and genetic findings in a large pedigree of male and female patients with 5alpha-reductase 2 deficiency. Journal of Clinical Endocrinology and Metabolism. 1996;81(8):2821-2827. X-2, X-3. [pmid: 8768837].
1021 Hod N, Maizlin Z, Strauss S, et al. The relative merits of Doppler sonography in the evaluation of patients with clinically and scintigraphically suspected testicular torsion. Israel Medical Association Journal. Jan. 2004;6(1):13-15. X-2, X-3. [pmid: 14740502].
1022 Hodgson YM, de Kretser DM. Testosterone response of cryptorchid and hypophysectomized rats to human chorionic gonadotrophin (hCG) stimulation. Aust J Biol Sci. 1985;38(4):445-55. X-2, X-3. [pmid: 2871828].
1023 Hoei-Hansen CE, Kraggerud SM, Abeler VM, et al. Ovarian dysgerminomas are characterised by frequent KIT mutations and abundant expression of pluripotency markers. Mol Cancer. 2007;6:12. X-2, X-3. [pmid: 17274819].
1024 Hoekstra T, Witt MA. The correlation of internal spermatic vein palpability with ultrasonographic diameter and reversal of venous flow. J Urol. Jan. 1995;153(1):82-4. X-2, X-3. [pmid: 7966798].
1025 Holland AJ, Whittington JE, Butler J, et al. Behavioral phenotypes associated with specific genetic disorders: Evidence from a population-based study of people with Prader-Willi syndrome. Psychological Medicine. Jan. 2003;33(1):141-153. X-2, X-3. [pmid: 12537045].
1026 Holland AJ, Whittington JE, Butler J, et al. Behavioural phenotypes associated with specific genetic disorders: evidence from a population-based study of people with Prader-Willi syndrome. Psychol Med. Jan. 2003;33(1):141-53. X-2, X-3. [pmid: 12537045].
1027 Holm M, Hoei-Hansen CE, Rajpert-De Meyts E, et al. Increased risk of carcinoma in situ in patients with testicular germ cell cancer with ultrasonic microlithiasis in the contralateral testicle. J Urol. Oct. 2003;170(4 Pt 1):1163-7. X-2, X-3. [pmid: 14501716].
1028 Holm M, Rajpert-De Meyts E, Andersson AM, et al. Leydig cell micronodules are a common finding in testicular biopsies from men with impaired spermatogenesis and are associated with decreased testosterone/LH ratio. J Pathol. Mar. 2003;199(3):378-86. X-2, X-3. [pmid: 12579540].
1029 Holoch PA, Mallapragada S, Ariza CA, et al. Fertility and Sterility. [Conference Abstract]. September. Conference: 65th Annual Meeting of the American Society for Reproductive Medicine, ASRM 2009. Atlanta, GA United States. Conference Start: 20091017 Conference End: 20091021. Conference Publication: (var.pagings). 2009;92(3 SUPPL 1):S207. X-2, X-3.
1030 Holt B, Pryor JP, Hendry WF. Male infertility after surgery for imperforate anus. J Pediatr Surg. Dec. 1995;30(12):1677-9. X-2, X-3. [pmid: 8749922].
1031 Holt PJ, Adshead JM, Filiadis I, et al. Retroperitoneal anomalies in men with testicular germ cell tumours. BJU Int. Feb. 2007;99(2):344-6. X-2, X-3. [pmid: 17026596].
1032 Holzbeierlein JM, Sogani PC, Sheinfeld J. Histology and clinical outcomes in patients with bilateral testicular germ cell tumors: the Memorial Sloan Kettering Cancer Center experience 1950 to 2001. J Urol. Jun. 2003;169(6):2122-5. X-2, X-3. [pmid: 12771732].
1033 Homayoon K, Suhre CD, Steinhardt GF. Epididymal cysts in children: natural history. J Urol. Mar. 2004;171(3):1274-6. X-2, X-3. [pmid: 14767330].
1034 Homonnai ZT, Fainman N, Paz GF, et al. Testicular function after herniotomy. Herniotomy and fertility. Andrologia. Mar–Apr. 1980;12(2):115-20. X-2, X-3. [pmid: 6770717].
1035 Hong YK, Onal B, Diamond DA, et al. Robot-assisted laparoscopic excision of symptomatic retrovesical cysts in boys and young adults. J Urol. Dec. 2011;186(6):2372-8. X-3. [pmid: 22014819].
1036 Honzik T, Tesarova M, Mayr JA, et al. Mitochondrial encephalocardio-myopathy with early neonatal onset due to TMEM70 mutation. Arch Dis Child. Apr. 2010;95(4):296-301. X-2, X-3. [pmid: 20335238].
1037 Hopps CV, Goldstein M. Ultrasound guided needle localization and microsurgical exploration for incidental nonpalpable testicular tumors. J Urol. Sep. 2002;168(3):1084-7. X-2, X-3. [pmid: 12187228].
1038 Hopps CV, Goldstein M. Microsurgical reconstruction of iatrogenic injuries to the epididymis from hydrocelectomy. J Urol. Nov. 2006;176(5):2077-9. discussion 2080. X-2, X-3. [pmid: 17070262].
1039 Horica CA, Hadziselimovic F, Kreutz G, et al. Ultrastructural studies of the contorted and contralateral testicle in unilateral testicular torsion. Eur Urol. 1982;8(6):358-62. X-2, X-3. [pmid: 7140786].
1040 Hormann M, Balassy C, Philipp MO, et al. Imaging of the scrotum in children. European Radiology. Jun. 2004;14(6):974-983. X-1, X-2, X-3. [pmid: 14986053].
1041 Hornak M, Bardos A Jr. Diagnostic and therapeutic problems of acute scrotum. Czech Med. 1986;9(1):29-33. X-2, X-3. [pmid: 3086057].
1042 Hornak M, Ondrus D. Extragonadal germ cell tumours. Int Urol Nephrol. 1988;20(4):395-401. X-2, X-3. [pmid: 2844690].
1043 Hornak M, Zvara V, Ondrus D, et al. Prognosis of patients after retroperitoneal lymphadenectomy for clinical stage I nonseminomatous germ cell tumour of the testis. Czech Med. 1987;10(2):109-16. X-2, X-3. [pmid: 2820669].
1044 Horstman WG, Haluszka MM, Burkhard TK. Management of testicular masses incidentally discovered by ultrasound. J Urol. May. 1994;151(5):1263-5. X-2, X-3. [pmid: 8158772].
1045 Horta LSG, Longui CA, Soares ES, et al. Methylation of the androgen receptor gene in cryptorchid boys. Journal of Endocrine Genetics. 2002;3(1):27-31. X-3.
1046 Hosgor M, Karaca I, Ozer E, et al. Do alterations in collagen synthesis play an etiologic role in childhood inguinoscrotal pathologies: an immunohistochemical study. J Pediatr Surg. Jul. 2004;39(7):1024-9. X-2, X-3. [pmid: 15213891].
1047 Hou JW. Natural course of neonatal progeroid syndrome. Pediatr Neonatol. Jun. 2009;50(3):102-9. X-2, X-3. [pmid: 19579756].
1048 Hovatta O, Huhtaniemi I, Wahlstrom T. Testicular gonadotrophins and their receptors in human cryptorchidism as revealed by immunohistochemistry and radioreceptor assay. Acta Endocrinol (Copenh). Jan. 1986;111(1):128-32. X-2, X-3. [pmid: 2868600].
1049 Hsiang YH, Berkovitz GD, Bland GL, et al. Gonadal function in patients with Down syndrome. Am J Med Genet. Jun. 1987;27(2):449-58. X-2, X-3. [pmid: 2955699].
1050 Hsiao W, Rosoff JS, Pale JR, et al. Older age is associated with similar improvements in semen parameters and testosterone after subinguinal microsurgical varicocelectomy. J Urol. Feb. 2011;185(2):620-5. X-2, X-3. [pmid: 21168880].
1051 Hsiao W, Sultan R, Lee R, et al. Increased follicle-stimulating hormone is associated with higher assisted reproduction use after vasectomy reversal. J Urol. Jun. 2011;185(6):2266-71. X-2, X-3. [pmid: 21497850].
1052 Hsieh TF, Chang CH, Chang SS. Foreskin development before adolescence in 2149 schoolboys. International Journal of Urology. Jul. 2006;13(7):968-970. X-3. [pmid: 16882064].
1053 Hsu GL, Ling PY, Hsieh CH, et al. Outpatient varicocelectomy performed under local anesthesia. Asian J Androl. Dec. 2005;7(4):439-44. X-2, X-3. [pmid: 16281094].
1054 Hsu H, Lin CM, Sun TB, et al. Unilateral gracilis myofasciocutaneous advancement flap for single stage reconstruction of scrotal and perineal defects. Journal of Plastic, Reconstructive and Aesthetic Surgery. Sep. 2007;60(9):1055-1059. X-2, X-3.
1055 Huang CS. Surgical treatment of recurrent groin hernia. J Formos Med Assoc. Feb. 1999;98(2):122-7. X-2, X-3. [pmid: 10083768].
1056 Huang CS, Liang DC. Treatment of testicular relapse in childhood acute lymphoblastic leukemia. Zhonghua Min Guo Xiao Er Ke Yi Xue Hui Za Zhi. Nov–Dec. 1992;33(6):401-7. X-2, X-3. [pmid: 1306924].
1057 Huang TT. Twenty years of experience in managing gender dysphoric patients: I. Surgical management of male transsexuals. Plast Reconstr Surg. Sep. 1995;96(4):921-30. discussion 931–4. X-2, X-3. [pmid: 7652067].
1058 Hudson MM, Frankel LS, Mullins J, et al. Diagnostic value of surgical testicular biopsy after therapy for acute lymphocytic leukemia. J Pediatr. Jul. 1985;107(1):50-3. X-2, X-3. [pmid: 3859628].
1059 Huff DS, Hadziselimovic F, Snyder HM 3rd, et al. Early postnatal testicular maldevelopment in cryptorchidism. J Urol. Aug. 1991;146(2 ( Pt 2)):624-6. X-3. [pmid: 1677687].
1060 Huff DS, Hadziselimovic F, Snyder HM 3rd, et al. Histologic maldevelopment of unilaterally cryptorchid testes and their descended partners. Eur J Pediatr. Suppl 2. 1993;152:S11-4. X-2, X-3. [pmid: 8101802].
1061 Huff DS, Hadziselimovic F, Snyder HM 3rd, et al. Postnatal testicular maldevelopment in unilateral cryptorchidism. J Urol. Aug. 1989;142(2 Pt 2):546-8. discussion 572. X-3. [pmid: 2568502].
1062 Huff DS, Wu HY, Snyder HM 3rd, et al. Evidence in favor of the mechanical (intrauterine torsion) theory over the endocrinopathy (cryptorchidism) theory in the pathogenesis of testicular agenesis. J Urol. Aug. 1991;146(2 ( Pt 2)):630-1. X-3. [pmid: 1677689].
1063 Huhtaniemi I, Nikula H, Rannikko S, et al. Regulation of testicular steroidogenesis by gonadotropin-releasing hormone agonists and antagonists. J Steroid Biochem. Jan. 1986;24(1):169-76. X-2, X-3. [pmid: 3009972].
1064 Humphrey GM, Najmaldin AS. Laparoscopy in the management of pediatric varicoceles. J Pediatr Surg. Oct. 1997;32(10):1470-2. X-3. [pmid: 9349772].
1065 Hunt BM, Vallieres E, Buduhan G, et al. Sarcoidosis as a benign cause of lymphadenopathy in cancer patients. American Journal of Surgery. May. 2009;197(5):629-632. X-2, X-3. [pmid: 19321155].
1066 Hunter AG, Stevenson RE. Gastroschisis: clinical presentation and associations. Am J Med Genet C Semin Med Genet. Aug. 15. 2008;148C(3):219-30. X-2, X-3. [pmid: 18655099].
1067 Huseby RA. Dormancy versus extinction of mouse Leydig cell tumors following endocrine-induced regression. Cancer Research. 1983;43(11):5365-5378. X-2, X-3. [pmid: 6616470].
1068 Hussein TM, Zakaria NH, Zahran AM. Clinical, laboratory and genetic assessment of patients with congenital bilateral absent vas deferens. Andrologia. Feb. 2011;43(1):16-22. X-2, X-3. [pmid: 21219377].
1069 Hustin J, Collette J, Franchimont P. Immunohistochemical demonstration of placental alkaline phosphatase in various states of testicular development and in germ cell tumours. Int J Androl. Feb. 1987;10(1):29-35. X-3. [pmid: 3583420].
1070 Hutcheson JC, Snyder HM 3rd, Zuniga ZV, et al. Ectopic and undescended testes: 2 variants of a single congenital anomaly?. J Urol. Mar. 2000;163(3):961-3. X-3. [pmid: 10688032].
1071 Hutson JM, Albano FR, Paxton G, et al. In vitro fusion of human inguinal hernia with associated epithelial transformation. Cells Tissues Organs. 2000;166(3):249-258. X-2, X-3. [pmid: 10765020].
1072 Hutson JM, Balic A, Nation T, et al. Cryptorchidism. Seminars in Pediatric Surgery. August. 2010;19(3):215-224. X-1, X-2, X-3. [pmid: 20610195].
1073 Hutson JM, Clarke MCC. Current management of the undescended testicle. Seminars in Pediatric Surgery. Feb. 2007;16(1):64-70. X-1, X-2, X-3. [pmid: 17210485].
1074 Huyghe E, Soulie M, Escourrou G, et al. Conservative management of small testicular tumors relative to carcinoma in situ prevalence. J Urol. Mar. 2005;173(3):820-3. X-2, X-3. [pmid: 15711277].
1075 Hwang TIS, Lin YC, Lee MCC, et al. The effects of medical castration on testes in patients with advanced prostate cancer. Urological Science. December. 2010;21(4):169-174. X-2, X-3.
1076 Iacono F, Capparelli G, Darmiento M. Bilateral varicocele repair by transscrotal extratunica vaginalis procedure in outpatients: a novel technique. Tech Urol. Sep. 2000;6(3):196-200. X-2, X-3. [pmid: 10963486].
1077 Iarchy J. Peritoneography, a safe method to assess the bilaterality of inguinal hernias in children with an obvious unilateral hernia or cryptorchidism (100 cases). Acta Chir Belg. Jul–Aug. 1983;83(4):253-60. X-2, X-3. [pmid: 6138911].
1078 Ibingira CB. Long-term complications of inguinal hernia repair. East Afr Med J. Jul. 1999;76(7):396-9. X-2, X-3. [pmid: 10520369].
1079 Iida T, Park S, Kato K, et al. Cleft palate in Kabuki syndrome: A report of six cases. Cleft Palate-Craniofacial Journal. Nov. 2006;43(6):756-761. X-2, X-3. [pmid: 17105332].
1080 Ikeda H, Hatanaka M, Suzuki M, et al. A selective sac extraction method: another minimally invasive procedure for inguinal hernia repair in children: a technical innovation with satisfactory surgical and cosmetic results. J Pediatr Surg. Aug. 2009;44(8):1666-71. X-2, X-3. [pmid: 19635327].
1081 Ikoma F, Shima H. Caudal migration of the verumontanum. J Pediatr Surg. Jul. 1991;26(7):858-61. X-2, X-3. [pmid: 1895200].
1082 Imajima T, Shono T, Kai H, et al. The biological effect of phthalate esters on transabdominal migration of the testis in fetal rats in comparison with the antiandrogen flutamide. Pediatr Surg Int. Mar. 2001;17(2–3):164-6. X-2, X-3. [pmid: 11315278].
1083 Imthurn T, Hadziselimovic F, Herzog B. Impaired germ cells in secondary cryptorchid testis after herniotomy. J Urol. Mar. 1995;153(3 Pt 1):780-1. X-3. [pmid: 7861537].
1084 Inaba Y, Fujisawa M, Okada H, et al. Clinical outcome of microsurgery for obstructive azoospermia. Int J Urol. Mar. 1999;6(3):139-44. X-2, X-3. [pmid: 10226825].
1085 Inci K, Duzova A, Aki FT, et al. Semen variables and hormone profiles after kidney transplantation during adolescence. Transplant Proc. Mar. 2006;38(2):541-2. X-2, X-3. [pmid: 16549169].
1086 Inci K, Hascicek M, Kara O, et al. Sperm retrieval and intracytoplasmic sperm injection in men with nonobstructive azoospermia, and treated and untreated varicocele. J Urol. Oct. 2009;182(4):1500-5. X-2, X-3. [pmid: 19683732].
1087 Ingimarsson O, Spak I. Inguinal and femoral hernias. Long-term results in a community hospital. Acta Chir Scand. 1983;149(3):291-7. X-2, X-3. [pmid: 6613466].
1088 Ishigami K, Abu-Yousef MM, El-Zein Y. Tubular ectasia of the epididymis: a sign of postvasectomy status. J Clin Ultrasound. Dec. 2005;33(9):447-51. X-2, X-3. [pmid: 16281269].
1089 Ishizaka K, Suzuki M, Kageyama Y, et al. Bone mineral density in hypogonadal men remains low after long-term testosterone replacement. Asian J Androl. Jun. 2002;4(2):117-21. X-2, X-3. [pmid: 12085102].
1090 Iskit SH, Dagli TE, Kiyan G, et al. Interstitial hernia: a diagnostic dilemma in infants and children. J Pediatr Surg. Apr. 1998;33(4):586-8. X-3, X-4, X-5, X-6. [pmid: 9574756].
1091 Issa MM, Krishnan A, Bouet R, et al. The fate of the medically castrated testis: expectation versus reality. J Urol. Sep. 2004;172(3):1042-4. X-2, X-3. [pmid: 15311033].
1092 Issa MM, Lendvay TS, Bouet R, et al. Epididymal sparing bilateral simple orchiectomy with epididymoplasty: preservation of esthetics and body image. J Urol. Sep. 2005;174(3):893-7. X-2, X-3. [pmid: 16093982].
1093 Isurugi K, Hasegawa F, Shibahara N, et al. Incomplete testicular feminization syndrome: Studies on androgen receptor(AR) function, AR gene analysis, and aromatase activities at puberty and long-term observations of clinical and hormonal features from infancy to puberty. Endocrine Journal. 1996;43(5):557-564. X-2, X-3. [pmid: 8980896].
1094 Itesako T, Nara K, Matsui F, et al. Acquired undescended testes in boys with hypospadias. J Urol. Jun. 2011;185(6 Suppl):2440-3. X-3. [pmid: 21527201].
1095 Itoh M, Moriyama H, Tokunaga Y, et al. Embryological consideration of drainage of the left testicular vein into the ipsilateral renal vein: Analysis of cases of a double inferior vena cava. International Journal of Andrology. 2001;24(3):142-152. X-2, X-3. [pmid: 11380703].
1096 Ivell R, Anand-ivell R. Biology of insulin-like factor 3 in human reproduction. Human Reproduction Update. 2009;15(4):463-476. X-1, X-2, X-3. [pmid: 19329805].
1097 Ivell R, Anand-Ivell R. Biological role and clinical significance of insulin-like peptide 3. Current Opinion in Endocrinology, Diabetes and Obesity. June. 2011;18(3):210-216. X-2, X-3.
1098 Ivell R, Hartung S. The molecular basis of cryptorchidism. Molecular Human Reproduction. 01. Apr. 2003;9(4):175-181. X-1, X-3. [pmid: 12651898].
1099 Iwatsuki S, Kojima Y, Mizuno K, et al. Endocrine assessment of prepubertal boys with a history of cryptorchidism and/or hypospadias: a pilot study. J Urol. Jun. 2011;185(6 Suppl):2444-50. X-4, X-5, X-6. [pmid: 21555006].
1100 Izumi K, Konaka H, Seto C, et al. A case of bilateral testicular calcifications in a bicycle motocross rider accompanied by bulbar urethral injury. Hinyokika Kiyo. May. 2006;52(5):383-5. X-1, X-2, X-3. [pmid: 16758731].
1101 Jaakkola E, Mustonen A, Olsen P, et al. ERCC6 founder mutation identified in Finnish patients with COFS syndrome. Clinical Genetics. December. 2010;78(6):541-547. X-2, X-3. [pmid: 20456449].
1102 Jackson SM, Olivotto I, McLoughlin MG, et al. Radiation therapy for seminoma of the testis: results in British Columbia. Can Med Assoc J. Sep. 20. 1980;123(6):507-12. X-2, X-3. [pmid: 7437970].
1103 Jacob S, Spillane H, Keane D, et al. Initial experiences of a testicular sperm extraction programme for assisted reproduction in Ireland. Ir J Med Sci. Jan–Mar. 2000;169(1):26-9. X-2, X-3. [pmid: 10846853].
1104 Jacobsen KD, Fossa SD, Bjoro TP, et al. Gonadal function and fertility in patients with bilateral testicular germ cell malignancy. Eur Urol. Sep. 2002;42(3):229-38. discussion 237–8. X-2, X-3. [pmid: 12234507].
1105 Jacobsen KD, Ous S, Waehre H, et al. Ejaculation in testicular cancer patients after post-chemotherapy retroperitoneal lymph node dissection. Br J Cancer. Apr. 1999;80(1–2):249-55. X-2, X-3. [pmid: 10390004].
1106 Jacobsen KD, Theodorsen L, Fossa SD. Spermatogenesis after unilateral orchiectomy for testicular cancer in patients following surveillance policy. J Urol. Jan. 2001;165(1):93-6. X-2, X-3. [pmid: 11125372].
1107 Jadot-Van De, Casseye M, De Bled G, Gepts W, et al. An immunohistochemical study for testicular biopsies in cases of male infertility. Andrologia. Mar–Apr. 1980;12(2):122-9. X-2, X-3. [pmid: 6992650].
1108 Jain VK, Singh S, Garge S, et al. Orchidopexy san ligation technique of orchidopexy. Afr J Paediatr Surg. Jan–Apr. 2011;8(1):112-4. X-2, X-3. [pmid: 21478603].
1109 Janetschek G, Hobisch A, Hittmair A, et al. Laparoscopic retroperitoneal lymphadenectomy after chemotherapy for stage IIB nonseminomatous testicular carcinoma. J Urol. Feb. 1999;161(2):477-81. X-2, X-3. [pmid: 9915430].
1110 Janetschek G, Hobisch A, Peschel R, et al. Laparoscopic retroperitoneal lymph node dissection for clinical stage I nonseminomatous testicular carcinoma: long-term outcome. J Urol. Jun. 2000;163(6):1793-6. X-2, X-3. [pmid: 10799184].
1111 Janzen DL, Mathieson JR, Marsh JI, et al. Testicular microlithiasis: sonographic and clinical features. AJR Am J Roentgenol. May. 1992;158(5):1057-60. X-2, X-3. [pmid: 1566667].
1112 Jarow JP. Clinical significance of intratesticular arterial anatomy. J Urol. Apr. 1991;145(4):777-9. X-2, X-3. [pmid: 2005699].
1113 Jarow JP, Chen H, Rosner TW, et al. Assessment of the androgen environment within the human testis: minimally invasive method to obtain intratesticular fluid. J Androl. Jul–Aug. 2001;22(4):640-5. X-2, X-3. [pmid: 11451361].
1114 Jarow JP, Espeland MA, Lipshultz LI. Evaluation of the azoospermic patient. J Urol. Jul. 1989;142(1):62-5. X-2, X-3. [pmid: 2499695].
1115 Jarvi K, McCallum S, Zielenski J, et al. Heterogeneity of reproductive tract abnormalities in men with absence of the vas deferens: role of cystic fibrosis transmembrane conductance regulator gene mutations. Fertil Steril. Oct. 1998;70(4):724-8. X-2, X-3. [pmid: 9797105].
1116 Jasper HG. Somatomedin response to testosterone stimulation in children with male pseudohermaphroditism, cryptorchidism, anorchia, or micropenis. J Clin Endocrinol Metab. May. 1985;60(5):910-3. X-2, X-3. [pmid: 2858491].
1117 Javadpour N, Ozols RF, Anderson T, et al. A randomized trial of cytoreductive surgery followed by chemotherapy versus chemotherapy alone in bulky stage testicular cancer with poor prognostic features. Cancer. Nov. 15. 1982;50(10):2004-10. X-2, X-3. [pmid: 6751514].
1118 Jemelik R, Penickova V, Vyborny K. Testalgia caused by dysfunction at the thoraco-lumbar junction. Journal of Manual Medicine. 1992;6(6):189. X-2, X-3.
1119 Jensen MS, Bonde JP, Olsen J. Prenatal alcohol exposure and cryptorchidism. Acta Paediatr. Nov. 2007;96(11):1681-5. X-3, X-4, X-5, X-6. [pmid: 17888049].
1120 Jensen MS, Olsen LH, Thulstrup AM, et al. Age at cryptorchidism diagnosis and orchiopexy in Denmark: a population based study of 508,964 boys born from 1995 to 2009. J Urol. Oct. 2011;186(4 Suppl):1595-600. X-4, X-5, X-6. [pmid: 21855929].
1121 Jensen MS, Rebordosa C, Thulstrup AM, et al. Human Reproduction. [Conference Abstract]. June. Conference: 26th Annual Meeting of the European Society of Human Reproduction and Embryology, ESHRE. Rome Italy. Conference Start: 20100627 Conference End: 20100630. Conference Publication: (var.pagings). 2010;25:i135. X-3, X-4, X-5, X-6.
1122 Jensen MS, Rebordosa C, Thulstrup AM, et al. Maternal use of acetaminophen, ibuprofen, and acetylsalicylic acid during pregnancy and risk of cryptorchidism. Epidemiology. Nov. 2010;21(6):779-85. X-2, X-3. [pmid: 20805751].
1123 Jensen MS, Toft G, Thulstrup AM, et al. Cryptorchidism according to maternal gestational smoking. Epidemiology. Mar. 2007;18(2):220-5. X-2, X-3. [pmid: 17202869].
1124 Jensen MS, Toft G, Thulstrup AM, et al. Cryptorchidism concordance in monozygotic and dizygotic twin brothers, full brothers, and half-brothers. Fertil Steril. Jan. 2010;93(1):124-9. X-2, X-3. [pmid: 19022430].
1125 Jensen TK, Vierula M, Hjollund NHI, et al. Semen quality among Danish and Finnish men attempting to conceive. European Journal of Endocrinology. Jan. 2000;142(1):47-52. X-2, X-3. [pmid: 10633221].
1126 Jequier AM, Holmes SC. Primary testicular disease presenting as azoospermia or oligozoospermia in an infertility clinic. Br J Urol. Jun. 1993;71(6):731-5. X-2, X-3. [pmid: 8102079].
1127 Jequier AM, Phillips N. Cystic dilatation of the rete testis: a hidden diagnosis among infertile men. Reprod Biomed Online. Feb. 2009;18(2):190-4. X-2, X-3. [pmid: 19192338].
1128 Jequier S, Patriquin H, Filiatrault D, et al. Duplex Doppler sonographic examinations of the testis in prepubertal boys. J Ultrasound Med. Jun. 1993;12(6):317-22. X-2, X-3. [pmid: 8515528].
1129 Jewett MA. Nerve-sparing technique for retroperitoneal lymphadenectomy in testis cancer. Urol Clin North Am. May. 1990;17(2):449-56. X-2, X-3. [pmid: 2336749].
1130 Jewett MA, Kong YS, Goldberg SD, et al. Retroperitoneal lymphadenectomy for testis tumor with nerve sparing for ejaculation. J Urol. Jun. 1988;139(6):1220-4. X-2, X-3. [pmid: 2836633].
1131 Jewett MA, Thachil JV, Harris JF. Exocrine function of testis with germinal testicular tumour. Br Med J (Clin Res Ed). Jun. 11. 1983;286(6381):1849-50. X-2, X-3.
1132 Jezek D, Banek L, Hittmair A, et al. Mast cells in testicular biopsies of infertile men with ‘mixed atrophy’ of seminiferous tubules. Andrologia. Jul. 1999;31(4):203-10. X-2, X-3. [pmid: 10470410].
1133 Jezek D, Knuth UA, Schulze W. Successful testicular sperm extraction (TESE) in spite of high serum follicle stimulating hormone and azoospermia: correlation between testicular morphology, TESE results, semen analysis and serum hormone values in 103 infertile men. Hum Reprod. May. 1998;13(5):1230-4. X-2, X-3. [pmid: 9647552].
1134 Jhaveri KS, Mazrani W, Chawla TP, et al. The role of cross-sectional imaging in male infertility: A pictorial review. Canadian Association of Radiologists Journal. June. 2010;61(3):144-155. X-1, X-2, X-3. [pmid: 20188509].
1135 Jiang R, Chen JH, Chen M, et al. Male genital schwannoma, review of 5 cases. Asian Journal of Andrology. Sep. 2003;5(3):251-254. X-2, X-3. [pmid: 12937811].
1136 Jimenez-Lopez M, Ramirez-Garrido F, Lopez-Gonzalez Garrido JD, et al. Dilatation of the rete testis: ultrasound study. Eur Radiol. 1999;9(7):1327-9. X-2, X-3. [pmid: 10460368].
1137 Jingde Z, Xin X, Entan G, et al. Surgical treatment of hermaphroditism: Experience with 25 cases. Annals of Plastic Surgery. November. 2009;63(5):543-551. X-3, X-4, X-5, X-6. [pmid: 19806042].
1138 Jinno M, Ozaki T, Nakamura Y, et al. Predicting sperm retrieval rates in testicular sperm extraction for azoospermia according to endocrine profiles. Reproductive Medicine and Biology. Dec. 2005;4(4):239-245. X-2, X-3.
1139 Joao EC, Calvet GA, Krauss MR, et al. Maternal antiretroviral use during pregnancy and infant congenital anomalies: The NISDI perinatal study. Journal of Acquired Immune Deficiency Syndromes. February. 2010;53(2):176-185. X-3. [pmid: 20104119].
1140 Johansen TE, Blom GP. Histological studies of gubernaculum testis taken during orchiopexies. Scand J Urol Nephrol. 1988;22(2):107-8. X-2, X-3. [pmid: 2905074].
1141 Johansen TE, Klein H. Evidence of androgen receptivity in the pathway of testicular descent in humans. A postnatal study. Eur Urol. 1993;23(4):466-8. X-3. [pmid: 8101489].
1142 John CM, Kooner G, Mathew DE, et al. Neonatal testicular torsion--a lost cause?. Acta Paediatr. Apr. 2008;97(4):502-4. X-2, X-3. [pmid: 18331368].
1143 John H, Schmid C. Kallmann’s syndrome: Clues to clinical diagnosis. International Journal of Impotence Research. 2000;12(5):269-271. X-2, X-3. [pmid: 11424964].
1144 Johnson AR 3rd, Jarow JP. Is routine endocrine testing of impotent men necessary?. J Urol. Jun. 1992;147(6):1542-3. discussion 1543–4. X-2, X-3. [pmid: 1593685].
1145 Johnson D, Jones K, Chambers C. Canadian Journal of Gastroenterology. Conference: Canadian Digestive Diseases Week. [Conference Abstract]. 2009;20090227(20090302). X-2, X-3.
1146 Johnson D, Jones K, Chambers C. Pregnancy outcomes in women exposed to adalimumab. Canadian Journal of Gastroenterology. Conference: Canadian Digestive Diseases Week. [Conference Abstract]. 2009;20090227(20090302). X-2, X-3.
1147 Johnson DK, Perlmutter AD. Single system ectopic ureteroceles with anomalies of the heart, testis and vas deferens. J Urol. Jan. 1980;123(1):81-3. X-2, X-3. [pmid: 7351728].
1148 Johnson DL, Jones KL, Chambers CD, et al. Gastroenterology. [Conference Abstract]. May. Conference: Digestive Disease Week, DDW 2009. Chicago, IL United States. Conference Start: 20090530 Conference End: 20090604. Conference Publication: (var.pagings). 2009;136(5 SUPPL 1):A27. X-3.
1149 Jones DJ. Recurrent subacute torsion: prospective study of effects on testicular morphology and function. J Urol. Feb. 1991;145(2):297-9. X-2, X-3. [pmid: 1988721].
1150 Jones DJ, Macreadie D, Morgans BT. Testicular torsion in the armed services: twelve year review of 179 cases. Br J Surg. Aug. 1986;73(8):624-6. X-2, X-3. [pmid: 3742174].
1151 Jones EC, Murray SK, Young RH. Cysts and epithelial proliferations of the testicular collecting system (including rete testis). Seminars in Diagnostic Pathology. 2000;17(4):270-293. X-2, X-3. [pmid: 11202545].
1152 Jones HB, Betton GR, Bowdler AL, et al. Pathological and morphometric assessment of testicular parameters in patients with metastatic prostate cancer following treatment with either the antiandrogen Casodex (ZM176,334) or bilateral orchidectomy. Urol Res. 1994;22(3):191-5. X-2, X-3. [pmid: 7992465].
1153 Jones ME, Swerdlow AJ, Griffith M, et al. Prenatal risk factors for cryptorchidism: a record linkage study. Paediatr Perinat Epidemiol. Oct. 1998;12(4):383-96. X-2, X-3. [pmid: 9805712].
1154 Jones TD, MacLennan GT, Bonnin JM, et al. Screening for intratubular germ cell neoplasia of the testis using OCT4 immunohistochemistry. Am J Surg Pathol. Nov. 2006;30(11):1427-31. X-2, X-3. [pmid: 17063084].
1155 Jones TH, Darne JF. Self-administered subcutaneous human menopausal gonadotrophin for the stimulation of testicular growth and the initiation of spermatogenesis in hypogonadotrophic hypogonadism. Clin Endocrinol (Oxf). Feb. 1993;38(2):203-8. X-2, X-3. [pmid: 8435901].
1156 Jones VS, Cohen RC. Two decades of minimally invasive pediatric surgery-taking stock. J Pediatr Surg. Sep. 2008;43(9):1653-9. X-3. [pmid: 18779002].
1157 Jorgensen N, Meyts ER, Main KM, et al. Testicular dysgenesis syndrome comprises some but not all cases of hypospadias and impaired spermatogenesis. Int J Androl. Apr. 2010;33(2):298-303. X-1, X-2, X-3. [pmid: 20132348].
1158 Jorgez C, Whirledge S, Sahin A, et al. Journal of Andrology. [Conference Abstract]. March-April. Conference: 35th Annual Meeting of the American Society of Andrology, ASA. Houston, TX United States. Conference Start: 20100410 Conference End: 20100413. Conference Publication: (var.pagings). 2010;31(54). X-2, X-3.
1159 Jose B, Perkins LP, Kays H, et al. Is mediastinal irradiation necessary for stage I testicular seminoma?. J Surg Oncol. Apr. 1984;25(4):250-1. X-2, X-3. [pmid: 6717022].
1160 Joseph VT. Pudendal-thigh flap vaginoplasty in the reconstruction of genital anomalies. J Pediatr Surg. Jan. 1997;32(1):62-5. X-2, X-3. [pmid: 9021571].
1161 Joseph VT, Fong PH. Undescended testis: a study of 212 cases treated surgically. Ann Acad Med Singapore. Oct. 1981;10(4):502-6. X-4, X-5, X-6. [pmid: 6124206].
1162 Joshi W, Connelly NR, Freeman K, et al. Analgesic effect of clonidine added to bupivacaine 0.125% in paediatric caudal blockade. Paediatr Anaesth. Jun. 2004;14(6):483-6. X-2, X-3. [pmid: 15153211].
1163 Josso N. Paediatric applications of anti-mullerian hormone research. 1992 Andrea Prader Lecture. Horm Res. 1995;43(6):243-8. X-1, X-2, X-3. [pmid: 7607609].
1164 Jugenburg I, Kipikasa A. Fertility in patients with hypospadias. Acta Chirurgiae Plasticae. 1988;30(2):86-93. X-3. [pmid: 2470226].
1165 Jung A, Schill WB, Schuppe HC. Genital heat stress in men of barren couples: a prospective evaluation by means of a questionnaire. Andrologia. Dec. 2002;34(6):349-55. X-2, X-3. [pmid: 12472617].
1166 Jung A, Schill WB, Schuppe HC. Improvement of semen quality by nocturnal scrotal cooling in oligozoospermic men with a history of testicular maldescent. Int J Androl. Apr. 2005;28(2):93-8. X-2, X-3. [pmid: 15811070].
1167 Kabay S, Yucel M, Ozden H, et al. Magnetic resonance imaging is a complementary method to stereological measurement of testicular volume. Urology. May. 2009;73(5):1131-5. X-2, X-3. [pmid: 18455779].
1168 Kadioglu A, Tefekli A, Cayan S, et al. Microsurgical inguinal varicocele repair in azoospermic men. Urology. Feb. 2001;57(2):328-33. X-2, X-3. [pmid: 11182347].
1169 Kaftanovskaya EM, Feng S, Huang Z, et al. Suppression of insulin-like3 receptor reveals the role of beta-catenin and Notch signaling in gubernaculum development. Mol Endocrinol. Jan. 2011;25(1):170-83. X-2, X-3. [pmid: 21147849].
1170 Kaiho Y, Nakagawa H, Ito A, et al. Ipsilateral seminal emission generated by electrostimulation of the lumbar sympathetic nerve during nerve sparing laparoscopic retroperitoneal lymph node dissection for testicular cancer. J Urol. Sep. 2004;172(3):928-31. X-2, X-3. [pmid: 15311000].
1171 Kajbafzadeh AM, Payabvash S. Endoscopic treatment of vesicovasal and vesicoureteral reflux in infants with persisting mesonephric duct. J Urol. Dec. 2006;176(6 Pt 1):2657-62. X-2, X-3. [pmid: 17085187].
1172 Kajbafzadeh AM, Talab SS, Elmi A, et al. Modified scrotal approach for correction of abdominoscrotal hydrocele in children: clinical presentation and description of technique. Urology. Jul. 2010;76(1):87-91. X-2, X-3. [pmid: 20394967].
1173 Kaleva M, Virtanen H, Haavisto AM, et al. Does variant luteinizing hormone (V-LH) predispose to improper testicular position in late pregnancy?. Pediatr Res. Sep. 2005;58(3):447-50. X-3. [pmid: 16148055].
1174 Kaleva M, Virtanen HE, Haavisto AM, et al. Circannual rhythm in the incidence of cryptorchidism in Finland. Int J Androl. Feb. 2005;28(1):53-7. X-3. [pmid: 15679622].
1175 Kalita J, Misra UK, Mishra DK, et al. Nonprogressive juvenile-onset spinal muscular atrophy: A clinico-radiological and CAG repeat study of androgen receptor gene. J Neurol Sci. Jan. 15. 2007;252(1):24-8. X-2, X-3. [pmid: 17137601].
1176 Kallen B. Hyperemesis during pregnancy and delivery outcome: a registry study. Eur J Obstet Gynecol Reprod Biol. Dec. 1987;26(4):291-302. X-2, X-3. [pmid: 3691940].
1177 Kallen B, Bertollini R, Castilla E, et al. A joint international study on the epidemiology of hypospadias. Acta Paediatr Scand Suppl. 1986;324:1-52. X-2, X-3. [pmid: 3471045].
1178 Kallen BAJ, Olausson PO, Danielsson BR. Is erythromycin therapy teratogenic in humans?. Reproductive Toxicology. Jul. 2005;20(2):209-214. X-2, X-3. [pmid: 15907655].
1179 Kamal A, Fahmy I, Mansour R, et al. Does the outcome of ICSI in cases of obstructive azoospermia depend on the origin of the retrieved spermatozoa or the cause of obstruction? A comparative analysis. Fertil Steril. Nov. 2010;94(6):2135-40. X-2, X-3. [pmid: 20188354].
1180 Kamaledeen S, Surana R. Intermittent testicular pain: fix the testes. BJU Int. Mar. 2003;91(4):406-8. X-2, X-3. [pmid: 12603424].
1181 Kamischke A, Jurgens H, Hertle L, et al. Cryopreservation of sperm from adolescents and adults with malignancies. J Androl. Jul–Aug. 2004;25(4):586-92. X-2, X-3. [pmid: 15223847].
1182 Kaneko K, Tsuda M. Four-triangular-skin-flap approach to umbilical diseases and laparoscopic umbilical port. J Pediatr Surg. Sep. 2004;39(9):1404-7. X-2, X-3. [pmid: 15359399].
1183 Kann P, Hengstermann C, Heussel CP, et al. Endosonography of the adrenal glands: normal size--pathological findings. Exp Clin Endocrinol Diabetes. 1998;106(2):123-9. X-2, X-3. [pmid: 9628243].
1184 Kanto S, Hiramatsu M, Suzuki K, et al. Risk factors in past histories and familial episodes related to development of testicular germ cell tumor. Int J Urol. Aug. 2004;11(8):640-6. X-2, X-3. [pmid: 15285755].
1185 Kanyo K, Konc J. A follow-up study of children born after diode laser assisted hatching. European Journal of Obstetrics Gynecology and Reproductive Biology. 10. Oct. 2003;110(2):176-180. X-2, X-3.
1186 Kaplan BS, Kaplan P, Kessler A. Cystic kidneys associated with connective tissue disorders. American Journal of Medical Genetics. 17. Mar. 1997;69(2):133-137. X-2, X-3. [pmid: 9056549].
1187 Kaplan GW. Nomenclature of cryptorchidism. Eur J Pediatr. Suppl 2. 1993;152:S17-9. X-1, X-2, X-3. [pmid: 8101804].
1188 Kaplan JD, Bernstein JA, Kwan A, et al. Clues to an early diagnosis of Kallmann syndrome. American Journal of Medical Genetics, Part A. November. 2010;152(11):2796-2801. X-3. [pmid: 20949504].
1189 Kaplan JH, Kudish HG, Sacks SA. Testicular tumors of germ cell origin. 1. Epidemiology, pathogenesis, clinical presentation, and diagnosis. Postgrad Med. Dec. 1981;70(6):114-21. X-1, X-2, X-3. [pmid: 6118858].
1190 Kaplan LM, Koyle MA, Kaplan GW. Association between abdominal wall defects and cryptorchidism. Journal of Urology. 1986;136(3):645-647. X-3. [pmid: 2874239].
1191 Kaplan WE, Firlit CF. Treatment of testicular yolk sac carcinoma in the young child. J Urol. Nov. 1981;126(5):663-4. X-2, X-3. [pmid: 7299932].
1192 Kaponis A, Yiannakis D, Tsoukanelis K, et al. The role of ultrasonographically guided puncture of the human rete testis in the therapeutic management of nonobstructive azoospermia. Andrologia. Apr. 2003;35(2):85-92. X-2, X-3. [pmid: 12653781].
1193 Karam M, Roberts-Klein S, Shet N, et al. Bilateral hilar foci on18F-FDG PET scan in patients without lung cancer: Variables associated with benign and malignant etiology. Journal of Nuclear Medicine. 01. Sep. 2008;49(9):1429-1436. X-1, X-2, X-3, X-9. [pmid: 18765585].
1194 Karaman IM, Kaya C, Ozturk M, et al. The effects of human chorionic gonadotrophin on normal testicular tissue of rats: dose-dependence and reversibility. BJU Int. May. 2006;97(5):1116-8. X-2, X-3. [pmid: 16643501].
1195 Karcaaltincaba M. Demonstration of normal and dilated testicular veins by multidetector computed tomography. Jpn J Radiol. Apr. 2011;29(3):161-5. X-3. [pmid: 21519988].
1196 Karlberg S, Toppari J, Karlberg N, et al. Testicular failure and male infertility in the monogenic mulibrey nanism disorder. Journal of Clinical Endocrinology and Metabolism. November. 2011;96(11):3399-3407. X-2, X-3. [pmid: 21865362].
1197 Kashif M, Haq MR, Hussain N. Perinatal testicular torsion: Some facts and figures. Medical Forum Monthly. January. 2009;20(1):28-31. X-3.
1198 Kass EJ, Freitas JE, Salisz JA, et al. Pituitary gonadal dysfunction in adolescents with varicocele. Urology. Aug. 1993;42(2):179-81. X-2, X-3. [pmid: 8367925].
1199 Kass EJ, Stork BR, Steinert BW. Varicocele in adolescence induces left and right testicular volume loss. BJU Int. Apr. 2001;87(6):499-501. X-2, X-3. [pmid: 11298042].
1200 Katri KM. Open preperitoneal mesh repair of recurrent inguinal hernia. Hernia. Dec. 2009;13(6):585-9. X-2, X-3. [pmid: 19572181].
1201 Kaufman DG, Nagler HM. Aspiration flow cytometry of the testes in the evaluation of spermatogenesis in the infertile male. Fertil Steril. Aug. 1987;48(2):287-91. X-2, X-3. [pmid: 3609340].
1202 Kavic MS. Laparoscopic hernia repair. Surg Endosc. May–Jun. 1993;7(3):163-7. X-2, X-3. [pmid: 8503072].
1203 Kawada T, Yamanaka H, Hasegawa Y. Decreased immunoreactive inhibin and increased FSH levels in cryptorchidism after orchidopexy. Endocr J. Aug. 1995;42(4):577-80. X-4, X-5, X-6. [pmid: 8556067].
1204 Kawame H, Matsui M, Kurosawa K, et al. Further delineation of the behavioral and neurologic features in Costello syndrome. American Journal of Medical Genetics. 01. Apr. 2003;118 A(1):8-14. X-2, X-3. [pmid: 12605434].
1205 Kaye JD, Levitt SB, Friedman SC, et al. Neonatal torsion: a 14-year experience and proposed algorithm for management. J Urol. Jun. 2008;179(6):2377-83. X-2, X-3. [pmid: 18433778].
1206 Kaye KW. Modified high varicocelectomy: outpatient microsurgical procedure. Urology. Jul. 1988;32(1):13-6. X-2, X-3. [pmid: 3291369].
1207 Kehinde EO, Mojiminiyi OA, Mahmoud AH, et al. The significance of measuring the time course of serum malondialdehyde concentration in patients with torsion of the testis. J Urol. Jun. 2003;169(6):2177-80. X-2, X-3. [pmid: 12771743].
1208 Kelly D, Harte FB, Roe P. Urinary tract anomalies in patients with hypospadias. Br J Urol. Jun. 1984;56(3):316-8. X-2, X-3. [pmid: 6152714].
1209 Kenkel S, Rolf C, Nieschlag E. Occupational risks for male fertility: An analysis of patients attending a tertiary referral centre. International Journal of Andrology. 2001;24(6):318-326. X-2, X-3. [pmid: 11737412].
1210 Kessaris DN, Mellinger BC. Incidence and implication of testicular microlithiasis detected by scrotal duplex sonography in a select group of infertile men. Journal of Urology. 1994;152(51):1560-1561. X-2, X-3. [pmid: 7933202].
1211 Ketata S, Ketata H, Sahnoun A, et al. Ectopic adrenal cortex tissue: an incidental finding during inguinoscrotal operations in pediatric patients. Urol Int. 2008;81(3):316-9. X-2, X-3. [pmid: 18931550].
1212 Ketola I, Pentikainen V, Vaskivuo T, et al. Expression of transcription factor GATA-4 during human testicular development and disease. J Clin Endocrinol Metab. Oct. 2000;85(10):3925-31. X-2, X-3. [pmid: 11061558].
1213 Khairi A, El-Kholi N, Shehata S. Early insertion of trans-scrotal port during laparoscopic orchidopexy: A new concept. Journal of Pediatric Urology. October. 2011;7(5):548-551. X-4, X-5, X-6. [pmid: 20801720].
1214 Khaleghnejad-Tabari A, Mirshermirani A, Rouzrokh M, et al. Early exploration in the management of acute scrotum in children. Iranian Journal of Pediatrics. 2010;20(4):466-470. X-4, X-5, X-6. [pmid: 23056747].
1215 Khalifa OA, Walter CU, Rahbeeni ZA, et al. Terminal 4q deletion and 8q duplication in a patient with CHARGE-like features. Eur J Med Genet. Mar–Apr. 2011;54(2):173-6. X-2, X-3. [pmid: 21094707].
1216 Khan BAH, Ul Haq RN, Khan FB, et al. Role of diagnostic laparoscopy: A study of 58 patients. Medical Forum Monthly. December. 2010;21(12):3-5. X-4, X-5, X-6.
1217 Khan FA, Memon GA, Kamal RS. Effect of route of buprenorphine on recovery and postoperative analgesic requirement in paediatric patients. Paediatr Anaesth. Nov. 2002;12(9):786-90. X-2, X-3. [pmid: 12519138].
1218 Khan MA, Khan K, Khan Y, et al. Testicular re-routing in high undescended testis. JPMI - Journal of Postgraduate Medical Institute. July–September. 2009;23(3):263-266. X-4, X-5, X-6.
1219 Khan MS, Humayoon MS, Al Manee MS. Epididymo-orchitis and Brucellosis. Br J Urol. Jan. 1989;63(1):87-9. X-3. [pmid: 2920268].
1220 Khouni H, Bouchiba N, Khelifa MM, et al. Treatment of idiopathic varicocele: Comparative study of three techniques about 128 cases. Tunisie Medicale. December. 2011;89(12):929-934. X-2, X-3. [pmid: 22198896].
1221 Kibar Y, Frimberger D, Kropp BP, et al. Accuracy of perinatal diagnosis of 45,X/46,XY mosaicism and electronic consultation of affected parents. J Pediatr Urol. Aug. 2009;5(4):274-8. X-2, X-3. [pmid: 19329364].
1222 Kidney DD, Cohen AJ, Seville P. Original report. Retractile testis: An incidental CT finding in trauma patients. American Journal of Roentgenology. 1997;168(5):1233-1234. X-2, X-3. [pmid: 9129418].
1223 Kiely EA, Chapman RS, Bajoria SK, et al. Maternal serum human chorionic gonadotrophin during early pregnancy resulting in boys with hypospadias or cryptorchidism. Br J Urol. Sep. 1995;76(3):389-92. X-3. [pmid: 7551854].
1224 Kiesewetter WB, Mammen K, Kalyglou M. The rationale and results in two-stage orchidopexies. J Pediatr Surg. Aug. 1981;16(4 Suppl 1):631-5. X-4, X-5, X-6. [pmid: 6115897].
1225 Kiesling VJ Jr, Schroeder DE, Pauljev P, et al. Spermatic cord block and manual reduction: primary treatment for spermatic cord torsion. J Urol. Nov. 1984;132(5):921-3. X-2, X-3. [pmid: 6492282].
1226 Kim B, Leonard MP, Bass J, et al. Analysis of the clinical significance and cost associated with the routine pathological analysis of pediatric inguinal hernia sacs. J Urol. Oct. 2011;186(4 Suppl):1620-4. X-2, X-3. [pmid: 21855930].
1227 Kim ED, Leibman BB, Grinblat DM, et al. Varicocele repair improves semen parameters in azoospermic men with spermatogenic failure. J Urol. Sep. 1999;162(3 Pt 1):737-40. X-2, X-3. [pmid: 10458356].
1228 Kim SO, Chung HS, Park K. Modified microsurgical subinguinal varicocelectomy without testicular delivery. Andrologia. December. 2011;43(6):405-408. X-2, X-3. [pmid: 21714798].
1229 Kim TH, Hargreaves HK, Chan WC, et al. Sequential testicular biopsies in childhood acute lymphocytic leukemia. Cancer. Mar. 1. 1986;57(5):1038-41. X-2, X-3. [pmid: 3455840].
1230 Kimura T, Suzuki A, Fujita Y, et al. Conditional loss of PTEN leads to testicular teratoma and enhances embryonic germ cell production. Development. Apr. 2003;130(8):1691-700. X-2, X-3. [pmid: 12620992].
1231 King LR. Orchiopexy for impalpable testis: high spermatic vessel division is a safe maneuver. J Urol. Dec. 1998;160(6 Pt 2):2457-60. X-4, X-5, X-6. [pmid: 9817403].
1232 Kingsley D, Vogt DM, Nelson MT, et al. Laparoscopic intraperitoneal onlay inguinal herniorrhaphy. Am J Surg. Dec. 1998;176(6):548-53. X-2, X-3. [pmid: 9926788].
1233 Kinkade S. Testicular cancer. American Family Physician. 01. May. 1999;59(9):2539-2544. X-2, X-3. [pmid: 10323360].
1234 Kirby RS, Chapple CR, Ward SP, et al. Is the scrotal testis normal in unilateral cryptorchidism?. Br J Urol. Apr. 1985;57(2):187-9. X-4, X-5, X-6. [pmid: 2859073].
1235 Kirkilionis AJ, Pozsonyi J, Sergovich FR. The use of testicular volume as a clinical marker for cytogenetic disorders in mentally retarded males. J Ment Defic Res. Feb. 1988;32(Pt 1):19-30. X-2, X-3. [pmid: 2896248].
1236 Kiss A, Csontai A, Merksz M, et al. Intrascrotal and testicular solid masses in childhood. Int Urol Nephrol. 1996;28(6):787-92. X-2, X-3. [pmid: 9089047].
1237 Kitajima K, Nakamoto Y, Senda M, et al. Normal uptake of 18F-FDG in the testis: an assessment by PET/CT. Ann Nucl Med. Sep. 2007;21(7):405-10. X-2, X-3. [pmid: 17876554].
1238 Kitilla T. Relationships of testicular volume and fine-needle aspiration cytology pattern in infertile azoospermic men (Fgae Centeral Clinic, 2003–4). Ethiop Med J. Jan. 2007;45(1):19-28. X-2, X-3. [pmid: 17642154].
1239 Kjaer D, Horvath-Puho E, Christensen J, et al. Use of phenytoin, phenobarbital, or diazepam during pregnancy and risk of congenital abnormalities: A case-time-control study. Pharmacoepidemiology and Drug Safety. Feb. 2007;16(2):181-188. X-2, X-3. [pmid: 16941718].
1240 Klamt B, Koziell A, Poulat F, et al. Frasier syndrome is caused by defective alternative splicing of WT1 leading to an altered ratio of WT1 +/-KTS splice isoforms. Hum Mol Genet. Apr. 1998;7(4):709-14. X-2, X-3. [pmid: 9499425].
1241 Klatte T, de Martino M, Arensmeier K, et al. Management and outcome of bilateral testicular germ cell tumors: a 25-year single center experience. Int J Urol. Sep. 2008;15(9):821-6. X-2, X-3. [pmid: 18657202].
1242 Kleiman SE, Yogev L, Gamzu R, et al. Genetic evaluation of infertile men. Hum Reprod. Jan. 1999;14(1):33-8. X-2, X-3. [pmid: 10374090].
1243 Klein FA, Whitmore WF Jr, Sogani PC, et al. Inguinal lymph node metastases from germ cell testicular tumors. J Urol. Mar. 1984;131(3):497-500. X-2, X-3. [pmid: 6699990].
1244 Kleinschmidt K, Dieckmann KP, Georgiew A, et al. Chemotherapy is of limited efficacy in the control of contralateral testicular intraepithelial neoplasia in patients with testicular germ cell cancer. Oncology. 2009;77(1):33-9. X-2, X-3. [pmid: 19440001].
1245 Klepp O, Olsson AM, Ous S, et al. Early clinical stages of nonseminomatous testis cancer. Evaluation of the primary treatment and follow-up procedures of the SWENOTECA project. Scand J Urol Nephrol. 1991;25(3):179-90. X-2, X-3. [pmid: 1658924].
1246 Kliesch S, Bergmann M, Hertle L, et al. Semen parameters and testicular pathology in men with testicular cancer and contralateral carcinoma in situ or bilateral testicular malignancies. Hum Reprod. Dec. 1997;12(12):2830-5. X-2, X-3. [pmid: 9455863].
1247 Klin B, Lotan G, Efrati Y, et al. Acute idiopathic scrotal edema in children - Revisited. Journal of Pediatric Surgery. 2002;37(8):1200-1202. X-2, X-3. [pmid: 12149702].
1248 Klin B, Zlotkevich L, Horne T, et al. A selective approach to the treatment of acute scrotum in children. Pediatric Surgery International. Aug. 1996;11(7):483-486. X-2, X-3.
1249 Klocker H, Neuschmid-Kaspar F, Culig Z, et al. Androgen receptor alterations in patients with disturbances in male sexual development and in prostatic carcinoma. Urol Int. 1995;54(1):2-5. X-2, X-3. [pmid: 7770997].
1250 Klys HS, Whillis D, Howard G, et al. Glutathione S-transferase expression in the human testis and testicular germ cell neoplasia. Br J Cancer. Sep. 1992;66(3):589-93. X-2, X-3. [pmid: 1355663].
1251 Knight PJ, Vassy LE. The diagnosis and treatment of the acute scrotum in children and adolescents. Annals of Surgery. 1984;200(5):664-673. X-2, X-3. [pmid: 6486916].
1252 Knoll LD. Use of porcine small intestinal submucosal graft in the surgical management of tunical deficiencies with penile prosthetic surgery. Urology. May. 2002;59(5):758-61. X-2, X-3. [pmid: 11992915].
1253 Knorr JR, Ragland RL, Brown RS, et al. Kallmann syndrome: MR findings. American Journal of Neuroradiology. 1993;14(4):845-854. X-2, X-3. [pmid: 8352155].
1254 Knudtzon J, Aarskog D. 45,X/46,XY mosaicism. A clinical review and report of ten cases. European Journal of Pediatrics. 1987;146(3):266-271. X-2, X-3. [pmid: 3595646].
1255 Ko YS, Lin LH, Chen DF. Abdominal teratomas in children. Zhonghua Min Guo Xiao Er Ke Yi Xue Hui Za Zhi. Sep–Oct. 1995;36(5):342-5. X-2, X-3. [pmid: 8607359].
1256 Kocak I, Yenisey C, Dundar M, et al. Relationship between seminal plasma interleukin-6 and tumor necrosis factor alpha levels with semen parameters in fertile and infertile men. Urol Res. Sep. 2002;30(4):263-7. X-2, X-3. [pmid: 12202945].
1257 Kocaoglu M, Bozlar U, Bulakbasi N, et al. Testicular microlithiasis in pediatric age group: Ultrasonography findings and literature review. Diagnostic and Interventional Radiology. Mar. 2005;11(1):60-65. X-2, X-3. [pmid: 15795846].
1258 Kocvara R, Dolezal J, Hampl R, et al. Division of lymphatic vessels at varicocelectomy leads to testicular oedema and decline in testicular function according to the LH-RH analogue stimulation test. Eur Urol. Apr. 2003;43(4):430-5. X-2, X-3. [pmid: 12667726].
1259 Koff SA. Does compensatory testicular enlargement predict monorchism?. J Urol. Aug. 1991;146(2 ( Pt 2)):632-3. X-3. [pmid: 1677690].
1260 Koff SA, Sethi PS. Treatment of high undescended testes by low spermatic vessel ligation: an alternative to the Fowler-Stephens technique. J Urol. Aug. 1996;156(2 Pt 2):799-803. discussion 803. X-4, X-5, X-6. [pmid: 8683787].
1261 Kogan BA, Gupta R, Juenemann KP. Fertility in cryptorchidism: Improved timing of fixation and treatment in an experimental model. Journal of Urology. 1987;138(411):1046-1047. X-3. [pmid: 2888906].
1262 Kogan SJ, Houman BZ, Reda EF, et al. Orchiopexy of the high undescended testis by division of the spermatic vessels: a critical review of 38 selected transections. J Urol. Jun. 1989;141(6):1416-9. X-4, X-5, X-6. [pmid: 2566690].
1263 Koh KBH. Beware the undescended testis and abdomimal mass. Australian and New Zealand Journal of Surgery. 1996;66(12):851-853. X-2, X-3. [pmid: 8996073].
1264 Kohler B, Biebermann H, Friedsam V, et al. Analysis of the Wilms’ tumor suppressor gene (WT1) in patients 46,XY disorders of sex development. J Clin Endocrinol Metab. Jul. 2011;96(7):E1131-6. X-2, X-3. [pmid: 21508141].
1265 Koide O, Iwai S, Baba K, et al. Identification of testicular atypical germ cells by an immunohistochemical technique for placental alkaline phosphatase. Cancer. Sep. 15. 1987;60(6):1325-30. X-2, X-3. [pmid: 3621115].
1266 Koivusalo A, Taskinen S, Rintala RJ. Cryptorchidism in boys with congenital abdominal wall defects. Pediatr Surg Int. Mar. 1998;13(2–3):143-5. X-2, X-3. [pmid: 9563028].
1267 Koizumi S, Shimizu H, Asami K, et al. Assessment of testicular biopsy after cessation of maintenance chemotherapy in childhood acute lymphoblastic leukemia: a report from the Children’s Cancer and Leukemia Study Group. Int J Hematol. Aug. 1994;60(2):137-43. X-2, X-3. [pmid: 7948963].
1268 Kojima Y, Mizuno K, Imura M, et al. Laparoscopic orchiectomy and subsequent internal ring closure for extra-abdominal testicular nubbin in children. Urology. Mar. 2009;73(3):515-9. discussion 519–20. X-4, X-5, X-6. [pmid: 19118886].
1269 Kojima Y, Mizuno K, Kamisawa H, et al. Laparoscopic management of nonpalpable testis: New treatment strategy. Journal of Endourology. 01. Apr. 2011;25(4):635-640. X-4, X-5, X-6. [pmid: 21381960].
1270 Kojima Y, Mizuno K, Kohri K, et al. Advances in Molecular Genetics of Cryptorchidism. Urology. September. 2009;74(3):571-578. X-1, X-2, X-3. [pmid: 19589567].
1271 Koksal IT, Ishak Y, Usta M, et al. Varicocele-induced testicular dysfunction may be associated with disruption of blood-testis barrier. Arch Androl. Jan–Feb. 2007;53(1):43-8. X-2, X-3. [pmid: 17364465].
1272 Koksal IT, Tefekli A, Usta M, et al. The role of reactive oxygen species in testicular dysfunction associated with varicocele. BJU Int. Sep. 2000;86(4):549-52. X-2, X-3. [pmid: 10971290].
1273 Kolligian ME, Kogan SJ, Beneck D. Intrascrotal hemangioendothelioma in infancy. Urology. Sep. 1997;50(3):456-8. X-2, X-3. [pmid: 9301719].
1274 Kolon TF, Clement MR, Cartwright L, et al. Transient asynchronous testicular growth in adolescent males with a varicocele. J Urol. Sep. 2008;180(3):1111-4. discussion 1114–5. X-2, X-3. [pmid: 18639288].
1275 Kolon TF, Wiener JS, Lewitton M, et al. Analysis of homeobox gene HOXA10 mutations in cryptorchidism. Journal of Urology. Jan. 1999;161(1):275-280. X-3. [pmid: 10037424].
1276 Komatsuzaki S, Aoki Y, Niihori T, et al. Mutation analysis of the SHOC2 gene in Noonan-like syndrome and in hematologic malignancies. J Hum Genet. Dec. 2010;55(12):801-9. X-2, X-3. [pmid: 20882035].
1277 Kondo Y, Ishikawa T, Yamaguchi K, et al. Predictors of improved seminal characteristics by varicocele repair. Andrologia. Feb. 2009;41(1):20-3. X-2, X-3. [pmid: 19143725].
1278 Kondoh N, Koh E, Matsui T, et al. Improvement of semen characteristics after surgical repair of bilateral testicular varicocele as compared to unilateral varicocele patients. Arch Androl. 1990;24(1):61-7. X-2, X-3. [pmid: 2327814].
1279 Konstantinos S, Alevizos A, Anargiros M, et al. Association between testicular microlithiasis, testicular cancer, cryptorchidism and history of ascending testis. Int Braz J Urol. Jul–Aug. 2006;32(4):434-8. discussion 439. X-2, X-3. [pmid: 16953910].
1280 Koo H, Chi JG. Congenital hydrocephalus--analysis of 49 cases. J Korean Med Sci. Dec. 1991;6(4):287-98. X-2, X-3. [pmid: 1844637].
1281 Korde LA, Premkumar A, Mueller C, et al. Increased prevalence of testicular microlithiasis in men with familial testicular cancer and their relatives. Br J Cancer. Nov. 18. 2008;99(10):1748-53. X-2, X-3. [pmid: 18841155].
1282 Kosan M, Gonulalan U, Ugurlu O, et al. Testicular microlithiasis in patients with scrotal symptoms and its relationship to testicular tumors. Urology. Dec. 2007;70(6):1184-6. X-2, X-3. [pmid: 18158043].
1283 Koscinski I, Wittemer C, Lefebvre-Khalil V, et al. Optimal management of extreme oligozoospermia by an appropriate cryopreservation programme. Human Reproduction. Oct. 2007;22(10):2679-2684. X-2, X-3. [pmid: 17673455].
1284 Koumantakis E, Matalliotakis I, Kyriakou D, et al. Increased levels of interleukin-8 in human seminal plasma. Andrologia. Nov. 1998;30(6):339-43. X-2, X-3. [pmid: 9835948].
1285 Kovac V. Prevention of fertility disturbances in oncological male patients. Radiology and Oncology. 1996;30(4):286-290. X-1, X-2, X-3.
1286 Kovachev LS. Possibilities of preperitoneal approach methods in the treatment of groin hernias. Preperitoneal approach methods. Int Surg. Jul–Sep. 1991;76(3):154-8. X-2, X-3. [pmid: 1834603].
1287 Kozina V, Geist D, Kubinova L, et al. Visualization of Reinke’s crystals in normal and cryptorchid testis. Histochemistry and Cell Biology. February. 2011;135(2):215-228. X-3. [pmid: 21287192].
1288 Kozminski M, Richards WH 3rd. Fly-casting method of intracorporeal laparoscopic knot tying. Urology. Oct. 1994;44(4):577-8. X-3, X-4, X-5, X-6. [pmid: 7941200].
1289 Kraft KH, Bhargava N, Schast AW, et al. Histological examination of solitary contralateral descended testis in congenital absence of testis. Journal of Urology. February. 2012;187(2):676-680. X-3. [pmid: 22177918].
1290 Kraft KH, Mucksavage P, Canning DA, et al. Histological findings in patients with cryptorchidism and testis-epididymis nonfusion. Journal of Urology. November. 2011;186(5):2045-2049. X-4, X-5, X-6. [pmid: 21944137].
1291 Kratz CP, Greene MH, Bratslavsky G, et al. A stratified genetic risk assessment for testicular cancer. Int J Androl. Aug. 2011;34(4 Pt 2):e98-102. X-2, X-3. 3145032. [pmid: 21564132].
1292 Kratzer SS, Ulbright TM, Talerman A, et al. Large cell calcifying sertoli cell tumor of the testis: Contrasting features of six malignant and six benign tumors and a review of the literature. American Journal of Surgical Pathology. 1997;21(11):1271-1280. X-2, X-3. [pmid: 9351565].
1293 Krhen I, Kulis T, Coric M, et al. OCT 4 immunohistochemistry in postpubertal cryptorchidism. Central European Journal of Medicine. April. 2011;6(2):243-246. X-2, X-3.
1294 Krieger NR, Shochat SJ, McGowan V, et al. Early hernia repair in the premature infant: long-term follow-up. J Pediatr Surg. Aug. 1994;29(8):978-81. discussion 981–2. X-2, X-3. [pmid: 7965533].
1295 Kristianslund S, Fossa SD, Kjellevold K. Bilateral malignant testicular germ cell cancer. Br J Urol. Feb. 1986;58(1):60-3. X-2, X-3. [pmid: 2868770].
1296 Kroovand RL, Al-Ansari RM, Perlmutter AD. Urethral and genital malformations in prune belly syndrome. J Urol. Jan. 1982;127(1):94-6. X-2, X-3. [pmid: 7057514].
1297 Krstic ZD. Modified orchiopexy: a “real dartos pocket”. Eur J Pediatr Surg. Apr. 1995;5(2):106-9. X-4, X-5, X-6. [pmid: 7612578].
1298 Kruse R, Schuppe HC, Malms J, et al. Anti-inflammatory and varicocele treatment in nonobstructive azoospermia. Andrologia. Aug. 2003;35(4):217-219. X-2, X-3. [pmid: 12950405].
1299 Ku JH, Kim YH, Jeon YS, et al. The preventive effect of systemic treatment with interferon-alpha2B for infertility from mumps orchitis. BJU Int. Nov. 1999;84(7):839-42. X-2, X-3. [pmid: 10532982].
1300 Ku JH, Son H, Kwak C, et al. Impact of varicocele on testicular volume in young men: significance of compensatory hypertrophy of contralateral testis. J Urol. Oct. 2002;168(4 Pt 1):1541-4. X-2, X-3. [pmid: 12352455].
1301 Kuber W. Testicular tumor and crytoptorchidism. Eur Urol. 1982;8(5):280-3. X-2, X-3. [pmid: 6126362].
1302 Kuber W, Kratzik C, Schwarz HP, et al. Experience with beta-HCG-positive seminoma. Br J Urol. Oct. 1983;55(5):555-9. X-2, X-3. [pmid: 6194845].
1303 Kuber W, Viehberger G, Zeillinger R, et al. Effects of the duration of therapy with the LHRH agonist D-ser (BUT)6 Azgly10-LHRH (ICI 118–630) on the steroid hormone content and the morphology of human testicular tissue in the treatment of patients with advanced prostate cancer. Urol Res. 1991;19(1):19-24. X-2, X-3. [pmid: 1827557].
1304 Kubota M, Okuyama N, Yamazaki S, et al. Is mobile testis a true pathological condition due to a gubernaculum abnormality?. Pediatr Surg Int. Jul. 2007;23(7):633-6. X-3, X-4, X-5, X-6. [pmid: 17503057].
1305 Kucukaydin M, Ozokutan BH, Turan C, et al. Malformation of the epididymis in undescended testis. Pediatr Surg Int. Dec. 1998;14(3):189-91. X-4, X-5, X-6. [pmid: 9880745].
1306 Kuenkel MR, Korth K. Rationale for antegrade sclerotherapy in varicoceles. Eur Urol. 1995;27(1):13-7. X-2, X-3. [pmid: 7744134].
1307 Kugelman A, Tubi A, Bader D, et al. Pre-auricular tags and pits in the newborn: The role of renal ultrasonography. Journal of Pediatrics. Sep. 2002;141(3):388-391. X-2, X-3. [pmid: 12219060].
1308 Kuhn JM, Mahoudeau JA, Billaud L, et al. Evaluation of diagnostic criteria for Leydig cell tumours in adult men revealed by gynaecomastia. Clin Endocrinol (Oxf). Apr. 1987;26(4):407-16. X-2, X-3. [pmid: 3308189].
1309 Kuligowska E, Baker CE, Oates RD. Male infertility: role of transrectal US in diagnosis and management. Radiology. Nov. 1992;185(2):353-60. X-2, X-3. [pmid: 1410338].
1310 Kulkarni BK, Oak SN, Patel MP, et al. Developmental anomalies associated with hypospadias. J Postgrad Med. Jul. 1991;37(3):140-3. X-2, X-3. [pmid: 1784025].
1311 Kulkarni JN, Desai SM, Phadke GK, et al. Improved management of abdominal undescended testicular tumors with bulky confluent retroperitoneal nodal metastases. J Urol. Oct. 1996;156(4):1341-4. X-2, X-3. [pmid: 8808867].
1312 Kulkarni JN, Kamat MR. Tumors in undescended testis. J Surg Oncol. Apr. 1991;46(4):257-60. X-2, X-3. [pmid: 1706815].
1313 Kulungowski AM, Schook CC, Alomari AI, et al. Vascular anomalies of the male genitalia. Journal of Pediatric Surgery. June. 2011;46(6):1214-1221. X-2, X-3. [pmid: 21683225].
1314 Kumagai J, Hsu SY, Matsumi H, et al. INSL3/Leydig insulin-like peptide activates the LGR8 receptor important in testis descent. Journal of Biological Chemistry. 30. Aug. 2002;277(35):31283-31286. X-2, X-3. [pmid: 12114498].
1315 Kumar D, Bremner DN, Brown PW. Fertility after orchiopexy for cryptorchidism: a new approach to assessment. Br J Urol. Nov. 1989;64(5):516-20. X-3, X-4, X-5, X-6. [pmid: 2575428].
1316 Kumar P, Kun LE, Hustu HO, et al. Survival outcome following isolated central nervous system relapse treated with additional chemotherapy and craniospinal irradiation in childhood acute lymphoblastic leukemia. Int J Radiat Oncol Biol Phys. Feb. 1. 1995;31(3):477-83. X-2, X-3. [pmid: 7852109].
1317 Kumar PA, Pitteloud N, Andrews PA, et al. Testis morphology in patients with idiopathic hypogonadotropic hypogonadism. Hum Reprod. Apr. 2006;21(4):1033-40. X-2, X-3. [pmid: 16396935].
1318 Kumar PV. Testicular leukemia relapse. Fine needle aspiration findings. Acta Cytol. Mar–Apr. 1998;42(2):312-6. X-2, X-3. [pmid: 9568129].
1319 Kumar PV, Owji SM, Khezri AA. Tuberculous orchitis diagnosed by fine needle aspiration cytology. Acta Cytol. Nov–Dec. 1996;40(6):1253-6. X-2, X-3. [pmid: 8960037].
1320 Kumar R, Gautam G, Gupta NP, et al. Role of testicular fine-needle aspiration cytology in infertile men with clinically obstructive azoospermia. Natl Med J India. Jan–Feb. 2006;19(1):18-20. X-2, X-3. [pmid: 16570680].
1321 Kumar R, Mukherjee S, Gupta NP. Intussusception Vasoepididymostomy With Longitudinal Suture Placement for Idiopathic Obstructive Azoospermia. Journal of Urology. April. 2010;183(4):1489-1492. X-2, X-3. [pmid: 20171699].
1322 Kumar RK, Shi EC, Duffy B. Cisapride and caesarean section: their role in babies with gastroschisis. J Paediatr Child Health. Apr. 1999;35(2):181-4. X-2, X-3. [pmid: 10365357].
1323 Kunej T, Zorn B, Peterlin B. Y chromosome microdeletions in infertile men with cryptorchidism. Fertil Steril. Jun. 2003;79(Suppl 3):1559-65. X-3. [pmid: 12801560].
1324 Kung AW, Zhong YY, Lam KS, et al. Induction of spermatogenesis with gonadotrophins in Chinese men with hypogonadotrophic hypogonadism. Int J Androl. Oct. 1994;17(5):241-7. X-2, X-3. [pmid: 7698849].
1325 Kuo JY, Huang WJ, Chiu AW, et al. Clinical experiences of germ cell tumor in cryptorchid testis. Kaohsiung J Med Sci. Jan. 1999;15(1):32-7. X-2, X-3. [pmid: 10063793].
1326 Kupeli S, Arikan N, Aydos K, et al. Multiparametric evaluation of testicular atrophy due to varicocele. Urol Int. 1991;46(2):189-92. X-2, X-3. [pmid: 2053229].
1327 Kurahashi N, Kasai S, Shibata T, et al. Parental and neonatal risk factors for cryptorchidism. Med Sci Monit. Jun. 2005;11(6):CR274-283. X-3, X-4, X-5, X-6. [pmid: 15917718].
1328 Kurien A, Mammen K, Jacob S. Role of fine needle aspiration cytology (FNAC) of testes in male infertility. Indian Journal of Urology. Apr. 2003;19(2):140-144. X-2, X-3.
1329 Kuroiwa T, Hasuo K, Yasumori K, et al. Transcatheter embolization of testicular vein for varicocele testis. Acta Radiol. Jul. 1991;32(4):311-4. X-2, X-3. [pmid: 1863502].
1330 Kurpisz M, Kasprzak M, Mazurkiewicz I. The easy formation of antisperm antibodies in prepubertal boys and the difficult humoral response in severe-combined immunodeficiency mice. Fertil Steril. Nov. 1996;66(5):805-8. X-2, X-3. [pmid: 8893689].
1331 Kursh ED. What is the incidence of varicocele in a fertile population?. Fertil Steril. Sep. 1987;48(3):510-1. X-2, X-3. [pmid: 3622800].
1332 Kuypers P, Kang N, Ellis H. Valveless testicular veins: A possible etiological factor in varicocele. Clinical Anatomy. 1992;5(2):113-118. X-2, X-3.
1333 Kvist E, Gyrtrup JH, Mejdahl S, et al. Outpatient orchiopexy and herniotomy in children. Acta Paediatr Scand. Sep. 1989;78(5):754-8. X-4, X-5, X-6. [pmid: 2574523].
1334 Kvist K, Thorup J, Byskov AG, et al. Cryopreservation of intact testicular tissue from boys with cryptorchidism. Hum Reprod. Feb. 2006;21(2):484-91. X-3. [pmid: 16210383].
1335 Kwon EO, Pareek G, Fracchia JA, et al. Scrotal reconstruction using rapid intraoperative tissue expansion: a preliminary report. J Urol. Jan. 2008;179(1):207-9. X-2, X-3. [pmid: 18001793].
1336 La Scala GC, Ein SH. Retractile testes: an outcome analysis on 150 patients. J Pediatr Surg. Jul. 2004;39(7):1014-7. X-3. [pmid: 15213889].
1337 La Vignera S, Calogero AE, Condorelli R, et al. Cryptorchidism and its long-term complications. Eur Rev Med Pharmacol Sci. Sep–Oct. 2009;13(5):351-6. X-3. [pmid: 19961040].
1338 Laberge JM, Nguyen LT, Homsy YL, et al. Bilateral Wilms’ tumors: Changing concepts in management. Journal of Pediatric Surgery. 1987;22(8):730-735. X-3. [pmid: 2821215].
1339 Lacerda HM, Richiardi L, Pettersson A, et al. Cancer risk in mothers of men operated for undescended testis. PLoS ONE. 2010;5(12):1-4. e14285. X-3.
1340 Lackgren G, Ploen L. The morphology of the human undescended testis with special reference to the Sertoli cell and puberty. Int J Androl. Feb. 1984;7(1):23-38. X-3, X-4, X-5, X-6. [pmid: 6143732].
1341 Lackner J, Schatzl G, Koller A, et al. Treatment of testicular cancer: influence on pituitary-gonadal axis and sexual function. Urology. Aug. 2005;66(2):402-6. X-2, X-3. [pmid: 16040104].
1342 Lackner JE, Mark I, Schatzl G, et al. Hypogonadism and androgen deficiency symptoms in testicular cancer survivors. Urology. Apr. 2007;69(4):754-8. X-2, X-3. [pmid: 17445664].
1343 Laghari AA, Jamal A. Evaluation of morbidity and recurrence in bilateral repair of inguinal hernias. Journal of the College of Physicians and Surgeons Pakistan. 1999;9(8):371-373. X-2, X-3.
1344 Lagmay J, Termuhlen A, Fung B, et al. Primary testicular presentation of ALK-1-negative anaplastic large cell lymphoma in a pediatric patient. J Pediatr Hematol Oncol. May. 2009;31(5):330-2. X-2, X-3. [pmid: 19415011].
1345 Lahdenne P, Dunkel L, Heikinheimo M, et al. Hypergonadotropic hypogonadism and sperm abnormalities in men born with benign sacrococcygeal teratoma. Journal of Andrology. 1991;12(4):226-230. X-2, X-3. [pmid: 1917687].
1346 Lai PP, Bernstein MJ, Kim H, et al. Radiation therapy for stage I and IIA testicular seminoma. Int J Radiat Oncol Biol Phys. Jan. 15. 1994;28(2):373-9. X-2, X-3. [pmid: 8276652].
1347 Lais A, Ferro F. Trans-scrotal approach for surgical correction of cryptorchidism and congenital anomalies of the processus vaginalis. Eur Urol. 1996;29(2):235-8. discussion 238–9. X-4, X-5, X-6. [pmid: 8647155].
1348 Lal A, Kwan E, al Mahr M, et al. Molecular detection of acute lymphoblastic leukaemia in boys with testicular relapse. Mol Pathol. Oct. 1998;51(5):277-81. X-2, X-3. [pmid: 10193523].
1349 Lamesch AJ. Monorchidism or unilateral anorchidism. Langenbecks Arch Chir. 1994;379(2):105-8. X-2, X-3. [pmid: 7910927].
1350 Lange J, Peterson SM, Takashima JR, et al. Risk factors for end stage renal disease in non-wt1-syndromic wilms tumor. Journal of Urology. August. 2011;186(2):378-386. X-2, X-3. [pmid: 21683387].
1351 Laor E, Fisch H, Tennenbaum S, et al. Unilateral testicular torsion: abnormal histological findings in the contralateral testis--cause or effect?. Br J Urol. May. 1990;65(5):520-3. X-2, X-3. [pmid: 2354319].
1352 Laron Z, Arad J, Gurewitz R, et al. Age at first conscious ejaculation: a milestone in male puberty. Helv Paediatr Acta. Mar. 1980;35(1):13-20. X-2, X-3. [pmid: 6106006].
1353 Laron Z, Dickerman Z, Ritterman I, et al. Follow-up of boys with unilateral compensatory testicular hypertrophy. Fertil Steril. Mar. 1980;33(3):297-301. X-2, X-3. [pmid: 6102528].
1354 Larsen HP, Thorup J, Skovgaard LT, et al. Long-term cultures of testicular biopsies from boys with cryptorchidism: effect of FSH and LH on the number of germ cells. Hum Reprod. Feb. 2002;17(2):383-9. X-4, X-5, X-6. [pmid: 11821283].
1355 Larsson LT, Kullendorff CM. Late surgical problems in children born with abdominal wall defects. Ann Chir Gynaecol. 1990;79(1):23-5. X-2, X-3. [pmid: 2141463].
1356 Law GS, Perez LM, Joseph DB. Two-stage Fowler-Stephens orchiopexy with laparoscopic clipping of the spermatic vessels. J Urol. Sep. 1997;158(3 Pt 2):1205-7. X-4, X-5, X-6. [pmid: 9258174].
1357 Law H, Mushtaq I, Williams S, et al. Risk of germ cell malignancy in children with XY intersex versus isolated cryptorchidism by immunohistochemistry. Fetal Pediatr Pathol. Mar–Apr. 2006;25(2):95-105. X-2, X-3. [pmid: 16908459].
1358 Law H, Mushtaq I, Wingrove K, et al. Histopathological features of testicular regression syndrome: relation to patient age and implications for management. Fetal Pediatr Pathol. Mar–Apr. 2006;25(2):119-29. X-2, X-3. [pmid: 16908461].
1359 Le Coultre C, Cuendet A, Richon J. Frequency of testicular atrophy following incarcerated hernia. Z Kinderchir. Apr. 1983;38(Suppl):39-41. X-2, X-3. [pmid: 6637144].
1360 Lebed B, Packer M, Husmann D, et al. Results and complications of adolescent varicocele repair with intraoperative sodium morrhuate sclerotherapy. J Urol. Oct. 2008;180(4 Suppl):1837-41. X-2, X-3. [pmid: 18721963].
1361 LeBlanc E, Caty A, Dargent D, et al. Extraperitoneal laparoscopic para-aortic lymph node dissection for early stage nonseminomatous germ cell tumors of the testis with introduction of a nerve sparing technique: description and results. J Urol. Jan. 2001;165(1):89-92. X-2, X-3. [pmid: 11125371].
1362 Lechter A, Lopez G, Martinez C, et al. Anatomy of the gonadal veins: A reappraisal. Surgery. 1991;109(6):735-739. X-1, X-2, X-3. [pmid: 2042092].
1363 Lee A, Park SJ, Lee HK, et al. Acute idiopathic scrotal edema: ultrasonographic findings at an emergency unit. Eur Radiol. Aug. 2009;19(8):2075-80. X-2, X-3. [pmid: 19259680].
1364 Lee CF, Lin PY, Chen IH, et al. Microsurgical subinguinal varicocelectomy-An experience of 327 operations in 224 patients. Urological Science. March. 2010;21(1):30-37. X-2, X-3.
1365 Lee CH, Dellon AL. Surgical management of groin pain of neural origin. J Am Coll Surg. Aug. 2000;191(2):137-42. X-2, X-3. [pmid: 10945356].
1366 Lee CT, Thirumoorthy T, Lim KB, et al. Epidemiology of acute epididymo-orchitis in Singapore. Ann Acad Med Singapore. May. 1989;18(3):320-3. X-2, X-3. [pmid: 2505664].
1367 Lee GH, Cohen AJ. CT imaging of abdominal hernias. AJR Am J Roentgenol. Dec. 1993;161(6):1209-13. X-2, X-3. [pmid: 8249727].
1368 Lee JS, Park HJ, Seo JT. What is the indication of varicocelectomy in men with nonobstructive azoospermia?. Urology. Feb. 2007;69(2):352-5. X-2, X-3. [pmid: 17320677].
1369 Lee KF, Tam YT, Zuo Y, et al. Characterization of an acrosome protein VAD1.2/AEP2 which is differentially expressed in spermatogenesis. Mol Hum Reprod. Aug. 2008;14(8):465-74. X-2, X-3. [pmid: 18621766].
1370 Lee LM, Johnson HW, McLoughlin MG. Microdissection and radiographic studies of the arterial vasculature of the human testes. J Pediatr Surg. Jun. 1984;19(3):297-301. X-2, X-3. [pmid: 6747794].
1371 Lee LM, Wright JE, McLoughlin MG. Testicular torsion in the adult. J Urol. Jul. 1983;130(1):93-4. X-1, X-2, X-3. [pmid: 6864923].
1372 Lee RK, Li PS, Goldstein M. Simultaneous vasectomy and varicocelectomy: indications and technique. Urology. Aug. 2007;70(2):362-5. X-2, X-3. [pmid: 17826510].
1373 Leenen AS, Riebel TW. Testicular microlithiasis in children: sonographic features and clinical implications. Pediatr Radiol. Aug. 2002;32(8):575-9. X-2, X-3. [pmid: 12136348].
1374 Leeners B, Sauer I, Schefels J, et al. Prune-belly syndrome: Therapeutic options including in utero placement of a vesicoamniotic shunt. Journal of Clinical Ultrasound. 2000;28(9):500-507. X-2, X-3. [pmid: 11056030].
1375 Legare C, Thabet M, Sullivan R. Expression of heat shock protein 70 in normal and cryptorchid human excurrent duct. Mol Hum Reprod. Mar. 2004;10(3):197-202. X-2, X-3. [pmid: 14981147].
1376 Leibl BJ, Kraft B, Redecke JD, et al. Are postoperative complaints and complications influenced by different techniques in fashioning and fixing the mesh in transperitoneal laparoscopic hernioplasty? Results of a prospective randomized trial. World J Surg. Dec. 2002;26(12):1481-4. X-2, X-3. [pmid: 12297933].
1377 Lemack GE, Uzzo RG, Schlegel PN, et al. Microsurgical repair of the adolescent varicocele. J Urol. Jul. 1998;160(1):179-81. X-2, X-3. [pmid: 9628646].
1378 Lemcke B, Zentgraf J, Behre HM, et al. Long-term effects on testicular function of high-dose testosterone treatment for excessively tall stature. J Clin Endocrinol Metab. Jan. 1996;81(1):296-301. X-2, X-3. [pmid: 8550767].
1379 Lenz S, Giwercman A, Elsborg A, et al. Ultrasonic testicular texture and size in 444 men from the general population: correlation to semen quality. Eur Urol. 1993;24(2):231-8. X-2, X-3. [pmid: 8104150].
1380 Lenz S, Skakkebaek NE, Hertel NT. Abnormal ultrasonic pattern in contralateral testes in patients with unilateral testicular cancer. World J Urol. Suppl 1. 1996;14:S55-8. X-2, X-3. [pmid: 8738413].
1381 Leonhartsberger N, Ramoner R, Aigner F, et al. Increased incidence of Leydig cell tumours of the testis in the era of improved imaging techniques. BJU Int. Nov. 2011;108(10):1603-7. X-2, X-3. [pmid: 21631694].
1382 Lerchl A, Keck C, Spiteri-Grech J, et al. Diurnal variations in scrotal temperature of normal men and patients with varicocele before and after treatment. Int J Androl. Jun. 1993;16(3):195-200. X-2, X-3. [pmid: 8359934].
1383 Leroy X, Rigot JM, Aubert S, et al. Value of frozen section examination for the management of nonpalpable incidental testicular tumors. Eur Urol. Oct. 2003;44(4):458-60. X-2, X-3. [pmid: 14499681].
1384 Leung WY, Poon M, Fan TW, et al. Testicular volume of boys after inguinal herniotomy: combined clinical and radiological follow-up. Pediatr Surg Int. 1999;15(1):40-1. X-2, X-3. [pmid: 9914353].
1385 Levalle OA, Zylbersztein C, Aszpis S, et al. Serum luteinizing hormone pulsatility and intratesticular testosterone and oestradiol concentrations in idiopathic infertile men with high and normal follicle stimulating hormone serum concentrations. Hum Reprod. May. 1994;9(5):781-7. X-2, X-3. [pmid: 7929722].
1386 Levard G, Laberge JM. The fate of undescended testes in patients with gastroschisis. Eur J Pediatr Surg. Jun. 1997;7(3):163-5. X-4, X-5, X-6. [pmid: 9241504].
1387 Levine LA, Matkov TG. Microsurgical denervation of the spermatic cord as primary surgical treatment of chronic orchialgia. J Urol. Jun. 2001;165(6 Pt 1):1927-9. X-2, X-3. [pmid: 11371883].
1388 Levine LA, Matkov TG, Lubenow TR. Microsurgical denervation of the spermatic cord: a surgical alternative in the treatment of chronic orchialgia. J Urol. Mar. 1996;155(3):1005-7. X-2, X-3. [pmid: 8583547].
1389 Levinger U, Gornish M, Gat Y, et al. Is varicocele prevalence increasing with age?. Andrologia. Jun. 2007;39(3):77-80. X-1, X-2, X-3. [pmid: 17683466].
1390 Levy HL, Vargas JE, Waisbren SE, et al. Reproductive fitness in maternal homocystinuria due to cystathionine beta-synthase deficiency. J Inherit Metab Dis. Aug. 2002;25(4):299-314. X-2, X-3. [pmid: 12227460].
1391 Lewin LM, Shalev DP, Weissenberg R, et al. Carnitine and acylcarnitines in semen from azoospermic patients. Fertil Steril. Aug. 1981;36(2):214-8. X-2, X-3. [pmid: 6114878].
1392 Lewis RW, Garcia RR. The results of epididymal ablation by sclerosing agents in the nonhuman primate. Fertil Steril. Mar. 1984;41(3):465-9. X-2, X-3. [pmid: 6698239].
1393 Ley SB, Leonard JM. Male hypogonadotropic hypogonadism: factors influencing response to human chorionic gonadotropin and human menopausal gonadotropin, including prior exogenous androgens. J Clin Endocrinol Metab. Oct. 1985;61(4):746-52. X-2, X-3. [pmid: 3928676].
1394 Li X, Nokkala E, Yan W, et al. Altered structure and function of reproductive organs in transgenic male mice overexpressing human aromatase. Endocrinology. Jun. 2001;142(6):2435-42. X-2, X-3. [pmid: 11356692].
1395 Li X, Strauss L, Makela S, et al. Multiple structural and functional abnormalities in the p450 aromatase expressing transgenic male mice are ameliorated by a p450 aromatase inhibitor. Am J Pathol. Mar. 2004;164(3):1039-48. X-2, X-3. [pmid: 14982857].
1396 Li YX, Coucke PA, Qian TN, et al. Clinical characteristics, prognosis, and treatment of pelvic cryptorchid seminoma. Int J Radiat Oncol Biol Phys. May. 1. 1997;38(2):351-7. X-2, X-3. [pmid: 9226323].
1397 Li YX, Coucke PA, Qian TN, et al. Seminoma arising in corrected and uncorrected inguinal cryptorchidism: treatment and prognosis in 66 patients. Int J Radiat Oncol Biol Phys. May. 1. 1997;38(2):343-50. X-2, X-3. [pmid: 9226322].
1398 Libman JL, Segal R, Baazeem A, et al. Microanatomy of the left and right spermatic cords at subinguinal microsurgical varicocelectomy: comparative study of primary and redo repairs. Urology. Jun. 2010;75(6):1324-7. X-2, X-3. [pmid: 20188403].
1399 Liebert PS. Undescended testis - Evaluation and treatment. Emergency and Office Pediatrics. 1994;7(4):95-97. X-1.
1400 Lien HH, Talle K. Normal and anomalous structures simulating retroperitoneal lymphadenopathy at computed tomography. Acta Radiol. Jul–Aug. 1988;29(4):385-90. X-3, X-4, X-5, X-6. [pmid: 2900643].
1401 Lim DJ, Liu XL, Sutkowski DM, et al. Growth of an androgen-sensitive human prostate cancer cell line, LNCaP, in nude mice. Prostate. 1993;22(2):109-18. X-2, X-3. [pmid: 7681204].
1402 Lim HN, Hughes IA, Ross Hawkins J. Clinical and molecular evidence for the role of androgens and WT1 in testis descent. Molecular and Cellular Endocrinology. 20. Dec. 2001;185(1–2):43-50. X-3. [pmid: 11738793].
1403 Lim HN, Nixon RM, Chen H, et al. Evidence that longer androgen receptor polyglutamine repeats are a causal factor for genital abnormalities. J Clin Endocrinol Metab. Jul. 2001;86(7):3207-10. X-2, X-3. [pmid: 11443190].
1404 Lim SM. Surgery in transsexuals. Ann Acad Med Singapore. Jan. 1986;15(1):122-6. X-2, X-3. [pmid: 3707030].
1405 Lima M, Tursini S, Ruggeri G, et al. Laparoscopically assisted anorectal pull-through for high imperforate anus: three years’ experience. J Laparoendosc Adv Surg Tech A. Feb. 2006;16(1):63-6. X-2, X-3. [pmid: 16494552].
1406 Lima Neto EV, Goldenberg A, Juca MJ. Prospective study on the effects of a polypropylene prosthesis on testicular volume and arterial flow in patients undergoing surgical correction for inguinal hernia. Acta Cir Bras. Jul–Aug. 2007;22(4):266-71. X-2, X-3. [pmid: 17625664].
1407 Lin ADY, Levin RM, Kogan BA, et al. Alteration of contractile and regulatory proteins in estrogen-induced hypertrophy of female rabbit bladder. Urology. Dec. 2006;68(5):1139-1143. X-2, X-3. [pmid: 17113912].
1408 Lin AE, Singh KE, Strauss A, et al. An additional patient with mycophenolate mofetil embryopathy: Cardiac and facial analyses. American Journal of Medical Genetics, Part A. April. 2011;155(4):748-756. X-2, X-3. [pmid: 21594997].
1409 Lin BJ, Chen KK, Chen MT, et al. The time for serum testosterone to reach castrate level after bilateral orchiectomy or oral estrogen in the management of metastatic prostatic cancer. Urology. Jun. 1994;43(6):834-7. X-2, X-3. [pmid: 8197647].
1410 Lin HY, Lin SP, Chen YJ, et al. Clinical characteristics and survival of trisomy 13 in a medical center in Taiwan, 1985–2004. Pediatr Int. Jun. 2007;49(3):380-6. X-2, X-3. [pmid: 17532840].
1411 Lin WW, Kim ED, Quesada ET, et al. Unilateral testicular injury from external trauma: evaluation of semen quality and endocrine parameters. J Urol. Mar. 1998;159(3):841-3. X-2, X-3. [pmid: 9474164].
1412 Lin YM, Hsu CC, Wu MH, et al. Successful testicular sperm extraction and paternity in an azoospermic man after bilateral postpubertal orchiopexy. Urology. Feb. 2001;57(2):365. X-4, X-5, X-6. [pmid: 11182364].
1413 Lindhagen J, Nilsson S, Seeman T, et al. Torsion of the testis--a misinterpreted diagnosis in the young adult. Ann Chir Gynaecol. 1980;69(4):157-60. X-2, X-3. [pmid: 7469369].
1414 Linke J, Loy V, Dieckmann KP. Prevalence of testicular intraepithelial neoplasia in healthy males. J Urol. May. 2005;173(5):1577-9. X-2, X-3. [pmid: 15821489].
1415 Lischka A, Herkner K, Pollak A. Diagnosis of peripheral androgen insensitivity in a male infant excretion analysis. Arch Androl. 1989;22(2):143-7. X-3. [pmid: 2568823].
1416 Little SE, Hanks SP, King-Underwood L, et al. Frequency and heritability of WT1 mutations in nonsyndromic Wilms’ tumor patients: a UK Children’s Cancer Study Group Study. J Clin Oncol. Oct. 15. 2004;22(20):4140-6. X-2, X-3. [pmid: 15483024].
1417 Liu KKW, Leung MWY. Update on the management of common urological problems in children. Hong Kong Practitioner. Feb. 2005;27(2):53-60. X-1, X-2, X-3.
1418 Liu RS, Chen YK, Hsu HS, et al. Reappraisal of scrotal scintigraphy in evaluation of varicocoeles. Nucl Med Commun. Jul. 1994;15(7):540-4. X-2, X-3. [pmid: 7970431].
1419 Liu SF, Lu GX, Liu G, et al. Cloning of a full-length cDNA of human testis-specific spermatogenic cell apoptosis inhibitor TSARG2 as a candidate oncogene. Biochem Biophys Res Commun. Jun. 18. 2004;319(1):32-40. X-3. [pmid: 15158438].
1420 Liu TC, Qiu JS. Pathological findings on peripheral nerves, lymph nodes, and visceral organs of leprosy. Int J Lepr Other Mycobact Dis. Sep. 1984;52(3):377-83. X-2, X-3. [pmid: 6541205].
1421 Livne PM, Savir A, Servadio C. Re-orchiopexy: advantages and disadvantages. Eur Urol. 1990;18(2):137-9. X-4, X-5, X-6. [pmid: 1977588].
1422 Lizza EF, Marmar JL, Schmidt SS. Transseptal crossed vasovasostomy. Journal of Urology. 1985;134(6):1131-1132. X-2, X-3. [pmid: 4057402].
1423 Lloyd-Lavery A, Ali I, Espinosa O, et al. British Journal of Dermatology. [Conference Abstract]. July. Conference: British Association of Dermatologists 89th Annual Meeting. Glasgow United Kingdom. Conference Start: 20090707 Conference End: 20090710. Conference Publication: (var.pagings). 2009;161:51. X-2, X-3.
1424 Lobaccaro JM, Medlej R, Berta P, et al. PCR analysis and sequencing of the SRY sex determining gene in four patients with bilateral congenital anorchia. Clin Endocrinol (Oxf). Feb. 1993;38(2):197-201. X-3. [pmid: 8435900].
1425 Lobo MV, Arenas MI, Alonso FJ, et al. Nestin, a neuroectodermal stem cell marker molecule, is expressed in Leydig cells of the human testis and in some specific cell types from human testicular tumours. Cell Tissue Res. Jun. 2004;316(3):369-76. X-2, X-3. [pmid: 15127288].
1426 Loftus BM, Gilmartin LG, O’Brien MJ, et al. Intratubular germ cell neoplasia of the testis: identification by placental alkaline phosphatase immunostaining and argyrophilic nucleolar organizer region quantification. Hum Pathol. Sep. 1990;21(9):941-8. X-2, X-3. [pmid: 1697556].
1427 Londergan TA, Hochman HI, Goldberger N. Postoperative pain following outpatient pediatric urologic surgery: A comparison of anesthetic techniques. Urology. 1994;44(4):572-576. X-2, X-3. [pmid: 7941199].
1428 Looijenga LH, de Leeuw H, van Oorschot M, et al. Stem cell factor receptor (c-KIT) codon 816 mutations predict development of bilateral testicular germ-cell tumors. Cancer Res. Nov. 15. 2003;63(22):7674-8. X-2, X-3. [pmid: 14633689].
1429 Looijenga LHJ, Hersmus R, De Leeuw BHCGM, et al. Gonadal tumours and DSD. Best Practice and Research: Clinical Endocrinology and Metabolism. 2010;24(2):291-310. X-3. [pmid: 20541153].
1430 Lopez G, Jmenez S, Martinez R, et al. Glycosylation pattern in the appendix testis in children with cryptorchidism. Prep Biochem Biotechnol. Jan. 2011;41(1):22-9. X-2, X-3. [pmid: 21229461].
1431 Lopez Teijon M, Garcia F, Serra O, et al. Semen quality in a population of volunteers from the province of Barcelona. Reprod Biomed Online. Oct. 2007;15(4):434-44. X-2, X-3. [pmid: 17908407].
1432 Lorenzi P, Spicher VM, Laubereau B, et al. Antiretroviral therapies in pregnancy: maternal, fetal and neonatal effects. Swiss HIV Cohort Study, the Swiss Collaborative HIV and Pregnancy Study, and the Swiss Neonatal HIV Study. AIDS. Dec. 24. 1998;12(18):F241-7. X-2, X-3. [pmid: 9875571].
1433 Lothe RA, Heimdal K, Lier ME, et al. High resolution chromosome banding in search of germ line mutations applied on testicular cancer patients. Cancer Genet Cytogenet. Mar. 1992;59(1):62-7. X-2, X-3. [pmid: 1555193].
1434 Loughlin KR. Complications of vasovasostomy. Urol Clin North Am. May. 1988;15(2):243-8. X-2, X-3. [pmid: 3381371].
1435 Loy V, Dieckmann KP. Prevalence of contralateral testicular intraepithelial neoplasia (carcinoma in situ) in patients with testicular germ cell tumour. Results of the German multicentre study. Eur Urol. 1993;23(1):120-2. X-2, X-3. [pmid: 8386640].
1436 Ludwig AK, Katalinic A, Thyen U, et al. Physical health at 5.5 years of age of term-born singletons after intracytoplasmic sperm injection: results of a prospective, controlled, single-blinded study. Fertil Steril. Jan. 2009;91(1):115-24. X-2, X-3. [pmid: 18206144].
1437 Lugo Vicente HL. The pediatric inguinal hernia: is contralateral exploration justified?. Bol Asoc Med P R. Jan–Feb. 1995;87(1–2):8-11. X-2, X-3. [pmid: 7786359].
1438 Luk JM, Lee NPY, Shum CK, et al. Acrosome-specific gene AEP1: Identification, characterization and roles in spermatogenesis. Journal of Cellular Physiology. Dec. 2006;209(3):755-766. X-2, X-3. [pmid: 16924657].
1439 Luks FI, Hansbrough F, Klotz DH Jr, et al. Early gender assignment in true hermaphroditism. J Pediatr Surg. Dec. 1988;23(12):1122-6. X-2, X-3. [pmid: 3236177].
1440 Lukusa T, Fryns JP, Kleczkowska A, et al. Role of gonadal dysgenesis in gonadoblastoma induction in 46, XY individuals. The Leuven experience in 46, XY pure gonadal dysgenesis and testicular feminization syndromes. Genet Couns. 1991;2(1):9-16. X-2, X-3. [pmid: 1741980].
1441 Lund DP, Mitchell J, Kharasch V, et al. Congenital diaphragmatic hernia: the hidden morbidity. J Pediatr Surg. Feb. 1994;29(2):258-62. discussion 262–4. X-2, X-3. [pmid: 8176602].
1442 Lund L, Tang YC, Roebuck D, et al. Testicular catch-up growth after varicocele correction in adolescents. Pediatr Surg Int. 1999;15(3–4):234-7. X-2, X-3. [pmid: 10370032].
1443 Lundsberg LS, Bracken MB, Belanger K. Occupationally related magnetic field exposure and male subfertility. Fertil Steril. Feb. 1995;63(2):384-91. X-2, X-3. [pmid: 7843447].
1444 Lupien M, Dievart A, Morales CR, et al. Expression of constitutively active Notch1 in male genital tracts results in ectopic growth and blockage of efferent ducts, epididymal hyperplasia and sterility. Dev Biol. Dec. 15. 2006;300(2):497-511. X-2, X-3. [pmid: 17046738].
1445 Luque Mialdea R, Sanabia J, Martin Crespo R, et al. Microsurgical treatment of varicocele in adolescents. Eur J Pediatr Surg. Apr. 1995;5(2):101-3. X-2, X-3. [pmid: 7612576].
1446 Lykkesfeldt G, Hoyer H, Ibsen HH, et al. Steroid sulphatase deficiency disease. Clin Genet. Sep. 1985;28(3):231-7. X-2, X-3. [pmid: 2866054].
1447 Lynch DF Jr, Richie JP. Supraclavicular node biopsy in staging testis tumors. J Urol. Jan. 1980;123(1):39-40. X-2, X-3. [pmid: 7351720].
1448 Lyon RP, Marshall S, Scott MP. Varicocele in childhood and adolescence: implication in adulthood infertility?. Urology. Jun. 1982;19(6):641-4. X-2, X-3. [pmid: 7090115].
1449 Lyon RP, Marshall S, Scott MP. Varicocele in youth. West J Med. Jun. 1983;138(6):832-4. X-2, X-3. [pmid: 6613110].
1450 Ma SZ, Li XH, Hu J. Acellular extracellular matrix for inguinal hernia repair. Hernia. Jun. 2006;10(3):229-231. X-2, X-3. [pmid: 16440129].
1451 Ma T, Guo J, Yang W, et al. Testicular cancer in patients after treatment of cryptorchidism. Chinese-German Journal of Clinical Oncology. January. 2011;10(1):40-42. X-4, X-5, X-6.
1452 Mabboux P, Brisset S, Aboura A, et al. Pure and complete trisomy 18p due to a supernumerary marker chromosome associated with moderate mental retardation. Am J Med Genet A. Apr. 1. 2007;143(7):727-33. X-2, X-3. [pmid: 17330860].
1453 MacMahon RA, Cussen LJ. Detection of gonadal carcinoma in situ in childhood and implications for management. Aust N Z J Surg. Sep. 1991;61(9):667-9. X-3. [pmid: 1877934].
1454 MacMahon RA, Cussen LJ. Unilateral enlargement of the testis in childhood: does it need exploration?. J Pediatr Surg. Jan. 1991;26(1):68-9. X-2, X-3. [pmid: 2005529].
1455 Madgar I, Seidman DS, Levran D, et al. Micromanipulation improves in-vitro fertilization results after epididymal or testicular sperm aspiration in patients with congenital absence of the vas deferens. Hum Reprod. Oct. 1996;11(10):2151-4. X-2, X-3. [pmid: 8943520].
1456 Maghsoudi H, Pourzand A. Giant prosthetic reinforcement of the visceral sac: the Stoppa groin hernia repair in 234 patients. Ann Saudi Med. May–Jun. 2005;25(3):228-32. X-2, X-3. [pmid: 16119524].
1457 Magid MS, Ma ZW, Girardi SK, et al. The acid-fast stain is a superior stain for use in the mean mature spermatid count for testicular biopsies. J Androl. May–Jun. 1998;19(3):261-5. X-2, X-3. [pmid: 9639043].
1458 Magoha GA. Testicular cancer in Nigerians. East Afr Med J. Sep. 1995;72(9):554-6. X-2, X-3. [pmid: 7498039].
1459 Mahafza WS, Haroun AA, Al-Hadidy AM, et al. Testicular microlithiasis in patients with varicocele: A prospective study. Journal of the Bahrain Medical Society. October. 2007;19(4):137-141. X-3, X-4, X-5, X-6.
1460 Mahmoud AM, Comhaire FH, Vereecken A, et al. Inhibition and steroid response to testicular stimulation with purse FSH (Metrodin) in infertile men with unilateral cryptorchidism. Andrologia. 1996;28(2):103-108. X-2. [pmid: 8849044].
1461 Mahmoud AM, Goemaere S, El-Garem Y, et al. Testicular volume in relation to hormonal indices of gonadal function in community-dwelling elderly men. J Clin Endocrinol Metab. Jan. 2003;88(1):179-84. X-2, X-3. [pmid: 12519849].
1462 Mahmoud AM, Tuyttens CL, Comhaire FH. Clinical and biological aspects of male immune infertility: A case- controlled study of 86 cases. Andrologia. 1996;28(4):191-196. X-2, X-3. [pmid: 8844111].
1463 Mahomed AA, McLean V. Cost analysis of minimally invasive surgery in a pediatric setting. J Laparoendosc Adv Surg Tech A. Jun. 2007;17(3):375-9. X-4, X-5, X-6. [pmid: 17570792].
1464 Mahoney DH Jr, Gonzales ET, Ferry GD, et al. Childhood acute leukemia: a search for occult extramedullary disease prior to discontinuation of chemotherapy. Cancer. Nov. 1. 1981;48(9):1964-6. X-2, X-3. [pmid: 6945902].
1465 Mai PL, Friedlander M, Tucker K, et al. The International Testicular Cancer Linkage Consortium: a clinicopathologic descriptive analysis of 461 familial malignant testicular germ cell tumor kindred. Urol Oncol. Sep–Oct. 2010;28(5):492-9. X-2, X-3. [pmid: 19162511].
1466 Main KM, Kiviranta H, Virtanen HE, et al. Flame retardants in placenta and breast milk and cryptorchildism in newborn boys. Environmental Health Perspectives. Oct. 2007;115(10):1519-1526. X-3. [pmid: 17938745].
1467 Main KM, Toppari J, Virtanen HE, et al. International Journal of Andrology. [Conference Abstract]. October. Conference: 6th European Congress of Andrology. Athens Greece. Conference Start: 20100929 Conference End: 20101001. Conference Publication: (var.pagings). 2010;33:30. X-3.
1468 Maizels M, Zaontz MR, Houlihan DL, et al. In-office ultrasonography to image the kidneys and bladder of children. J Urol. Oct. 1987;138(4 Pt 2):1031-5. X-4, X-5, X-6. [pmid: 3309372].
1469 Majeed HA, Ghandour K, Shahin HM. The acute scrotum in Arab children with familial Mediterranean fever. Pediatr Surg Int. 2000;16(1–2):72-4. X-2, X-3. [pmid: 10663841].
1470 Manak E, Waldschmidt J, Albrecht T, et al. Ultrasound examination of paediatric testicles after laparoscopic laser dissection of internal testicular vessels in cryptorchism. Eur J Pediatr Surg. Oct. 2002;12(5):322-6. X-4, X-5, X-6. [pmid: 12469259].
1471 Mandelbaum I, Williams SD, Einhorn LH. Aggressive surgical management of testicular carcinoma metastatic to lungs and mediastinum. Ann Thorac Surg. Sep. 1980;30(3):224-9. X-2, X-3. [pmid: 7425701].
1472 Mandell J, Bromley B, Peters CA, et al. Prenatal sonographic detection of genital malformations. Journal of Urology. 1995;153(6):1994-1996. X-2, X-3. [pmid: 7752382].
1473 Mangoud AM, Emara MW, Ghobish A, et al. Hydrocele in filarial and non filarial patients. Histopathological, histochemical and ultrastructural studies. J Egypt Soc Parasitol. Apr. 1993;23(1):43-54. X-2, X-3. [pmid: 8482882].
1474 Manivel JC, Jessurun J, Wick MR, et al. Placental alkaline phosphatase immunoreactivity in testicular germ-cell neoplasms. Am J Surg Pathol. Jan. 1987;11(1):21-9. X-2, X-3. [pmid: 3538918].
1475 Manivel JC, Pettinato G, Reinberg Y, et al. Prune belly syndrome: clinicopathologic study of 29 cases. Pediatr Pathol. 1989;9(6):691-711. X-2, X-3. [pmid: 2602227].
1476 Manning MA, Woodward PJ. Testicular epidermoid cysts: sonographic features with clinicopathologic correlation. J Ultrasound Med. May. 2010;29(5):831-7. X-2, X-3. [pmid: 20427796].
1477 Manoharan M, Vyas S, Araki M, et al. Concurrent radical retropubic prostatectomy and Lichtenstein inguinal hernia repair through a single modified Pfannenstiel incision: a 3-year experience. BJU Int. Aug. 2006;98(2):341-4. X-2, X-3. [pmid: 16879675].
1478 Marekovic Z, Derezic D, Krhen I, et al. Urogenital war injuries. Mil Med. May. 1997;162(5):346-8. X-2, X-3. [pmid: 9155106].
1479 Mares AJ, Shkolnik A, Sacks M, et al. Aberrant (ectopic) adrenocortical tissue along the spermatic cord. J Pediatr Surg. Jun. 1980;15(3):289-92. X-2, X-3. [pmid: 6103925].
1480 Mariano MB, Tefilli MV. Laparoscopic retroperitoneal lymphadenectomy after chemotherapy for stage IIb testicular tumors. Brazilian Journal of Urology. 2001;27(6):527-534. X-2, X-3.
1481 Marin P, Ferlin A, Moro E, et al. Different insulin-like 3 (INSL3) gene mutations not associated with human cryptorchidism. J Endocrinol Invest. Apr. 2001;24(4):RC13-5. X-3. [pmid: 11383919].
1482 Mark E, Castells S, Glassberg K, et al. Deficiency of androgen receptors in male pseudohermaphroditism. Urology. Feb. 1983;21(2):168-71. X-2, X-3. [pmid: 6823726].
1483 Markey CM, Jequier AM, Meyer GT. Effects of ischaemia on the caput epididymis and its relationship to higher epididymal obstruction: a qualitative study in the ram. Int J Androl. Aug. 1995;18(4):185-96. X-2, X-3. [pmid: 7591191].
1484 Maroof SA, Khan K, Khan Y, et al. Torsion of testicular appendix as a cause of acute scrotum in children: Experience in surgical management at lady reading hospital Peshawar. Journal of Medical Sciences. 2009;17(1):40-44. X-3, X-4, X-5, X-6.
1485 Marrocco G, Bruner E, Vallasciani S, et al. Do patients with hypospadias and cryptorchidism share a common phenotype? Case-control study of an Italian paediatric population. Journal of Pediatric Urology. Dec. 2007;3(6):477-479. X-3. [pmid: 18947798].
1486 Marth D, Scheidegger J, Studer UE. Ultrasonography of testicular tumors. Urol Int. 1990;45(4):237-40. X-2, X-3. [pmid: 2163557].
1487 Martinez-Pineiro L Jr, Cerezo E, Cozar JM, et al. Value of testicular ultrasound in the evaluation of blunt scrotal trauma without haematocele. Br J Urol. Mar. 1992;69(3):286-90. X-2, X-3. [pmid: 1568102].
1488 Martini AC, Tissera A, Estofan D, et al. Overweight and seminal quality: A study of 794 patients. Fertility and Sterility. October. 2010;94(5):1739-1743. X-2, X-3. [pmid: 20056217].
1489 Martorell M, Gil-Salom M, Perez-Valles A, et al. Presence of human papillomavirus DNA in testicular biopsies from nonobstructive azoospermic men. Arch Pathol Lab Med. Sep. 2005;129(9):1132-6. X-2, X-3. [pmid: 16119985].
1490 Mason MD, Featherstone T, Olliff J, et al. Inguinal and iliac lymph node involvement in germ cell tumours of the testis: implications for radiological investigation and for therapy. Clin Oncol (R Coll Radiol). May. 1991;3(3):147-50. X-2, X-3. [pmid: 1676904].
1491 Massad CA, Cohen MB, Kogan BA, et al. Morphology and histochemistry of infant testes in the prune belly syndrome. J Urol. Dec. 1991;146(6):1598-600. X-2, X-3. [pmid: 1682513].
1492 Masterson TA, Wedmid A, Sandhu JS, et al. Outcomes after radical prostatectomy in men receiving previous pelvic radiation for non-prostate malignancies. BJU Int. Aug. 2009;104(4):482-5. X-2, X-3. [pmid: 19239447].
1493 Matalliotakis I, Fragouli Y, Kyriakou D, et al. Enhancement of soluble CD23 levels in the seminal plasma of infertile men with idiopathic testicular lesion. Archives of Andrology. 1999;43(2):105-111. X-2, X-3. [pmid: 10543572].
1494 Matalliotakis IM, Cakmak H, Fragouli Y, et al. Increased IL-18 levels in seminal plasma of infertile men with genital tract infections. Am J Reprod Immunol. Jun. 2006;55(6):428-33. X-2, X-3. [pmid: 16674600].
1495 Mathew RM, Vandenberghe R, Garcia-Merino A, et al. Orchiectomy for suspected microscopic tumor in patients with anti-Ma2-associated encephalitis. Neurology. Mar. 20. 2007;68(12):900-5. X-2, X-3. [pmid: 17151337].
1496 Mathews RI, Perlman E, Marsh DW, et al. Gonadal morphology in cloacal exstrophy: implications in gender assignment. BJU Int. Jul. 1999;84(1):99-100. X-2, X-3. [pmid: 10444133].
1497 Matsuda T, Muguruma K, Hiura Y, et al. Seminal tract obstruction caused by childhood inguinal herniorrhaphy: results of microsurgical reanastomosis. J Urol. Mar. 1998;159(3):837-40. X-2, X-3. [pmid: 9474163].
1498 Matsumiya K, Namiki M, Kondoh N, et al. New indication of testis biopsy for azoospermia: a clinical study in Japanese patients. Int J Urol. Jun. 1994;1(2):177-80. X-2, X-3. [pmid: 7627854].
1499 Matsumiya K, Namiki M, Takahara S, et al. Clinical study of azoospermia. Int J Androl. Jun. 1994;17(3):140-2. X-2, X-3. [pmid: 7960188].
1500 Matthews GJ, Goldstein M. Microsurgical autogenous sperm reservoir with simultaneous epididymal sperm aspiration: a novel approach for the man with surgically unreconstructable obstruction. Tech Urol. Fall. 1995;1(3):120-5. X-2, X-3. [pmid: 9118379].
1501 Matthews GJ, Matthews ED, Goldstein M. Induction of spermatogenesis and achievement of pregnancy after microsurgical varicocelectomy in men with azoospermia and severe oligoasthenospermia. Fertil Steril. Jul. 1998;70(1):71-5. X-2, X-3. [pmid: 9660424].
1502 Mattila-Vuori A, Salo M, Iisalo E, et al. Local and systemic immune response to surgery under balanced anaesthesia in children. Paediatr Anaesth. 2000;10(4):381-8. X-2, X-3. [pmid: 10886694].
1503 Maurer B, Gromoll J, Simoni M, et al. Prevalence of Y chromosome microdeletions in infertile men who consulted a tertiary care medical centre: the Munster experience. Andrologia. Jan. 2001;33(1):27-33. X-2, X-3. [pmid: 11167516].
1504 Mayagoitia JC, Prieto-Diaz Chavez E, Suarez D, et al. Predictive factors comparison of complications and recurrences in three tension-free herniorraphy techniques. Hernia. Apr. 2006;10(2):147-151. X-2, X-3. [pmid: 16453076].
1505 Mayr J, Pusch HH, Schimpl G, et al. Semen quality and gonadotropin levels in patients operated upon for cryptorchidism. Pediatric Surgery International. Jun. 1996;11(5–6):354-358. X-4, X-5, X-6.
1506 Mayr J, Rune GM, Fasching G, et al. Sertoli cell morphology in retractile prepubertal testes. Pediatric Surgery International. 1994;9(1–2):90-94. X-3.
1507 Mazen I, El-Ruby M, El-Bassyouni HT. Variable associations of Klinefelter syndrome in children. J Pediatr Endocrinol Metab. Oct. 2010;23(10):985-9. X-2, X-3. [pmid: 21158208].
1508 Mazen I, El-Ruby M, Kamal R, et al. Screening of genital anomalies in newborns and infants in two egyptian governorates. Horm Res Paediatr. 2010;73(6):438-42. X-2, X-3. [pmid: 20407231].
1509 Mazzilli F, Rossi T, Marchesini M, et al. Superoxide anion in human semen related to seminal parameters and clinical aspects. Fertil Steril. Oct. 1994;62(4):862-8. X-1, X-2, X-3. [pmid: 7926100].
1510 McCandless SE, Saal HM, Braddock SR, et al. Clinical report - Health supervision for children with Prader-Willi syndrome. Pediatrics. January. 2011;127(1):195-204. X-1, X-2, X-3. [pmid: 21187304].
1511 McClure RD, Hricak H. Scrotal ultrasound in the infertile man: detection of subclinical unilateral and bilateral varicoceles. J Urol. Apr. 1986;135(4):711-5. X-2, X-3. [pmid: 3514958].
1512 McCombe AW, Scobie WG. Torsion of scrotal contents in children. Br J Urol. Feb. 1988;61(2):148-50. X-2, X-3. [pmid: 3349280].
1513 McCullough R, Marshall FF, Berry SJ, et al. The influence of epididymal agenesis on the development and maturation of the testis: Experimental model and clinical correlations. Urological Research. 1984;12(3):165-170. X-2, X-3. [pmid: 6485184].
1514 McElreavey K, Bashamboo A. Genetic disorders of sex differentiation. Endocrinology. (Advances in Experimental Medicine and Biology. 707). 2011:91-99. X-1, X-2, X-3.
1515 McGillicuddy JE. Prospective randomized comparison of the Shouldice and Lichtenstein hernia repair procedures. Archives of Surgery. Sep. 1998;133(9):974-978. X-2, X-3. [pmid: 9749850].
1516 McGlynn KA, Sakoda LC, Rubertone MV, et al. Body size, dairy consumption, puberty, and risk of testicular germ cell tumors. Am J Epidemiol. Feb. 15. 2007;165(4):355-63. X-2, X-3. [pmid: 17110638].
1517 McGregor DB, Halverson K, McVay CB. The unilateral pediatric inguinal hernia: Should the contralateral side by explored?. J Pediatr Surg. Jun. 1980;15(3):313-7. X-2, X-3. [pmid: 7381667].
1518 McQuiston L, Macneily A, Liu D, et al. Computer enhanced visual learning method to train urology residents in pediatric orchiopexy provided a consistent learning experience in a multi-institutional trial. J Urol. Oct. 2010;184(4 Suppl):1748-53. X-2. [pmid: 20728179].
1519 Meador KJ, Baker GA, Finnell RH, et al. In utero antiepileptic drug exposure: Fetal death and malformations. Neurology. Aug. 2006;67(3):407-412. X-2, X-3. [pmid: 16894099].
1520 Megarbane A, Rassi S, Estephan F, et al. Post-natal short stature, short limbs, brachydactyly, facial abnormalities, and delayed bone age: a new syndrome?. Am J Med Genet A. Feb. 15. 2004;125A(1):57-60. X-3. [pmid: 14755467].
1521 Meglin AJ, Balotin RJ, Jelinek JS, et al. Cloacal exstrophy: radiologic findings in 13 patients. AJR Am J Roentgenol. Dec. 1990;155(6):1267-72. X-2, X-3. [pmid: 2122678].
1522 Mehta A, Boekelheide K, Sigman M. Journal of Andrology. [Conference Abstract]. March-April. Conference: 35th Annual Meeting of the American Society of Andrology, ASA. Houston, TX United States. Conference Start: 20100410 Conference End: 20100413. Conference Publication: (var.pagings). 2010;31:44-45. X-2, X-3.
1523 Meij-de Vries A, Hack WW, Heij HA, et al. Perioperative surgical findings in congenital and acquired undescended testis. J Pediatr Surg. Sep. 2010;45(9):1874-81. X-4, X-5, X-6. [pmid: 20850635].
1524 Meirow D, Schenker JG. Cancer and male infertility. Human Reproduction. 1995;10(8):2017-2022. X-1, X-2, X-3. [pmid: 8567834].
1525 Melton LJ 3rd, Alothman KI, Achenbach SJ, et al. Decline in bilateral orchiectomy for prostate cancer in Olmsted county, Minnesota, 1956–2000. Mayo Clin Proc. Dec. 2001;76(12):1199-203. X-4, X-5, X-6. [pmid: 11761500].
1526 Memish ZA, Venkatesh S. Brucellar epididymo-orchitis in Saudi Arabia: A retrospective study of 26 cases and review of the literature. BJU International. 2001;88(1):72-76. X-2, X-3. [pmid: 11446850].
1527 Menchini-Fabris GF, Canale D, Basile-Fasolo C, et al. Varicocele and male subfertility: prognostical criteria in the surgical treatment. Andrologia. Jan–Feb. 1985;17(1):16-21. X-2, X-3. [pmid: 3993999].
1528 Mendez R, Tellado MG, Somoza I, et al. Ectopic adrenal tissue in the spermatic cord in pediatric patients: Surgical implications. International Braz J Urol. Mar. 2006;32(2):202-207. X-4, X-5, X-6. [pmid: 16650300].
1529 Mendez-Gallart R, Bautista Casasnovas A, Estevez Martinez E, et al. Reactive hydrocele after laparoscopic Palomo varicocele ligation in pediatrics. Arch Esp Urol. Sep. 2010;63(7):532-6. X-2, X-3. [pmid: 20876949].
1530 Mendez-Gallart R, Bautista-Casasnovas A, Estevez-Martinez E, et al. Laparoscopic Palomo varicocele surgery: lessons learned after 10 years’ follow up of 156 consecutive pediatric patients. J Pediatr Urol. Apr. 2009;5(2):126-31. X-2, X-3. [pmid: 19083272].
1531 Meng MV, Black LD, Cha I, et al. Impaired spermatogenesis in men with congenital absence of the vas deferens. Hum Reprod. Mar. 2001;16(3):529-33. X-2, X-3. [pmid: 11228224].
1532 Mengel W, Wronecki K, Schroeder J, et al. Histopathology of the cryptorchid testis. Urol Clin North Am. Oct. 1982;9(3):331-8. X-3. [pmid: 6128815].
1533 Mennicke K, Klingenberg RD, Bals-Pratsch M, et al. Rational approach to genetic testing of cystic fibrosis (CF) in infertile men. Andrologia. Feb. 2005;37(1):1-9. X-2, X-3. [pmid: 15644056].
1534 Mercan A, El-Kerdawy H, Bhavsaar B, et al. The effect of timing and temperature of oral fluids ingested after minor surgery in preschool children on vomiting: A prospective, randomized, clinical study. Paediatric Anaesthesia. October. 2011;21(10):1066-1070. X-4, X-5, X-6. [pmid: 21668799].
1535 Merck C, Angervall L, Kindblom L, et al. Myxofibrosarcoma. A malignant soft tissue tumor of fibroblastic-histiocytic origin. A clinicopathologic and prognostic study of 110 cases using multivariate analysis. Acta Pathologica Microbiologica et Immunologica Scandinavica Supplementum. [Journal]. 1983;91(Suppl 282). X-2, X-3.
1536 Merino G, Murrieta S, Rodriguez L, et al. Sexually transmitted diseases and related genital pathologies in oligozoospermia. Arch Androl. Sep–Oct. 1993;31(2):87-94. X-1, X-2, X-3. [pmid: 8215696].
1537 Merksz M, Toth J. The state of the testicle and the epididymis associated with exstrophy of the bladder in undescended testes. Acta Chir Hung. 1990;31(4):297-301. X-3, X-4, X-5, X-6. [pmid: 1983451].
1538 Meschede D, Behre HM, Nieschlag E. Endocrine and spermatological characteristics of 135 patients with bilateral megalotestis. Andrologia. Jul–Aug. 1995;27(4):207-12. X-2, X-3. [pmid: 7486030].
1539 Mesrobian HG, Chassaignac JM, Laud PW. The presence or absence of an impalpable testis can be predicted from clinical observations alone. BJU Int. Jul. 2002;90(1):97-9. X-4, X-5, X-6. [pmid: 12081779].
1540 Metin A, Bulut O, Temizkan M. Relationship between the left spermatic vein diameter measured by ultrasound and palpated varicocele and Doppler ultrasound findings. Int Urol Nephrol. 1991;23(1):65-8. X-2, X-3. [pmid: 1938219].
1541 Metts IJC, Kotkin L, Kasper S, et al. Genital malformations and coexistent urinary tract or spinal anomalies in patients with imperforate anus. Journal of Urology. 1997;158(3 SUPPL):1298-1300. X-2, X-3. [pmid: 9258199].
1542 Meza MP, Amundson GM, Aquilina JW, et al. Color flow imaging in children with clinically suspected testicular torsion. Pediatr Radiol. 1992;22(5):370-3. X-2, X-3. [pmid: 1408449].
1543 Micic M, Micic S, Ganev V, et al. Cytogenetic analysis of men with cryptorchidism and reduced fertility. Urologia Internationalis. 1987;42(1):58-60. X-3. [pmid: 2884765].
1544 Middelburg KJ, Heineman MJ, Haadsma ML, et al. Neurological condition of infants born after in vitro fertilization with preimplantation genetic screening. Pediatric Research. April. 2010;67(4):430-434. X-2, X-3. [pmid: 20057341].
1545 Middendorff R, Davidoff M, Holstein AF. Neuroendocrine marker substances in human Leydig cells--changes by disturbances of testicular function. Andrologia. Sep–Oct. 1993;25(5):257-62. X-3. [pmid: 7902679].
1546 Middleton WD, Bell MW. Analysis of intratesticular arterial anatomy with emphasis on transmediastinal arteries. Radiology. Oct. 1993;189(1):157-60. X-2, X-3. [pmid: 8372187].
1547 Mieusset R, Bujan L, Mansat A. Effects of artificial cryptorchidism on sperm morphology. Fertility and Sterility. 1987;47(1):150-155. X-2, X-3. [pmid: 3792568].
1548 Mieusset R, Bujan L, Mansat A, et al. Hyperthermia and human spermatogenesis: enhancement of the inhibitory effect obtained by ‘artificial cryptorchidism’. Int J Androl. Aug. 1987;10(4):571-80. X-2, X-3. [pmid: 2888735].
1549 Mieusset R, Bujan L, Plantavid M, et al. Increased levels of serum follicle-stimulating hormone and luteinizing hormone associated with intrinsic testicular hyperthermia in oligospermic infertile men. J Clin Endocrinol Metab. Feb. 1989;68(2):419-25. X-2, X-3. [pmid: 2493031].
1550 Mieusset R, Fouda PJ, Vaysse P, et al. Increase in testicular temperature in case of cryptorchidism in boys. Fertil Steril. Jun. 1993;59(6):1319-21. X-4, X-5, X-6. [pmid: 8098695].
1551 Mieusset R, Grandjean H, Mansat A, et al. Inhibiting effect of artificial cryptorchidism on spermatogenesis. Fertil Steril. Apr. 1985;43(4):589-94. X-2, X-3. [pmid: 3987927].
1552 Mihmanli I, Kantarci F, Kulaksizoglu H, et al. Testicular size and vascular resistance before and after hydrocelectomy. AJR Am J Roentgenol. Nov. 2004;183(5):1379-85. X-2, X-3. [pmid: 15505307].
1553 Mikaelsson C, Arnbjornsson E, Lindhagen T, et al. Routine laparoscopy for nonpalpable testes?. J Laparoendosc Adv Surg Tech A. Jun. 1999;9(3):239-41. X-4, X-5, X-6. [pmid: 10414539].
1554 Mikuz G, Schwarz S, Hopfel-Kreiner I, et al. Leydig cell tumor of the testis. Morphological and endocrinological investigations in two cases. Eur Urol. 1980;6(5):293-300. X-2, X-3. [pmid: 7398702].
1555 Milam DF, Cartwright PC, Snow BW. Urological manifestations of sacrococcygeal teratoma. Journal of Urology. 1993;149(3):574-576. X-2, X-3. [pmid: 8437268].
1556 Miliaras D, Vlahakis-Miliaras E, Anagnostopoulos D, et al. Gross morphologic variations and histologic changes in cryptorchid testes. Pediatr Surg Int. Feb. 1997;12(2–3):158-62. X-4, X-5, X-6.
1557 Milkins RC, Landsdown MJR, Wedgwood KR, et al. Laparoscopic hernia repair: A prospective study of 409 cases. Minimally Invasive Therapy. 1993;2(5):237-242. X-2, X-3.
1558 Miller JS, Lee TK, Epstein JI, et al. The utility of microscopic findings and immunohistochemistry in the classification of necrotic testicular tumors: a study of 11 cases. Am J Surg Pathol. Sep. 2009;33(9):1293-8. X-2, X-3. [pmid: 19461507].
1559 Miller KD, Coughlin MT, Lee PA. Fertility after unilateral cryptorchidism. Paternity, time to conception, pretreatment testicular location and size, hormone and sperm parameters. Horm Res. 2001;55(5):249-53. X-4, X-5, X-6. [pmid: 11740148].
1560 Mineur P, De Cooman S, Hustin J. Feminizing testicular Leydig cell tumor: Hormonal profile before and after unilateral orchidectomy. Journal of Clinical Endocrinology and Metabolism. 1987;64(4):686-691. X-2, X-3. [pmid: 3818898].
1561 Minevich E, Wacksman J, Lewis AG, et al. Inguinal microsurgical varicocelectomy in the adolescent: technique and preliminary results. J Urol. Mar. 1998;159(3):1022-4. X-2, X-3. [pmid: 9474223].
1562 Mininberg DT, Rodger JC, Bedford JM. Ultrastructural evidence of the onset of testicular pathological conditions in the cryptorchid human testis within the first year of life. J Urol. Oct. 1982;128(4):782-4. X-4, X-5, X-6. [pmid: 6128431].
1563 Mininberg DT, Schlossberg S. The role of the epididymis in testicular descent. J Urol. Jun. 1983;129(6):1207-8. X-4, X-5, X-6. [pmid: 6133966].
1564 Mir IS, Mohsin M, Kirmani O, et al. Is laparoscospic orchidectomy the treatment of choice in adults with impalpable testis in rural hospitals in the developing world?. Trop Doct. Jan. 2009;39(1):12-5. X-4, X-5, X-6. [pmid: 19211413].
1565 Mirilas P, De Almeida M. Absence of antisperm surface antibodies in prepubertal boys with cryptorchidism and other anomalies of the inguinoscrotal region before and after surgery. J Urol. Jul. 1999;162(1):177-81. X-3, X-4, X-5, X-6. [pmid: 10379783].
1566 Mirilas P, Mentessidou A, Kontis E, et al. Sonographic evidence for patency of the processus vaginalis in children with acquired undescended testis. International Journal of Andrology. February. 2011;34(1):49-54. X-4, X-5, X-6. [pmid: 20345877].
1567 Mirilas P, Tsakiridis O. Initial development of an electronic testis rigidity tester. ScientificWorldJournal. 2011;11:673-86. X-2, X-3. [pmid: 21442145].
1568 Mirshemirani A, Ghorobi J, Roozroukh M, et al. Urogenital tract abnormalities associated with congenital Anorectal malformations. Iranian Journal of Pediatrics. Jun. 2008;18(2):171-174. X-3.
1569 Mishriki SF, Winkle DC, Frank JD. Fixation of a single testis: always, sometimes or never. Br J Urol. Mar. 1992;69(3):311-3. X-2, X-3. [pmid: 1568106].
1570 Misra D, Hewitt G, Potts SR, et al. Inguinal herniotomy in young infants, with emphasis on premature neonates. J Pediatr Surg. Nov. 1994;29(11):1496-8. X-2, X-3. [pmid: 7844731].
1571 Misra D, Mushtaq I, Drake DP, et al. Associated urologic anomalies in low imperforate anus are capable of causing significant morbidity: a 15-year experience. Urology. Aug. 1996;48(2):281-3. X-2, X-3. [pmid: 8753741].
1572 Misra M, MacLaughlin DT, Donahoe PK, et al. The role of Mullerian inhibiting substance in the evaluation of phenotypic female patients with mild degrees of virilization. J Clin Endocrinol Metab. Feb. 2003;88(2):787-92. X-2, X-3, X-9. [pmid: 12574214].
1573 Miyagawa Y, Tsujimura A, Matsumiya K, et al. Outcome of gonadotropin therapy for male hypogonadotropic hypogonadism at university affiliated male infertility centers: a 30-year retrospective study. J Urol. Jun. 2005;173(6):2072-5. X-2, X-3. [pmid: 15879837].
1574 Miyake H, Hara I, Takechi Y, et al. Long-term follow-up in patients with bilateral testicular germ cell tumors: A report of ten cases. International Journal of Clinical Oncology. Aug. 1999;4(4):244-247. X-2, X-3.
1575 Mizrak SC, Chikhovskaya JV, Sadri-Ardekani H, et al. Embryonic stem cell-like cells derived from adult human testis. Hum Reprod. Jan. 2010;25(1):158-67. X-2, X-3. [pmid: 19815622].
1576 Mizuno K, Kojima Y, Kurokawa S, et al. Identification of differentially expressed genes in human cryptorchid testes using suppression subtractive hybridization. J Urol. Mar. 2009;181(3):1330-7. discussion 1337. X-3, X-4, X-5, X-6. [pmid: 19157425].
1577 Moazzam M, Siddiqui KM, Ather MH, et al. Surgical ligation of scrotal varicocele for male factor infertility is a valid option of treatment. J Pak Med Assoc. Aug. 2006;56(8):363-5. X-2, X-3. [pmid: 16967788].
1578 Moerman P, Fryns JP, Goddeeris P, et al. Pathogenesis of the prune-belly syndrome: a functional urethral obstruction caused by prostatic hypoplasia. Pediatrics. Apr. 1984;73(4):470-5. X-3. [pmid: 6231520].
1579 Moerman P, Verbeken E, Fryns JP, et al. The Meckel Syndrome. Pathological and cytogenetic observations in eight cases. Hum Genet. 1982;62(3):240-5. X-2, X-3. [pmid: 6132872].
1580 Mohammed YA, Shawky RM, Soliman AAS, et al. Chromosomal study in newborn infants with congenital anomalies in Assiut University hospital: Cross-sectional study. Egyptian Journal of Medical Human Genetics. May. 2011;12(1):79-90. X-2, X-3.
1581 Mohr AM, Pham AM, Lavery RF, et al. Management of trauma to the male external genitalia: the usefulness of American Association for the Surgery of Trauma organ injury scales. J Urol. Dec. 2003;170(6 Pt 1):2311-5. X-2, X-3. [pmid: 14634403].
1582 Mol NM, Sorensen N, Weihe P, et al. Spermaturia and serum hormone concentrations at the age of puberty in boys prenatally exposed to polychlorinated biphenyls. European Journal of Endocrinology. 2002;146(3):357-363. X-3. [pmid: 11888842].
1583 Moller H, Skakkebaek NE. Risks of testicular cancer and cryptorchidism in relation to socio-economic status and related factors: case-control studies in Denmark. Int J Cancer. May. 3. 1996;66(3):287-93. X-3, X-4, X-5, X-6. [pmid: 8621244].
1584 Moller H, Skakkebaek NE. Testicular cancer and cryptorchidism in relation to prenatal factors: case-control studies in Denmark. Cancer Causes Control. Nov. 1997;8(6):904-12. X-3. [pmid: 9427433].
1585 Molnar D, Leb J, Hidvegi J, et al. Follow-up examination of patients with undescended testicles. Acta Paediatr Acad Sci Hung. 1981;22(3):177-85. X-4, X-5, X-6. [pmid: 6118009].
1586 Moltz L, Schwartz U, Pickartz H, et al. XY gonadal dysgenesis: aberrant testicular differentiation in the presence of H-Y antigen. Obstet Gynecol. Jul. 1981;58(1):17-25. X-2, X-3. [pmid: 7195530].
1587 Montanari E, Trinchieri A, Zanetti G, et al. Andrological laparoscopy. Annales d’Urologie. 1995;29(2):106-112. X-2. [pmid: 7645994].
1588 Montgomery P, Shanti G. The influence of bilateral orchiectomy on self-concept: a pilot study. J Adv Nurs. Dec. 1996;24(6):1249-56. X-2, X-3. [pmid: 8953362].
1589 Montironi R. Intratubular germ cell neoplasia of the testis: Testicular intraepithelial neoplasia. European Urology. 01. Jun. 2002;41(6):651-654. X-1, X-2, X-3. [pmid: 12074783].
1590 Moore GP, Alden AW, Rodman GH. Is closed diagnostic peritoneal lavage contraindicated in patients with previous abdominal surgery?. Acad Emerg Med. Apr. 1997;4(4):287-90. X-2, X-3. [pmid: 9107327].
1591 Moore SW. Down syndrome and Hirschsprung’s disease: A significant relationship?. International Journal on Disability and Human Development. Oct. 2006;5(4):369-375. X-3.
1592 Moorthy B, Papadopolou M, Shaw DG, et al. Depot testosterone in boys with anorchia or gonadotrophin deficiency: effect on growth rate and adult height. Arch Dis Child. Feb. 1991;66(2):197-9. X-3, X-4, X-5, X-6. [pmid: 2001104].
1593 Mor Y, Pinthus JH, Nadu A, et al. Testicular fixation following torsion of the spermatic cord--does it guarantee prevention of recurrent torsion events?. J Urol. Jan. 2006;175(1):171-3. discussion 173–4. X-2, X-3. [pmid: 16406900].
1594 Moradi M, Karimian B, Moradi A. Adult orchidopexy: A survey on necessity of intraoperative testicular biopsy. Nephro-Urology Monthly. 2011;3(3):196-200. X-3, X-4, X-5, X-6.
1595 Moraes AJ, Pereira RM, Cocuzza M, et al. Minor sperm abnormalities in young male post-pubertal patients with juvenile dermatomyositis. Braz J Med Biol Res. Dec. 2008;41(12):1142-7. X-2, X-3. [pmid: 19148379].
1596 Morag B, Rubinstein ZJ, Goldwasser B, et al. Percutaneous venography and occlusion in the management of spermatic varicoceles. AJR Am J Roentgenol. Sep. 1984;143(3):635-40. X-2, X-3. [pmid: 6331750].
1597 Morag B, Rubinstein ZJ, Madgar I, et al. The role of spermatic venography after surgical high ligation of the left spermatic veins: diagnosis and percutaneous occlusion. Urol Radiol. 1985;7(1):32-4. X-2, X-3. [pmid: 3984115].
1598 Morales V, Santana P, Diaz R, et al. Intratesticular delivery of tumor necrosis factor-alpha and ceramide directly abrogates steroidogenic acute regulatory protein expression and Leydig cell steroidogenesis in adult rats. Endocrinology. Nov. 2003;144(11):4763-72. X-2, X-3. [pmid: 12959973].
1599 Morales-Barrera R, Valverde C, Rodon J, et al. Bilateral testicular germ cell tumours: a single hospital experience. Clin Transl Oncol. Apr. 2010;12(4):299-302. X-2, X-3. [pmid: 20462840].
1600 Morales-Surez-Varela MM, Toft GV, Jensen MS, et al. Parental occupational exposure to endocrine disrupting chemicals and male genital malformations: A study in the danish national birth cohort study. Environmental Health: A Global Access Science Source. 2011;10((1)(3)). X-3.
1601 Morecroft JA, Stringer MD, Higgins M, et al. Follow-up after inguinal herniotomy or surgery for hydrocele in boys. Br J Surg. Dec. 1993;80(12):1613-4. X-2, X-3. [pmid: 8298941].
1602 Morel Y, Rey R, Teinturier C, et al. Aetiological diagnosis of male sex ambiguity: A collaborative study. European Journal of Pediatrics. 2002;161(1):49-59. X-3, X-4, X-5, X-6. [pmid: 11808880].
1603 Moreno-Garcia M, Miranda EB. Chromosomal anomalies in cryptorchidism and hypospadias. J Urol. Nov. 2002;168(5):2170-2. discussion 2172. X-3. [pmid: 12394752].
1604 Moretti E, Di Cairano G, Capitani S, et al. Cryptorchidism and semen quality: a TEM and molecular study. J Androl. Jan–Feb. 2007;28(1):194-9. X-3, X-4, X-5, X-6. [pmid: 16988323].
1605 Mori M, Davies TW, Tsukamoto T, et al. Maternal and other factors of cryptorchidism--a case-control study in Japan. Kurume Med J. 1992;39(2):53-60. X-2, X-3. [pmid: 1357225].
1606 Moriya K, Mitsui T, Tanaka H, et al. Long-term outcome of pituitary-gonadal axis and gonadal growth in patients with hypospadias at puberty. J Urol. Oct. 2010;184(4 Suppl):1610-4. X-2, X-3. [pmid: 20728133].
1607 Moro E, Marin P, Rossi A, et al. Y chromosome microdeletions in infertile men with varicocele. Mol Cell Endocrinol. Mar. 30. 2000;161(1–2):67-71. X-2, X-3. [pmid: 10773394].
1608 Mosharafa AA, Foster RS, Bihrle R, et al. Does retroperitoneal lymph node dissection have a curative role for patients with sex cord-stromal testicular tumors?. Cancer. Aug. 15. 2003;98(4):753-7. X-2, X-3. [pmid: 12910519].
1609 Moss AR, Osmond D, Bacchetti P, et al. Hormonal risk factors in testicular cancer. A case-control study. Am J Epidemiol. Jul. 1986;124(1):39-52. X-2, X-3. [pmid: 2872797].
1610 Moul JW, Paulson DF, Walther PJ. Refusal of cancer therapy in testicular cancer: Recognizing and preventing a significant problem. World Journal of Urology. 1990;8(1):58-62. X-3.
1611 Moyssakis IE, Rallidis LS, Guida GF, et al. Incidence and evolution of carcinoid syndrome in the heart. J Heart Valve Dis. Nov. 1997;6(6):625-30. X-2, X-3. [pmid: 9427132].
1612 Mozingo DW, Walters MJ, Otchy DP, et al. Properitoneal synthetic mesh repair of recurrent inguinal hernias. Surg Gynecol Obstet. Jan. 1992;174(1):33-5. X-2, X-3. [pmid: 1729746].
1613 Muffly KE, McWhorter CA, Bartone FF, et al. The absence of premalignant changes in the cryptorchid testis before adulthood. J Urol. Mar. 1984;131(3):523-5. X-3. [pmid: 6142124].
1614 Mulhall JP, Ghaly SW, Aviv N, et al. The utility of optical loupe magnification for testis sperm extraction in men with nonobstructive azoospermia. J Androl. Mar–Apr. 2005;26(2):178-81. X-2, X-3. [pmid: 15713823].
1615 Mulhall JP, Stokes S, Andrawis R, et al. Simultaneous microsurgical vasal reconstruction and varicocele ligation: safety profile and outcomes. Urology. Sep. 1997;50(3):438-42. X-2, X-3. [pmid: 9301713].
1616 Muller J, Ritzen EM, Ivarsson SA, et al. Management of males with 45,X/46,XY gonadal dysgenesis. Horm Res. 1999;52(1):11-4. X-3. [pmid: 10640893].
1617 Muller J, Skakkebaek NE, Nielsen OH, et al. Cryptorchidism and testis cancer. Atypical infantile germ cells followed by carcinoma in situ and invasive carcinoma in adulthood. Cancer. Aug. 15. 1984;54(4):629-34. X-3, X-4, X-5, X-6. [pmid: 6146398].
1618 Muller J, Skakkebaek NE, Ratcliffe SG. Quantified testicular histology in boys with sex chromosome abnormalities. International Journal of Andrology. 1995;18(2):57-62. X-3. [pmid: 7665210].
1619 Mumperow E, Lauke H, Holstein AF, et al. Further practical experiences in the recognition and management of carcinoma in situ of the testis. Urol Int. 1992;48(2):162-6. X-2, X-3. [pmid: 1374974].
1620 Muneer A, Laghari ZH, Shaikh AR, et al. Gynaecomastia: management in a developing country. J Ayub Med Coll Abbottabad. Jul–Sep. 2009;21(3):7-11. X-2, X-3. [pmid: 20929002].
1621 Muroya K, Okuyama T, Goishi K, et al. Sex-determining gene(s) on distal 9p: clinical and molecular studies in six cases. J Clin Endocrinol Metab. Sep. 2000;85(9):3094-100. X-2, X-3. [pmid: 10999792].
1622 Murphy FL, Law H, Mushtaq I, et al. Testicular and paratesticular pathology in infants and children: the histopathological experience of a tertiary paediatric unit over a 17 year period. Pediatr Surg Int. Sep. 2007;23(9):867-72. X-3. [pmid: 17639422].
1623 Murugaesu N, Powles T, Bestwick J, et al. Long-term follow-up of testicular cancer patients shows no predisposition to osteoporosis. Osteoporos Int. Sep. 2009;20(9):1627-30. X-2, X-3. [pmid: 19030945].
1624 Mutafoglu-Uysal K, Gunes D, Tufekci O, et al. The incidence of congenital malformations in children with cancer. Turkish Journal of Pediatrics. September–October. 2009;51(5):444-452. X-2, X-3. [pmid: 20112599].
1625 Muttarak M, Peh WC, Chaiwun B. Malignant germ cell tumours of undescended testes: imaging features with pathological correlation. Clin Radiol. Feb. 2004;59(2):198-204. X-4, X-5, X-6. [pmid: 14746792].
1626 Muzzonigro G, Minardi D, Polito M Jr, et al. Cryptorchidism and infertility: retrospective study of 18 post puberal patients affected with monolateral cryptorchidism. Arch Ital Urol Androl. Apr. 1996;68(2):75-80. X-3. [pmid: 8713563].
1627 Nachman J, Palmer NF, Sather HN, et al. Open-wedge testicular biopsy in childhood acute lymphoblastic leukemia after two years of maintenance therapy: Diagnostic accuracy and influence on outcome - A report from Children’s Cancer Study Group. Blood. 1990;75(5):1051-1055. X-2, X-3. [pmid: 2407298].
1628 Nachman J, Palmer NF, Sather HN, et al. Open-wedge testicular biopsy in childhood acute lymphoblastic leukemia after two years of maintenance therapy: diagnostic accuracy and influence on outcome--a report from Children’s Cancer Study Group. Blood. Mar. 1. 1990;75(5):1051-5. X-2, X-3. [pmid: 2407298].
1629 Nachtigall LB, Boepple PA, Seminara SB, et al. Inhibin B secretion in males with gonadotropin-releasing hormone (GnRH) deficiency before and during long-term GnRH replacement: Relationship to spontaneous puberty, testicular volume, and prior treatment - A clinical research center study. Journal of Clinical Endocrinology and Metabolism. 1996;81(10):3520-3525. X-2, X-3. [pmid: 8855795].
1630 Nachtsheim DA, Scheible FW, Gosink B. Ultrasonography of testis tumors. J Urol. May. 1983;129(5):978-81. X-2, X-3. [pmid: 6854774].
1631 Nader S, Schultz PN, Cundiff JH, et al. Endocrine profiles of patients with testicular tumors treated with radiotherapy. Int J Radiat Oncol Biol Phys. Nov. 1983;9(11):1723-6. X-2, X-3. [pmid: 6417074].
1632 Nagar H, Haddad R. Impact of early orchidopexy on testicular growth. Br J Urol. Aug. 1997;80(2):334-5. X-4, X-5, X-6. [pmid: 9284212].
1633 Nagar H, Kessler A. Abdominoscrotal hydrocele in infancy: A study of 15 cases. Pediatric Surgery International. Mar. 1998;13(2–3):189-190. X-2, X-3. [pmid: 9563045].
1634 Nalesnik JG, Sabanegh ES Jr, Eng TY, et al. Fertility in men after treatment for stage 1 and 2A seminoma. Am J Clin Oncol. Dec. 2004;27(6):584-8. X-2, X-3. [pmid: 15577436].
1635 Namiki M, Uchida K, Okuyama A, et al. Deoxyribonucleic acid study on 2 XX male patients. J Urol. Mar. 1992;147(3):633-5. X-2, X-3. [pmid: 1538446].
1636 Nangia AK, Myles JL, Thomas AJ. Vasectomy reversal for the post-vasectomy pain syndrome: a clinical and histological evaluation. J Urol. Dec. 2000;164(6):1939-42. X-2, X-3. [pmid: 11061886].
1637 Naude AM, Heyns CF, Matin SF. Laparoscopic urology training in South Africa. J Endourol. Dec. 2005;19(10):1180-4. X-2, X-3. [pmid: 16359210].
1638 Nazir M, Saebo A. Contralateral inguinal hernial development and ipsilateral recurrence following unilateral hernial repair in infants and children. Acta Chir Belg. Feb. 1996;96(1):28-30. X-2, X-3. [pmid: 8629384].
1639 Neel KF. Orchidopexy for undescended testis among saudi children: Is it conducted at the optimal age?. Current Pediatric Research. Jan–June. 2010;14(1):39-41. X-4, X-5, X-6.
1640 Nees SN, Glassberg KI. Observations on hydroceles following adolescent varicocelectomy. Journal of Urology. December. 2011;186(6):2402-2407. X-2, X-3. [pmid: 22019156].
1641 Negri L, Albani E, DiRocco M, et al. Testicular sperm extraction in azoospermic men submitted to bilateral orchidopexy. Hum Reprod. Dec. 2003;18(12):2534-9. X-2, X-3. [pmid: 14645168].
1642 Negri L, Benaglia R, Fiamengo B, et al. Cancer risk in male factor-infertility. Placenta. Oct. 2008;29(Suppl B):178-83. X-2, X-3. [pmid: 18755508].
1643 Nemec SF, Kasprian G, Brugger PC, et al. Abnormalities of the penis in utero - Hypospadias on fetal MRI. Journal of Perinatal Medicine. 01. Jul. 2011;39(4):451-456. X-2, X-3. [pmid: 21631398].
1644 Nermoen I, Rorvik J, Holmedal SH, et al. High frequency of adrenal myelolipomas and testicular adrenal rest tumours in adult Norwegian patients with classical congenital adrenal hyperplasia because of 21-hydroxylase deficiency. Clinical Endocrinology. December. 2011;75(6):753-759. X-2, X-3. [pmid: 21689130].
1645 Newby JA, Howard CV. Environmental influences in cancer aetiology. Journal of Nutritional & Environmental Medicine. 2005;15(2–3):56-114. X-1, X-2, X-3.
1646 Newhouse JH. Clinical use of urinary tract magnetic resonance imaging. Radiologic Clinics of North America. 1991;29(3):455-474. X-1, X-2, X-3. [pmid: 2024001].
1647 Ng AWH, Chu WCW, Ching ASC, et al. High-resolution sonography for paediatric scrotal pathology. Journal of the Hong Kong College of Radiologists. 2008;11(1):47-55. X-1, X-2, X-3.
1648 Nicopoullos JDM, Gilling-Smith C, Ramsay JWA. Does the cause of obstructive azoospermia affect the outcome of intracytoplasmic sperm injection: A meta-analysis. BJU International. Jun. 2004;93(9):1282-1286. X-2, X-3. [pmid: 15180623].
1649 Niculescu AM. Effects of in utero exposure to DES on male progeny. J Obstet Gynecol Neonatal Nurs. Nov–Dec. 1985;14(6):468-70. X-2, X-3.
1650 Niederkohr RD, Levin LA. Management of the patient with suspected temporal arteritis: A decision-analytic approach. Ophthalmology. May. 2005;112(5):744-756. X-2, X-3. [pmid: 15878052].
1651 Nihoul-Fekete C, Lortat-Jacob S, Cachin O, et al. Preservation of gonadal function in true hermaphroditism. J Pediatr Surg. Feb. 1984;19(1):50-5. X-2, X-3. [pmid: 6699763].
1652 Nijman JM, Jager S, Boer PW, et al. The treatment of ejaculation disorders after retroperitoneal lymph node dissection. Cancer. Dec. 15. 1982;50(12):2967-71. X-2, X-3. [pmid: 7139590].
1653 Nijman JM, Schraffordt Koops H, Kremer J, et al. Fertility and hormonal function in patients with a nonseminomatous tumor of the testis. Arch Androl. 1985;14(2–3):239-46. X-2, X-3. [pmid: 2415075].
1654 Nijman JM, Schraffordt Koops H, Oldhoff J, et al. Sexual function after bilateral retroperitoneal lymph node dissection for nonseminomatous testicular cancer. Arch Androl. 1987;18(3):255-67. X-2, X-3. [pmid: 3675073].
1655 Nimri R, Lebenthal Y, Lazar L, et al. A novel loss-of-function mutation in GPR54/KISS1R leads to hypogonadotropic hypogonadism in a highly consanguineous family. Journal of Clinical Endocrinology and Metabolism. March. 2011;96(3):E536-545. X-3. [pmid: 21193544].
1656 Ning Y, Cai Z, Chen H, et al. Development and clinical application of a new testicular prosthesis. Asian Journal of Andrology. November. 2011;13(6):903-904. X-3. [pmid: 21927041].
1657 Nishi M, Miyake H, Takeda T, et al. Congenital malformations and childhood cancer. Med Pediatr Oncol. Apr. 2000;34(4):250-4. X-2, X-3. [pmid: 10742060].
1658 Nishida T, Ueyama T, Sugiyama T, et al. Intrasplenic autograft of testicular tissue in rats. Oncol Rep. Jan–Feb. 1998;5(1):157-9. X-2, X-3. [pmid: 9458313].
1659 Nishiyama H, Danno S, Kaneko Y, et al. Decreased expression of cold-inducible RNA-binding protein (CIRP) in male germ cells at elevated temperature. Am J Pathol. Jan. 1998;152(1):289-96. X-2, X-3. [pmid: 9422546].
1660 Nishiyama T, Tanikawa T, Tomita Y, et al. Clinical studies of testicular tumors. Nishinihon Journal of Urology. 1994;56(1):33-37. X-2, X-3.
1661 Nishiyama T, Terunuma M. Hormone/antihormone withdrawal and dexamethasone for hormone-refractory prostate cancer. Int J Urol. Jan. 1998;5(1):44-7. X-2, X-3. [pmid: 9535600].
1662 Nistal M, Castillo MC, Regadera J, et al. Adenomatous hyperplasia of the rete testis. A review and report of new cases. Histology and Histopathology. Jul. 2003;18(3):741-752. X-2, X-3. [pmid: 12792886].
1663 Nistal M, Codesal J, Paniagua R. Carcinoma in situ of the testis in infertile men. A histological, immunocytochemical, and cytophotometric study of DNA content. J Pathol. Nov. 1989;159(3):205-10. X-2, X-3. [pmid: 2593044].
1664 Nistal M, De Mora JC, Paniagua R. Classification of several types of maturational arrest of spermatogonia according to Sertoli cell morphology: an approach to aetiology. Int J Androl. Dec. 1998;21(6):317-26. X-2, X-3. [pmid: 9972489].
1665 Nistal M, Garcia-Cabezas MA, Castello MC, et al. Age-related epididymis-like intratesticular structures: benign lesions of Wolffian origin that can be misdiagnosed as testicular tumors. J Androl. Jan–Feb. 2006;27(1):79-85. X-2, X-3. [pmid: 16400082].
1666 Nistal M, Garcia-Rodeja E, Paniagua R. Granular transformation of Sertoli cells in testicular disorders. Hum Pathol. Feb. 1991;22(2):131-7. X-2, X-3. [pmid: 1672120].
1667 Nistal M, Gonzalez-Peramato P, De Miguel MP. Immunodetection of inhibin in the human testis and epididymis during normal development and in non-tumoural testicular lesions. Reprod Fertil Dev. 2010;22(3):558-63. X-2, X-3. [pmid: 20188029].
1668 Nistal M, Gonzalez-Peramato P, Paniagua R. Diagnostic value of differential quantification of spermatids in obstructive azoospermia. J Androl. Sep–Oct. 2003;24(5):721-6. X-2, X-3. [pmid: 12954664].
1669 Nistal M, Jimenez F, Paniagua R. Sertoli cell types in the Sertoli-cell-only syndrome: Relationships between Sertoli cell morphology and aetiology. Histopathology. 1990;16(2):173-180. X-3. [pmid: 2182507].
1670 Nistal M, Jimenez-Heffernan JA, Garcia-Viera M, et al. Cystic transformation and calcium oxalate deposits in rete testis and efferent ducts in dialysis patients. Hum Pathol. Apr. 1996;27(4):336-41. X-2, X-3. [pmid: 8617475].
1671 Nistal M, Mate A, Paniagua R. Cystic transformation of the rete testis. American Journal of Surgical Pathology. Oct. 1996;20(10):1231-1239. X-2, X-3. [pmid: 8827030].
1672 Nistal M, Mate A, Paniagua R. Granulomatous epididymal lesion of possible ischemic origin. Am J Surg Pathol. Aug. 1997;21(8):951-6. X-2, X-3. [pmid: 9255259].
1673 Nistal M, Paniagua R. Infertility in adult males with retractile testes. Fertil Steril. Mar. 1984;41(3):395-403. X-2, X-3. [pmid: 6698232].
1674 Nistal M, Paniagua R. Occurrence of primary spermatocytes in the infant and child testis. Andrologia. Nov–Dec. 1984;16(6):532-6. X-2, X-3. [pmid: 6151369].
1675 Nistal M, Paniagua R, Abaurrea MA, et al. Hyperplasia and the immature appearance of Sertoli cells in primary testicular disorders. Hum Pathol. Jan. 1982;13(1):3-12. X-2, X-3. [pmid: 6122643].
1676 Nistal M, Paniagua R, Diez-Pardo JA. Histologic classification of undescended testes. Hum Pathol. Nov. 1980;11(6):666-74. X-3, X-4, X-5, X-6. [pmid: 6108912].
1677 Nistal M, Paniagua R, Leon L, et al. Ectopic seminiferous tubules in the tunica albuginea of normal and dysgenetic testes. Appl Pathol. 1985;3(3):123-8. X-2, X-3. [pmid: 3842073].
1678 Nistal M, Paniagua R, Queizan A. Histologic lesions in undescended ectopic obstructed testes. Fertil Steril. Mar. 1985;43(3):455-62. X-3. [pmid: 2858418].
1679 Nistal M, Paniagua R, Regadera J, et al. Hyperplasia of spermatic cord nerves: a sign of testicular absence. Urology. Apr. 1987;29(4):411-5. X-3. [pmid: 2882629].
1680 Nistal M, Pastrian LG, Gonzalez-Peramato P, et al. Inhibin bodies: a new marker for immature Sertoli cells. Histopathology. Jun. 2011;58(7):1019-27. X-2, X-3. [pmid: 21707703].
1681 Nistal M, Riestra ML, Galmes-Belmonte I, et al. Testicular biopsy in patients with obstructive azoospermia. Am J Surg Pathol. Dec. 1999;23(12):1546-54. X-2, X-3. [pmid: 10584709].
1682 Nistal M, Riestra ML, Paniagua R. Correlation between testicular biopsies (prepubertal and postpubertal) and spermiogram in cryptorchid men. Hum Pathol. Sep. 2000;31(9):1022-30. X-3, X-4, X-5, X-6. [pmid: 11014566].
1683 Nistal M, Riestra ML, Paniagua R. Focal orchitis in undescended testes: discussion of pathogenetic mechanisms of tubular atrophy. Arch Pathol Lab Med. Jan. 2002;126(1):64-9. X-2, X-3. [pmid: 11800649].
1684 Nixon RG, Pope JCt, Adams MC, et al. Laparoscopic variability of the internal inguinal ring: review of anatomical variation in children with and without a patent processus vaginalis. J Urol. Apr. 2002;167(4):1818-20. X-2, X-3. [pmid: 11912440].
1685 Niyogi A, Tahim AS, Sherwood WJ, et al. A comparative study examining open inguinal herniotomy with and without hernioscopy to laparoscopic inguinal hernia repair in a pediatric population. Pediatr Surg Int. Apr. 2010;26(4):387-92. X-2, X-3. [pmid: 20143077].
1686 Noccioli B, Pampaloni A. Refluent testicular autotransplantation by Domini’s method: Personal experience with seven pediatric patients. Pediatric Surgery International. 1995;10(5–6):356-358. X-4, X-5, X-6.
1687 Noe HN, Peeden JN, Jerkins GR, et al. Hypertelorism-hypospadias syndrome. J Urol. Nov. 1984;132(5):951-2. X-2, X-3. [pmid: 6149320].
1688 Nogales FF Jr, Toro M, Ortega I, et al. Bilateral incipient germ cell tumours of the testis in the incomplete testicular feminization syndrome. Histopathology. Sep. 1981;5(5):511-5. X-2, X-3. [pmid: 7286914].
1689 Nojima M, Taguchi T, Ando Y, et al. Huge seminoma developed in a patient with testicular feminization. J Obstet Gynaecol Res. Apr. 2004;30(2):109-12. X-2, X-3. [pmid: 15009613].
1690 Nonomura N, Aozasa K, Ueda T, et al. Malignant lymphoma of the testis: histological and immunohistological study of 28 cases. J Urol. Jun. 1989;141(6):1368-71. X-2, X-3. [pmid: 2657106].
1691 Noonan JA. Noonan syndrome and related disorders. Progress in Pediatric Cardiology. Jul. 2005;20(2):177-185. X-1, X-2, X-3.
1692 Nord C, Bjoro T, Ellingsen D, et al. Gonadal hormones in long-term survivors 10 years after treatment for unilateral testicular cancer. Eur Urol. Sep. 2003;44(3):322-8. X-2, X-3. [pmid: 12932930].
1693 Nordenskjold A, Friedman E, Tapper-Persson M, et al. Screening for mutations in candidate genes for hypospadias. Urol Res. 1999;27(1):49-55. X-2, X-3. [pmid: 10092153].
1694 Noroes J, Dreyer G. A mechanism for chronic filarial hydrocele with implications for its surgical repair. PLoS Negl Trop Dis. 2010;4(6):e695. X-2, X-3. [pmid: 20532225].
1695 North MO, Lellei I, Erdei E, et al. Meiotic studies of infertile men in case of non-obstructive azoospermia with normal karyotype and no microdeleted Y-chromosome precise the clinical couple management. Ann Genet. Apr–Jun. 2004;47(2):113-23. X-2, X-3. [pmid: 15183743].
1696 North MO, Lellei I, Rives N, et al. Reversible meiotic abnormalities in azoospermic men with bilateral varicocele after microsurgical correction. Cell Mol Biol (Noisy-le-grand). May. 2004;50(3):281-9. X-2, X-3. [pmid: 15209349].
1697 Northen AT, Norman GS, Anderson K, et al. Follow-up of children exposed in utero to 17 alpha-hydroxyprogesterone caproate compared with placebo. Obstetrics and Gynecology. Oct. 2007;110(4):865-872. X-2, X-3. [pmid: 17906021].
1698 Noseworthy J. Recurrent undescended testes. Seminars in Pediatric Surgery. May. 2003;12(2):90-93. X-1. [pmid: 12728393].
1699 Nouira F, Ahmed YB, Jlidi S, et al. Management of perineal ectopic testes. Tunisie Medicale. January. 2011;89(1):47-49. X-4, X-5, X-6. [pmid: 21267828].
1700 Novotny DA, Klein RL, Boeckman CR. Gastroschisis: an 18-year review. J Pediatr Surg. May. 1993;28(5):650-2. X-2, X-3. [pmid: 8340849].
1701 Nowroozi MR, Radkhah K, Ranjbaran A, et al. Is karyotyping and Y chromosome microdeletion study necessary in men candidate for ICSI?. Iranian Journal of Reproductive Medicine. 2010;8(4):173-178. X-3.
1702 Nuininga JE, DE Gier RP, Verschuren R, et al. Long-term outcome of different types of 1-stage hypospadias repair. J Urol. Oct. 2005;174(4 Pt 2):1544-8. discussion 1548. X-2, X-3. [pmid: 16148649].
1703 Nuti F, Marinari E, Erdei E, et al. The leucine-rich repeat-containing G protein-coupled receptor 8 gene T222P mutation does not cause cryptorchidism. J Clin Endocrinol Metab. Mar. 2008;93(3):1072-6. X-3. [pmid: 18073304].
1704 Obican S, Scialli AR. Teratogenic exposures. American Journal of Medical Genetics, Part C: Seminars in Medical Genetics. 15. August. 2011;157(3):150-169. X-1, X-2, X-3.
1705 Ocal G, Adiyaman P, Berberoglu M, et al. Mutations of the 5alpha-steroid reductase type 2 gene in six Turkish patients from unrelated families and a large pedigree of an isolated Turkish village. J Pediatr Endocrinol Metab. Apr. 2002;15(4):411-21. X-2, X-3. [pmid: 12008688].
1706 Odabas O, Ugras S, Yilmaz Y, et al. Testicular needle biopsy: is it a safe and adequate method?. Int Urol Nephrol. 1997;29(5):591-5. X-3. [pmid: 9413768].
1707 Oerter R, Kaiser D. Pulmonary metastases principles and strategies of surgical treatment. Acta Chirurgica Austriaca. 1996;28(1):23-27. X-2, X-3.
1708 Oesterwitz H, Fahlenkamp D. Microsurgical technique and results of testicular autotransplantation in children - Essential venous anastomosis. International Urology and Nephrology. 1993;25(6):587-593. X-1, X-2, X-3. [pmid: 7909792].
1709 Ogata T, Muroya K, Sasagawa I, et al. Genetic evidence for a novel gene(s) involved in urogenital development on 10q26. Kidney Int. Dec. 2000;58(6):2281-90. X-2, X-3. [pmid: 11115062].
1710 Oguzkurt P, Kayaselcuk F, Tuncer I, et al. Evaluation of extracellular matrix protein composition in sacs associated with undescended testis, hydrocele, inguinal hernia, and peritoneum. Urology. Aug. 2007;70(2):346-50. X-2, X-3. [pmid: 17826504].
1711 Ohyama C, Chiba Y, Yamazaki T, et al. Lymphatic mapping and gamma probe guided laparoscopic biopsy of sentinel lymph node in patients with clinical stage I testicular tumor. J Urol. Oct. 2002;168(4 Pt 1):1390-5. X-2, X-3. [pmid: 12352400].
1712 Ohyama C, Kyan A, Satoh M, et al. Bilateral testicular tumors: A report of nine cases with long-term follow-up. International Journal of Urology. 2002;9(3):173-177. X-2, X-3. [pmid: 12010330].
1713 Okada H, Yoshimura K, Fujioka H, et al. Assisted reproduction technology for patients with congenital bilateral absence of vas deferens. J Urol. Apr. 1999;161(4):1157-62. X-2, X-3. [pmid: 10081860].
1714 Okeke AA, Osegbe DN. Prevalence and characteristics of cryptorchidism in a Nigerian district. BJU Int. Dec. 2001;88(9):941-5. X-2, X-3. [pmid: 11851618].
1715 Okorie CO. Unilateral testicular torsion with necrotic outcome: dilemmas of surgical timing. Urology. Dec. 2011;78(6):1232-4. X-2, X-3. [pmid: 22014962].
1716 Okten G, Kara N, Gunes S, et al. A retrospective study in cases with sex chromosome anomaly in samsun and around. Turkiye Klinikleri Journal of Medical Sciences. 2009;29(3):643-647. X-2, X-3.
1717 Okunribido O, Ladipo JK, Ajao OG. Inguinal hernia in paediatric age-group: Ibadan experience. East Afr Med J. Jun. 1992;69(6):347-8. X-2, X-3. [pmid: 1354600].
1718 Okur H, Gough DC. Management of mullerian duct remnants. Urology. Mar. 2003;61(3):634-7. discussion 637. X-3. [pmid: 12639661].
1719 Okur H, Kucukaydin M, Kazez A, et al. Ectopic adrenal tissue in the inguinal region in children. Pediatric Pathology and Laboratory Medicine. 1995;15(5):763-767. X-2, X-3. [pmid: 8597861].
1720 Okuyama A, Itatani H, Mizutani S, et al. Factors affecting fertility after varicocelectomy. Eur Urol. 1980;6(4):214-7. X-2, X-3. [pmid: 6771142].
1721 Okuyama A, Koh E, Kondoh N, et al. Plasminogen activator in cultured cells of human undescended testis. Urol Int. 1991;46(4):324-8. X-3, X-4, X-5, X-6. [pmid: 1681607].
1722 Okuyama A, Koide T, Itatani H, et al. Pituitary-gonadal function in schoolboys with varicocele and indications of varicocelectomy. Eur Urol. 1981;7(2):92-6. X-2, X-3. [pmid: 6780355].
1723 Olea N, Olea-Serrano F, Lardelli-Claret P, et al. Inadvertent exposure to xenoestrogens in children. Toxicol Ind Health. Jan–Mar. 1999;15(1–2):151-8. X-1, X-2, X-3. [pmid: 10188197].
1724 O’Leary MP, Gee WF, Holtgrewe HL, et al. American Urological Association Gallup Survey: changes in physician practice patterns, treatment of incontinence and bladder cancer, and impact of managed care. J Urol. 2000. Oct. 1999;164(4):1311-6. X-2, X-3.
1725 Olesen IA, Hoei-Hansen CE, Skakkebaek NE, et al. Testicular carcinoma in situ in subfertile Danish men. Int J Androl. Aug. 2007;30(4):406-11. discussion 412. X-2, X-3. [pmid: 17705813].
1726 Oliva A, Spira A, Multigner L. Contribution of environmental factors to the risk of male infertility. Hum Reprod. Aug. 2001;16(8):1768-76. X-2, X-3. [pmid: 11473980].
1727 Olk RJ, Halperin LS, Soubrane G, et al. Fluorescein angiography--is it safe to use in a pregnant patient?. Eur J Ophthalmol. Apr–Jun. 1991;1(2):103-6. X-2, X-3. [pmid: 1821200].
1728 Olsen LH. Inter-observer variation in assessment of undescended testis. Analysis of kappa statistics as a coefficient of reliability. Br J Urol. Dec. 1989;64(6):644-8. X-3. [pmid: 2576391].
1729 Olsson H, Bladstrom A, Alm P. Male gynecomastia and risk for malignant tumours--a cohort study. BMC Cancer. Oct. 16. 2002;2:26. X-2, X-3. [pmid: 12383352].
1730 Omar S, Eissa S, Nasser H, et al. Retroperitoneal block dissection in the treatment of nonseminomatous tumors of the testis. Arch Androl. Nov. 1980;5(3):279-85. X-2, X-3. [pmid: 7436625].
1731 Ondrus D, Hornak M, Mat’oska J. Bilateral testicular germ-cell tumors--a single centre long-term experience. Int Urol Nephrol. 2001;33(3):521-4. X-2, X-3. [pmid: 12230287].
1732 Ondrus D, Matoska J, Hornak M. Bilateral germ cell tumors of the testis. Neoplasma. 1993;40(5):329-32. X-2, X-3. [pmid: 8272163].
1733 Ondrusova M, Ondrus D. Testicular cancer epidemiology in the Slovak Republic. International Journal of Cancer Prevention. May. 2008;2(5):375-386. X-3.
1734 Ondrusova M, Ondrus D. Epidemiological features of testicular cancer in the Slovak Republic--retrospective study. Klin Onkol. 2009;22(2):52-7. X-2, X-3. [pmid: 19522374].
1735 Ondrusova M, Ondrus D, Dusek L, et al. Damage of hormonal function and bone metabolism in long-term survivors of testicular cancer. Neoplasma. 2009;56(6):473-9. X-2, X-3. [pmid: 19728753].
1736 O’Neill BP, Dinapoli RP, Kurtin PJ, et al. Occult systemic non-Hodgkin’s lymphoma (NHL) in patients initially diagnosed as primary central nervous system lymphoma (PCNSL): how much staging is enough?. J Neurooncol. 1995;25(1):67-71. X-2, X-3. [pmid: 8523091].
1737 Onol SY, Ilbey YO, Onol FF, et al. A novel pull-through technique for the surgical management of idiopathic hydrocele. J Urol. Mar. 2009;181(3):1201-5. X-2, X-3. [pmid: 19152934].
1738 Opitz JM. Hypospadias. American Journal of Medical Genetics. [Journal]. 1985;21(1):57-60. X-1, X-2, X-3.
1739 Opitz JM. G syndrome (hyperteloeism with esophageal abnormality and hypospadias, or hypospadias-dysphagia, or ‘Opitz-Frias’ or ‘Optiz-G’ syndrome) - Perspective in 1987 and bibliography. American Journal of Medical Genetics. [Journal]. 1987;28(2):275-285. X-3. [pmid: 3322001].
1740 Orlando C, Santoro S, Calabro C, et al. Spermatic and peripheral venous plasma concentrations of immunoreactive inhibin in prepubertal boys with undescended testis and in pubertal boys with varicocele. Acta Endocrinol (Copenh). Nov. 1992;127(5):385-91. X-3. [pmid: 1361704].
1741 Ornstein DK, Smith DS, Andriole GL. Biochemical response to testicular androgen ablation among patients with prostate cancer for whom flutamide and/or finasteride therapy failed. Urology. Dec. 1998;52(6):1094-7. X-2, X-3. [pmid: 9836561].
1742 Ortega JJ, Javier G, Toran N. Testicular infiltrates in children with acute lymphoblastic leukemia: a prospective study. Med Pediatr Oncol. 1984;12(6):386-93. X-2, X-3. [pmid: 6594560].
1743 Orvis BR, Bottles K, Kogan BA. Testicular histology in fetuses with the prune belly syndrome and posterior urethral valves. J Urol. Feb. 1988;139(2):335-7. X-3. [pmid: 3339735].
1744 Osegbe DN. Testicular function affter unilateral bacterial epididymo-orchitis. European Urology. 1991;19(3):204-208. X-2, X-3. [pmid: 1855525].
1745 Osegbe DN, Amaku EO. The causes of male infertility in 504 consecutive Nigerian patients. Int Urol Nephrol. 1985;17(4):349-58. X-2, X-3. [pmid: 2872182].
1746 O’Shaughnessy PJ, Monteiro A, Verhoeven G, et al. Occurrence of testicular microlithiasis in androgen insensitive hypogonadal mice. Reprod Biol Endocrinol. 2009;7:88. X-2, X-3. [pmid: 19712470].
1747 Oshima H, Higashi Y, Hatakeyama S. Histochemical location of 17 beta-hydroxysteroid oxidoreductase in the adult and infantile human testis. Endocrinol Jpn. Jun. 1983;30(3):367-72. X-3, X-4, X-5, X-6. [pmid: 6141045].
1748 Osterlind A, Berthelsen JG, Abildgaard N, et al. Risk of bilateral testicular germ cell cancer in Denmark: 1960–1984. J Natl Cancer Inst. Oct. 2. 1991;83(19):1391-5. X-2, X-3. [pmid: 1656057].
1749 Osterlind A, Berthelsen JG, Abildgaard N, et al. Incidence of bilateral testicular germ cell cancer in Denmark, 1960–84: preliminary findings. Int J Androl. Feb. 1987;10(1):203-8. X-2, X-3. [pmid: 3034792].
1750 Ottesen AM, Kirchhoff M, De-Meyts ER, et al. Detection of chromosomal aberrations in seminomatous germ cell tumours using comparative genomic hybridization. Genes Chromosomes Cancer. Dec. 1997;20(4):412-8. X-2, X-3. [pmid: 9408759].
1751 Ozan H, Gumusalan Y, Onderoglu S, et al. High origin of gonadal arteries associated with other variations. Annals of Anatomy. 1995;177(2):157-160. X-2, X-3.
1752 Ozel SK, Kazez A, Akpolat N. Presence of ectopic adrenocortical tissues in inguinoscrotal region suggests an association with undescended testis. Pediatr Surg Int. Feb. 2007;23(2):171-5. X-2, X-3. [pmid: 17066272].
1753 Ozen H, Ayhan A, Esen A, et al. Histopathological changes in adult cryptorchid testes. Br J Urol. May. 1989;63(5):520-1. X-3. [pmid: 2567195].
1754 Ozkurkcugil C, Ozkan L, Saribacak A. Abnormalities of the external genitalia in school-age boys in Turkey: A contemporary epidemiologic evaluation. Turkiye Klinikleri Journal of Medical Sciences. 2011;31(2):371-374. X-3.
1755 Ozturk A, Ozturk E, Zeyrek F, et al. Comparison of brucella and non-specific epididymorchitis: gray scale and color Doppler ultrasonographic features. Eur J Radiol. Nov. 2005;56(2):256-62. X-2, X-3. [pmid: 16233893].
1756 Padron RS. Semen biochemistry studies in men with macro-orchidism. Int J Fertil. Mar–Apr. 1986;31(1):56-8. X-2, X-3. [pmid: 2908277].
1757 Paick J, Kim SH, Kim SW. Ejaculatory duct obstruction in infertile men. BJU Int. Apr. 2000;85(6):720-4. X-2, X-3. [pmid: 10759673].
1758 Pajulo OT, Pulkki KJ, Alanen MS, et al. Duration of surgery and patient age affect wound healing in children. Wound Repair Regen. May–Jun. 2000;8(3):174-8. X-2, X-3. [pmid: 10886808].
1759 Pallapies D. Trends in childhood disease. Mutation Research - Genetic Toxicology and Environmental Mutagenesis. 28. Sep. 2006;608(2):100-111. X-3. [pmid: 16854614].
1760 Palmer JM. The undescended testicle. Endocrinology and Metabolism Clinics of North America. 1991;20(1):231-240. X-1, X-2, X-3. [pmid: 1674244].
1761 Palmer JR, Herbst AL, Noller KL, et al. Urogenital abnormalities in men exposed to diethylstilbestrol in utero: A cohort study. Environmental Health: A Global Access Science Source. 2009;8:37. X-3. [pmid: 19689815].
1762 Palmieri G, Lotrecchiano G, Ricci G, et al. Gonadal function after multimodality treatment in men with testicular germ cell cancer. Eur J Endocrinol. Apr. 1996;134(4):431-6. X-2, X-3. [pmid: 8640293].
1763 Paltiel HJ, Rupich RC, Babcock DS. Maturational changes in arterial impedance of the normal testis in boys: Doppler sonographic study. AJR Am J Roentgenol. Nov. 1994;163(5):1189-93. X-2, X-3. [pmid: 7976898].
1764 Pamenter B, De Bono JS, Brown IL, et al. Bilateral testicular cancer: a preventable problem? Experience from a large cancer centre. BJU Int. Jul. 2003;92(1):43-6. X-2, X-3. [pmid: 12823381].
1765 Pan BSA, Ooi LLPJ, Mack POP. Laparoscopic assessment and orchidectomy for the undescended testis. Australian and New Zealand Journal of Surgery. 1994;64(2):118-120. X-4, X-5, X-6. [pmid: 7904814].
1766 Panagiotopoulou K, Katsouyanni K, Petridou E, et al. Maternal age, parity, and pregnancy estrogens. Cancer Causes Control. Sep. 1990;1(2):119-24. X-2, X-3. [pmid: 2102281].
1767 Paniagua R, Martinez-Onsurbe P, Santamaria L, et al. Quantitative and ultrastructural alterations in the lamina propria and Sertoli cells in human cryptorchid testes. Int J Androl. Dec. 1990;13(6):470-87. X-3. [pmid: 1982882].
1768 Paniagua R, Nistal M, Bravo MP. Leydig cell types in primary testicular disorders. Hum Pathol. Feb. 1984;15(2):181-90. X-2, X-3. [pmid: 6141991].
1769 Panidis D, Matalliotakis I, Papathanasiou K, et al. The sperm deformity and the sperm multiple anomalies indexes in patients who underwent unilateral orchectomy and preventive radiotherapy. Eur J Obstet Gynecol Reprod Biol. Oct. 1998;80(2):247-50. X-2, X-3. [pmid: 9846678].
1770 Papachristou EA, Mitselou MF, Finokaliotis ND. Surgical outcome and hospital cost analyses of laparoscopic and open tension-free hernia repair. Hernia. Jul. 2002;6(2):68-72. X-2, X-3. [pmid: 12152642].
1771 Papadimas J, Goulis DG, Sotiriades A, et al. Interleukin-1 beta and tumor necrosis factor-alpha in normal/infertile men. Arch Androl. Mar–Apr. 2002;48(2):107-13. X-2, X-3. [pmid: 11868623].
1772 Papanikolaou F, Chow V, Jarvi K, et al. Effect of adult microsurgical varicocelectomy on testicular volume. Urology. Jul. 2000;56(1):136-9. X-2, X-3. [pmid: 10869642].
1773 Papp G. Operative andrology. Hum Reprod. Apr. 1988;3(3):357-63. X-3. [pmid: 2897378].
1774 Papp Z, Toth-Pal E, Papp C, et al. Impact of prenatal mid-trimester screening on the prevalence of fetal structural anomalies: a prospective epidemiological study. Ultrasound Obstet Gynecol. Nov. 1995;6(5):320-6. X-2, X-3. [pmid: 8590201].
1775 Parekattil S, Sijo J, Atalah H, et al. Journal of Endourology. [Conference Abstract]. October. Conference: 27th WCE 2009. Munich Germany. Conference Start: 20091006 Conference End: 20091010. Conference Publication: (var.pagings). 2009;23:A218. X-2, X-3.
1776 Parelkar SV, Oak S, Bachani MK, et al. Laparoscopic repair of pediatric inguinal hernia-is vascularity of the testis at risk? A study of 125 testes. Journal of Pediatric Surgery. September. 2011;46(9):1813-1816. X-2, X-3. [pmid: 21929995].
1777 Parelkar SV, Oak S, Bachani MK, et al. Laparoscopic repair of pediatric inguinal hernia--is vascularity of the testis at risk? A study of 125 testes. J Pediatr Surg. Sep. 2011;46(9):1813-6. X-2, X-3. [pmid: 21929995].
1778 Parelkar SV, Oak S, Gupta R, et al. Laparoscopic inguinal hernia repair in the pediatric age group--experience with 437 children. J Pediatr Surg. Apr. 2010;45(4):789-92. X-2, X-3. [pmid: 20385288].
1779 Paris F, Jeandel C, Servant N, et al. Increased serum estrogenic bioactivity in three male newborns with ambiguous genitalia: a potential consequence of prenatal exposure to environmental endocrine disruptors. Environ Res. Jan. 2006;100(1):39-43. X-2, X-3. [pmid: 16274687].
1780 Paris F, Servant N, Terouanne B, et al. Evaluation of androgenic bioactivity in human serum by recombinant cell line: preliminary results. Mol Cell Endocrinol. Dec. 30. 2002;198(1–2):123-9. X-2, X-3. [pmid: 12573822].
1781 Park DS, Prow DM, Amato RJ, et al. Clinical characteristics of metachronous bilateral testicular tumors in the chemotherapeutic era. Yonsei Med J. Apr. 1999;40(2):137-43. X-2, X-3. [pmid: 10333717].
1782 Park KH, Lee JH, Han JJ, et al. Histological evidences suggest recommending orchiopexy within the first year of life for children with unilateral inguinal cryptorchid testis. Int J Urol. Jul. 2007;14(7):616-21. X-3. [pmid: 17645605].
1783 Park SW, Kim TN, Lee W, et al. Umbilical laparoendoscopic single site surgery versus inguinal varicocelectomy for bilateral varicocele: A comparative study. International Journal of Urology. March. 2011;18(3):250-254. X-3. [pmid: 21332819].
1784 Parkhouse H, Hendry WF. Vasal injuries during childhood and their effect on subsequent fertility. Br J Urol. Jan. 1991;67(1):91-5. X-3. [pmid: 1993283].
1785 Pasqualotto FF, Lucon AM, de Goes PM, et al. Is it worthwhile to operate on subclinical right varicocele in patients with grade II–III varicocele in the left testicle?. J Assist Reprod Genet. May. 2005;22(5):227-31. X-2, X-3. [pmid: 16047585].
1786 Pasqualotto FF, Pasqualotto EB, Agarwal A, et al. Detection of testicular cancer in men presenting with infertility. Rev Hosp Clin Fac Med Sao Paulo. Mar–Apr. 2003;58(2):75-80. X-2, X-3. [pmid: 12845359].
1787 Pasqualotto FF, Pasqualotto EB, Sobreiro BP, et al. Clinical diagnosis in men undergoing infertility investigation in a university hospital. Urol Int. 2006;76(2):122-5. X-2, X-3. [pmid: 16493211].
1788 Passman C, Urban D, Klemm K, et al. Testicular lesions other than germ cell tumours: feasibility of testis-sparing surgery. BJU Int. Feb. 2009;103(4):488-91. X-2, X-3. [pmid: 18793303].
1789 Patel PJ, Pareek SS. Scrotal ultrasound in male infertility. Eur Urol. 1989;16(6):423-5. X-2, X-3. [pmid: 2687000].
1790 Patel SR, Caldamone AA. Sir Denis Browne: Contributions to pediatric urology. Journal of Pediatric Urology. 2010;6(5):496-500. X-1, X-2, X-3. [pmid: 20005179].
1791 Patel SR, Richardson RL, Kvols L. Synchronous and metachronous bilateral testicular tumors. Mayo Clinic experience. Cancer. Jan. 1. 1990;65(1):1-4. X-2, X-3. [pmid: 2293856].
1792 Patel SR, Sigman M. Comparison of outcomes of vasovasostomy performed in the convoluted and straight vas deferens. J Urol. Jan. 2008;179(1):256-9. X-2, X-3. [pmid: 18001786].
1793 Payne K, Heydenrych JJ, Martins M, et al. Caudal block for analgesia after paediatric inguinal surgery. S Afr Med J. Nov. 7. 1987;72(9):629-30. X-4, X-5, X-6. [pmid: 2891200].
1794 Paz A, Melloul M. Comparison of radionuclide scrotal blood-pool index versus gonadal venography in the diagnosis of varicocele. J Nucl Med. Jun. 1998;39(6):1069-74. X-2, X-3. [pmid: 9627346].
1795 Pearce I, Islam S, McIntyre IG, et al. Suspected testicular torsion: a survey of clinical practice in North West England. J R Soc Med. May. 2002;95(5):247-9. X-2, X-3. [pmid: 11983766].
1796 Pearl MS, Hill MC. Ultrasound of the Scrotum. Seminars in Ultrasound, CT and MRI. Aug. 2007;28(4):225-248. X-1, X-2, X-3.
1797 Pearse I, Glick RD, Abramson SJ, et al. Testicular-sparing surgery for benign testicular tumors. J Pediatr Surg. Jun. 1999;34(6):1000-3. X-2, X-3. [pmid: 10392922].
1798 Pecile V, Filippi G. Screening for fra(x) mutation and Klinefelter syndrome in mental institutions. Clin Genet. Mar. 1991;39(3):189-93. X-3. [pmid: 2036739].
1799 Pedersen KV, Boiesen P, Zetterlund CG. Experience of screening for carcinoma-in-situ of the testis among young men with surgically corrected maldescended testes. Int J Androl. Feb. 1987;10(1):181-5. X-2, X-3. [pmid: 2884184].
1800 Pekindil G, Huseyin Atakan I, Kaya E, et al. Bilateral synchronous granulomatous orchitis: gray-scale and colour Doppler sonographic findings. Eur J Radiol. Sep. 1999;31(3):201-3. X-2, X-3. [pmid: 10566522].
1801 Pelliccione F, Cordeschi G, Giuliani V, et al. The contractile wall of the caput epididymidis in men affected by congenital or postinflammatory obstructive azoospermia. J Androl. May–Jun. 2004;25(3):417-25. X-2, X-3. [pmid: 15064321].
1802 Pena-Alonso R, Nieto K, Alvarez R, et al. Distribution of Y-chromosome-bearing cells in gonadoblastoma and dysgenetic testis in 45,X/46,XY infants. Modern Pathology. Mar. 2005;18(3):439-445. X-2, X-3. [pmid: 15475933].
1803 Pepe P, Panella P, Pennisi M, et al. Does color Doppler sonography improve the clinical assessment of patients with acute scrotum?. Eur J Radiol. Oct. 2006;60(1):120-4. X-3. [pmid: 16730939].
1804 Pereira RM, Tatsuo ES, Simoes e Silva AC, et al. New method of surgical delayed closure of giant omphaloceles: Lazaro da Silva’s technique. J Pediatr Surg. Jul. 2004;39(7):1111-5. X-2, X-3. [pmid: 15213910].
1805 Perez-Guillermo M, Sola Perez J. Aspiration cytology of palpable lesions of the scrotal content. Diagn Cytopathol. 1990;6(3):169-77. X-3. [pmid: 2387207].
1806 Peri G, Farina F, Marciano V, et al. Clinical and anatomic features of the inguinal canal during hernia. Ital J Anat Embryol. Apr–Jun. 1996;101(2):69-80. X-2, X-3. [pmid: 8997902].
1807 Perraguin-Jayot S, Audebert A, Emperaire JC, et al. Ongoing pregnancies after intracytoplasmic injection using cryopreserved testicular spermatozoa. Hum Reprod. Dec. 1997;12(12):2706-9. X-2, X-3. [pmid: 9455839].
1808 Perrin P, Rollet J, Durand L. The Doppler stethoscope in the diagnosis of subclinical varicocele. Br J Urol. Oct. 1980;52(5):390-1. X-2, X-3. [pmid: 7427013].
1809 Peschel R, Gettman MT, Steiner H, et al. Management of adult Leydig-cell testicular tumors: assessing the role of laparoscopic retroperitoneal lymph node dissection. J Endourol. Nov. 2003;17(9):777-80. X-2, X-3. [pmid: 14642042].
1810 Petersen HD, Abildgaard U, Daugaard G, et al. Psychological and physical long-term effects of torture. A follow-up examination of 22 Greek persons exposed to torture 1967–1974. Scand J Soc Med. 1985;13(3):89-93. X-2, X-3. [pmid: 4023668].
1811 Petersen PM, Andersson AM, Rorth M, et al. Undetectable inhibin B serum levels in men after testicular irradiation. J Clin Endocrinol Metab. Jan. 1999;84(1):213-5. X-2, X-3. [pmid: 9920086].
1812 Petersen PM, Giwercman A, Daugaard G, et al. Effect of graded testicular doses of radiotherapy in patients treated for carcinoma-in-situ in the testis. J Clin Oncol. Mar. 15. 2002;20(6):1537-43. X-2, X-3. [pmid: 11896102].
1813 Petersen PM, Hansen SW. The course of long-term toxicity in patients treated with cisplatin- based chemotherapy for non-seminomatous germ-cell cancer. Annals of Oncology. 1999;10(12):1475-1483. X-2, X-3. [pmid: 10643539].
1814 Peterson AC, Bauman JM, Light DE, et al. The prevalence of testicular microlithiasis in an asymptomatic population of men 18 to 35 years old. J Urol. Dec. 2001;166(6):2061-4. X-2, X-3. [pmid: 11696707].
1815 Petreschi F, Digilio MC, Marino B, et al. Prevalence of major malformations in infants with Down’s syndrome. Italian Journal of Pediatrics. Dec. 2002;28(6):488-493. X-2, X-3.
1816 Petrescu A, Dobrea C, Vasilica M, et al. Primary malignant lymphoma of the testis. Rom J Morphol Embryol. 2005;46(2):83-6. X-2, X-3. [pmid: 16286990].
1817 Pettus JA, Carver BS, Masterson T, et al. Preservation of ejaculation in patients undergoing nerve-sparing postchemotherapy retroperitoneal lymph node dissection for metastatic testicular cancer. Urology. Feb. 2009;73(2):328-31. discussion 331–2. X-2, X-3. [pmid: 19022490].
1818 Pharris-Ciurej ND, Cook LS, Weiss NS. Incidence of testicular cancer in the United States: has the epidemic begun to abate?. Am J Epidemiol. Jul. 1. 1999;150(1):45-6. X-2, X-3. [pmid: 10400552].
1819 Phelps S, Agrawal M. Morbidity after neonatal inguinal herniotomy. J Pediatr Surg. Mar. 1997;32(3):445-7. X-2, X-3. [pmid: 9094014].
1820 Philibert P, Audran F, Pienkowski C, et al. Complete androgen insensitivity syndrome is frequently due to premature stop codons in exon 1 of the androgen receptor gene: an international collaborative report of 13 new mutations. Fertil Steril. Jul. 2010;94(2):472-6. X-2, X-3. [pmid: 19463997].
1821 Philip J, Selvan D, Desmond AD. Mumps orchitis in the non-immune postpubertal male: a resurgent threat to male fertility?. BJU Int. Jan. 2006;97(1):138-41. X-2, X-3. [pmid: 16336344].
1822 Phillips G, Kumari-Subaiya S, Sawitsky A. Ultrasonic evaluation of the scrotum in lymphoproliferative disease. J Ultrasound Med. Apr. 1987;6(4):169-75. X-2, X-3. [pmid: 3295282].
1823 Phillipson GT, Petrucco OM, Matthews CD. Congenital bilateral absence of the vas deferens, cystic fibrosis mutation analysis and intracytoplasmic sperm injection. Hum Reprod. Feb. 2000;15(2):431-5. X-2, X-3. [pmid: 10655317].
1824 Phse G, Hense J, Bergmann M, et al. Bilateral histological evaluation of exocrine testicular function in men with obstructive azoospermia: Condition of spermatogenesis and andrological implications?. Human Reproduction. October. 2011;26(10):2606-2612. X-2, X-3. [pmid: 21840906].
1825 Picarro C, Tatsuo ES, Amaral VF, et al. Morphological comparison of processus vaginalis from boys with undescended testis and hernia sacs from boys with inguinal hernia. Eur J Pediatr Surg. Jun. 2009;19(3):145-7. X-3, X-4, X-5, X-6. [pmid: 19347803].
1826 Picone S, Paolillo P. Neonatal outcomes in a population of late-preterm infants. Journal of Maternal-Fetal and Neonatal Medicine. October. 2010;23(SUPPL 3):116-120. X-3. [pmid: 20822332].
1827 Pieri S, Agresti P, Morucci M, et al. A transbranchial approach for the percutaneous therapy of pediatric varicocele. Radiol Med. Sep. 2003;106(3):221-31. X-2, X-3. [pmid: 14612843].
1828 Pierik FH, Burdorf A, De Muinck Keizer-Schrama SMPF, et al. The cryptorchidism prevalence among infants in the general population of Rotterdam, the Netherlands. International Journal of Andrology. Aug. 2005;28(4):248-252. X-3. [pmid: 16048638].
1829 Pierik FH, Burdorf A, Deddens JA, et al. Maternal and paternal risk factors for cryptorchidism and hypospadias: A case-control study in newborn boys. Environmental Health Perspectives. Nov. 2004;112(15):1570-1576. X-3. [pmid: 15531444].
1830 Pierik FH, Vreeburg JT, Stijnen T, et al. Improvement of sperm count and motility after ligation of varicoceles detected with colour Doppler ultrasonography. Int J Androl. Oct. 1998;21(5):256-60. X-2, X-3. [pmid: 9805240].
1831 Pierik FH, Vreeburg JTM, Stijnen T, et al. Serum inhibin B as a marker of spermatogenesis. Journal of Clinical Endocrinology and Metabolism. 1998;83(9):3110-3114. X-2, X-3. [pmid: 9745412].
1832 Pigneur B, Trivin C, Brauner R. Idiopathic central precocious puberty in 28 boys. Med Sci Monit. Jan. 2008;14(1):CR10-14. X-2, X-3. [pmid: 18160938].
1833 Pillai PL, McCracken SRC, Thomas DJ, et al. Is contralateral testicular biopsy warranted at the time of orchidectomy?. British Journal of Medical and Surgical Urology. January. 2009;2(1):17-21. X-3.
1834 Pintauro WL, Klein FA, Vick CW 3rd, et al. The use of ultrasound for evaluating subacute unilateral scrotal swelling. J Urol. May. 1985;133(5):799-802. X-2, X-3. [pmid: 3886937].
1835 Pinto G, Abadie V, Mesnage R, et al. CHARGE syndrome includes hypogonadotropic hypogonadism and abnormal olfactory bulb development. J Clin Endocrinol Metab. Oct. 2005;90(10):5621-6. X-2, X-3. [pmid: 16030162].
1836 Pinto KJ, Kroovand RL, Jarow JP. Varicocele related testicular atrophy and its predictive effect upon fertility. J Urol. Aug. 1994;152(2 Pt 2):788-90. X-2, X-3. [pmid: 8022015].
1837 Pitteloud N, Meysing A, Quinton R, et al. Mutations in fibroblast growth factor receptor 1 cause Kallmann syndrome with a wide spectrum of reproductive phenotypes. Mol Cell Endocrinol. Jul. 25. 2006;254–255:60-9. X-2, X-3.
1838 Pizzocaro G. Retroperitoneal lymphadenectomy in clinical stage I nonseminomatous germinal testis cancer. Eur J Surg Oncol. Mar. 1986;12(1):25-8. X-2, X-3. [pmid: 3007218].
1839 Pizzocaro G, Salvioni R, Zanoni F. Unilateral lymphadenectomy in intraoperative stage I nonseminomatous germinal testis cancer. J Urol. Sep. 1985;134(3):485-9. X-2, X-3. [pmid: 2993672].
1840 Pizzocaro G, Zanoni F, Salvioni R, et al. Surveillance or lymph node dissection in clinical stage I non-seminomatous germinal testis cancer?. Br J Urol. Dec. 1985;57(6):759-62. X-2, X-3. [pmid: 3002535].
1841 Pizzocaro G, Zanoni F, Salvioni R, et al. Difficulties of a surveillance study omitting retroperitoneal lymphadenectomy in clinical stage I nonseminomatous germ cell tumors of the testis. J Urol. Dec. 1987;138(6):1393-6. X-2, X-3. [pmid: 2824862].
1842 Pizzorno R, Bonini F, Donelli A, et al. Blunt scrotal traumas. Ultrasound and immunological follow-up in fifteen years of experience at the urological clinic, Genoa. Acta Urologica Italica. 1997;11(4):225-227. X-2, X-3.
1843 Plas E, Riedl CR, Engelhardt PF, et al. Unilateral or bilateral testicular biopsy in the era of intracytoplasmic sperm injection. J Urol. Dec. 1999;162(6):2010-3. X-2, X-3. [pmid: 10569558].
1844 Plata C, Algaba F, Andujar M, et al. Large cell calcifying Sertoli cell tumour of the testis. Histopathology. 1995;26(3):255-259. X-2, X-3. [pmid: 7541015].
1845 Plevraki E, Kita M, Goulis DG, et al. Bilateral ovarian agenesis and the presence of the testis-specific protein 1-Y-linked gene: Two new features of Mayer-Rokitansky-Kuster-Hauser syndrome. Fertility and Sterility. Mar. 2004;81(3):689-692. X-2, X-3. [pmid: 15037423].
1846 Plotton I, Sanchez P, Durand P, et al. Decrease of both stem cell factor and clusterin mRNA levels in testicular biopsies of azoospermic patients with constitutive or idiopathic but not acquired spermatogenic failure. Hum Reprod. Sep. 2006;21(9):2340-5. X-2, X-3. [pmid: 16709604].
1847 Plouffe L Jr, Behzadian A, Tho SP, et al. Deoxyribonucleic acid analysis of the zinc finger Y gene in 45,X/46,XY subjects. Fertil Steril. Aug. 1990;54(2):265-9. X-2, X-3. [pmid: 2379625].
1848 Podesta ML, Gottlieb S, Medel R Jr, et al. Hormonal parameters and testicular volume in children and adolescents with unilateral varicocele: preoperative and postoperative findings. J Urol. Aug. 1994;152(2 Pt 2):794-7. discussion 798. X-2, X-3. [pmid: 8022017].
1849 Poenaru D, Fitzgerald P. Training general surgery residents in pediatric surgery: A Canadian survey. J Pediatr Surg. May. 2001;36(5):706-10. X-3. [pmid: 11329570].
1850 Politoff L, Hadziselimovic F, Herzog B, et al. Does hydrocele affect later fertility?. Fertil Steril. Apr. 1990;53(4):700-3. X-2, X-3. [pmid: 1969360].
1851 Pombo M, Castro-Feijoo L. Endocrine disruptors. Journal of Pediatric Endocrinology and Metabolism. Dec. 2005;18(SUPPL 1):1145-1155. X-1, X-2, X-3. [pmid: 16398443].
1852 Ponchietti R, Grechi G, Dini G. Varicocele in adolescents: ultrastructural aspects. Acta Eur Fertil. Jan–Feb. 1986;17(1):47-50. X-2, X-3. [pmid: 3727893].
1853 Popek EJ. Embryonal remnants in inguinal hernia sacs. Hum Pathol. Mar. 1990;21(3):339-49. X-2, X-3. [pmid: 2312111].
1854 Popek EJ, Tyson RW, Miller GJ, et al. Prostate development in prune belly syndrome (PBS) and posterior urethral valves (PUV): etiology of PBS--lower urinary tract obstruction or primary mesenchymal defect?. Pediatr Pathol. Jan–Feb. 1991;11(1):1-29. X-2, X-3. [pmid: 2014185].
1855 Portnoi MF, Lebas F, Gruchy N, et al. 22q11.2 Duplication syndrome: Two new familial cases with some overlapping features with DiGeorge/velocardiofacial syndromes. American Journal of Medical Genetics. 15. Aug. 2005;137 A(1):47-51. X-2, X-3. [pmid: 16007629].
1856 Portuondo JA, Neyro JL, Barral A, et al. Management of phenotypic female patients with an XY karyotype. J Reprod Med. Jul. 1986;31(7):611-5. X-2, X-3. [pmid: 3091820].
1857 Pottern LM, Brown LM, Hoover RN, et al. Testicular cancer risk among young men: role of cryptorchidism and inguinal hernia. J Natl Cancer Inst. Feb. 1985;74(2):377-81. X-3. [pmid: 2857796].
1858 Poucell-Hatton S, Huang M, Bannykh S, et al. Fetal obstructive uropathy: patterns of renal pathology. Pediatr Dev Pathol. May–Jun. 2000;3(3):223-31. X-2, X-3. [pmid: 10742409].
1859 Poulakis V, Ferakis N, de Vries R, et al. Induction of spermatogenesis in men with azoospermia or severe oligoteratoasthenospermia after antegrade internal spermatic vein sclerotherapy for the treatment of varicocele. Asian J Androl. Sep. 2006;8(5):613-9. X-2, X-3. [pmid: 16847530].
1860 Pouplard A, Job JC, Luxembourger I, et al. Antigonadotropic cell antibodies in the serum of cryptorchid children and infants and of their mothers. J Pediatr. Jul. 1985;107(1):26-30. X-3. [pmid: 2861264].
1861 Pourbagher MA, Kilinc F, Guvel S, et al. Follow-up of testicular microlithiasis for subsequent testicular cancer development. Urol Int. 2005;74(2):108-12. discussion 113. X-2, X-3. [pmid: 15756060].
1862 Powell TM, Tarter TH. Management of nonpalpable incidental testicular masses. J Urol. Jul. 2006;176(1):96-8. discussion 99. X-2. [pmid: 16753377].
1863 Powers JM, DeCiero DP, Cox C, et al. The dorsal root ganglia in adrenomyeloneuropathy: Neuronal atrophy and abnormal mitochondria. Journal of Neuropathology and Experimental Neurology. May. 2001;60(5):493-501. X-2, X-3. [pmid: 11379824].
1864 Powers JM, Moser HW, Moser AB, et al. Fetal cerebrohepatorenal (Zellweger) syndrome: dysmorphic, radiologic, biochemical, and pathologic findings in four affected fetuses. Hum Pathol. Jun. 1985;16(6):610-20. X-2, X-3. [pmid: 3997138].
1865 Pow-Sang JE, Benavente V, Pow-Sang JM. Management of yolk sac carcinoma of the testis clinical stage I: lymphadenectomy vs. no lymphadenectomy. Prog Clin Biol Res. 1989;303:791-8. X-2, X-3. [pmid: 2780673].
1866 Poyrazoglu S, Saka N, Agayev A, et al. Prevalence of testicular microlithiasis in males with congenital adrenal hyperplasia and its association with testicular adrenal rest tumors. Horm Res Paediatr. 2010;73(6):443-8. X-2, X-3. [pmid: 20407230].
1867 Pozza D, D’Ottavio G, Masci P, et al. Left varicocele at puberty. Urology. Sep. 1983;22(3):271-4. X-2, X-3. [pmid: 6623774].
1868 Pozza D, Gregori A, Pulone M. Surgical treatment of varicocele at adolescence. Acta Chir Hung. 1994;34(3–4):263-6. X-2, X-3. [pmid: 7618377].
1869 Pozza D, Versaci C, Antinori S. Azoospermia. Surgical prospectives. Acta Chir Hung. 1994;34(3–4):267-71. X-2, X-3. [pmid: 7618378].
1870 Pracki W. Laparoscopic and endoscopic inguinal hernia repair. [Polish, English]. Polski Przeglad Chirurgiczny. 2002;74(12):1145-1156. X-2, X-3.
1871 Prater JM, Overdorf BS. Testicular torsion: A surgical emergency. American Family Physician. 1991;44(3):834-840. X-1, X-2, X-3. [pmid: 1877426].
1872 Preiksa RT, Zilaitiene B, Matulevicius V, et al. Higher than expected prevalence of congenital cryptorchidism in Lithuania: a study of 1204 boys at birth and 1 year follow-up. Hum Reprod. Jul. 2005;20(7):1928-32. X-3. [pmid: 15860495].
1873 Preston Smith D, Felker RE, Norman Noe H, et al. Prenatal diagnosis of genital anomalies. Urology. Jan. 1996;47(1):114-117. X-2, X-3. [pmid: 8560643].
1874 Prince FP, Palmer NF, Newton WA. Ultrastructural criteria in evaluating leukemic infiltration in prepubertal testicular biopsies. Pediatr Pathol. 1986;5(1):17-29. X-2, X-3. [pmid: 3460053].
1875 Proud VK, Levine C, Carpenter NJ. New X-linked syndrome with seizures, acquired micrencephaly, and agenesis of the corpus callosum. American Journal of Medical Genetics. 1992;43(1–2):458-466. X-3. [pmid: 1605226].
1876 Przewratil P, Paduch DA, Kobos J, et al. Expression of estrogen receptor alpha and progesterone receptor in children with undescended testicle previously treated with human chorionic gonadotropin. J Urol. Sep. 2004;172(3):1112-6. X-3, X-4, X-5, X-6. [pmid: 15311052].
1877 Puhse G, Wachsmuth JU, Kemper S, et al. Phantom testis syndrome: prevalence, phenomenology and putative mechanisms. Int J Androl. Feb. 2010;33(1):e216-20. X-2, X-3. [pmid: 19765099].
1878 Puri A, Kumar A, Bhatnagar V. Hormonal analysis in post-pubertal patients with posterior urethral valves. European Journal of Pediatric Surgery. Oct. 2002;12(5):308-311. X-2, X-3. [pmid: 12469256].
1879 Puri B, Sreevastava DK. Exomphalos defects: A review of 15 cases. Medical Journal Armed Forces India. Apr. 2008;64(2):115-118. X-2, X-3.
1880 Puri P, Barton D, O’Donnell B. Prepubertal testicular torsion: subsequent fertility. J Pediatr Surg. Dec. 1985;20(6):598-601. X-2, X-3. [pmid: 4087084].
1881 Puri P, Guiney EJ, O’Donnell B. Inguinal hernia in infants: the fate of the testis following incarceration. J Pediatr Surg. Feb. 1984;19(1):44-6. X-2, X-3. [pmid: 6699762].
1882 Puri P, O’Donnell B. Semen analysis of patients who had orchidopexy at or after seven years of age. Lancet. Nov. 5. 1988;2(8619):1051-2. X-4, X-5, X-6. [pmid: 2903280].
1883 Puri P, O’Donnell B. Semen analysis in patients operated on for impalpable testes. Br J Urol. Dec. 1990;66(6):646-7. X-4, X-5, X-6. [pmid: 1979927].
1884 Puri P, Sparnon A. Relationship of primary site of testis to final testicular size in cryptorchid patients. Br J Urol. Aug. 1990;66(2):208-10. X-4, X-5, X-6. [pmid: 1975209].
1885 Purohit TM, Purohit MB, Dabhi BJ. Study of semen analysis and testicular biopsy in infertile male. Indian J Pathol Microbiol. Oct. 2004;47(4):486-90. X-2, X-3. [pmid: 16295372].
1886 Purvis K, Christiansen E. The role of pelvic organ inflammation in the etiology of sperm pathology. International Journal of Fertility. 1993;38(6):372-379. X-2, X-3.
1887 Pyorala S, Huttunen NP, Uhari M. A review and meta-analysis of hormonal treatment of cryptorchidism. Journal of Clinical Endocrinology and Metabolism. 1995;80(9):2795-2799. X-3, X-4, X-5, X-6. [pmid: 7673426].
1888 Qian HJ, Du XJ, Zhang C, et al. Cold ischemia time influences spermatogenesis in a testicular ischemia/reperfusion injury model. Transplant Proc. Jun. 2010;42(5):1610-3. X-2, X-3. [pmid: 20620484].
1889 Quinton R, Duke VM, Robertson A, et al. Idiopathic gonadotrophin deficiency: genetic questions addressed through phenotypic characterization. Clin Endocrinol (Oxf). Aug. 2001;55(2):163-74. X-2, X-3. [pmid: 11531922].
1890 Qvist H, Fossa SD, Ous S, et al. Retroperitoneal surgery in patients with nonseminomatous testicular cancer and minimal residual tumor. J Surg Oncol. Aug. 1992;50(4):220-3. X-2, X-3. [pmid: 1640703].
1891 Rabah DM, Adwan AA, Seida MA. Lymphatic preservation using methylene blue dye during laparoscopic varicocelectomy: early results. Can J Urol. Oct. 2009;16(5):4826-30. X-2, X-3. [pmid: 19796458].
1892 Rabbani F, Goldenberg SL, Gleave ME, et al. Retroperitoneal lymphadenectomy for post-chemotherapy residual masses: is a modified dissection and resection of residual masses sufficient?. Br J Urol. Feb. 1998;81(2):295-300. X-2, X-3. [pmid: 9488075].
1893 Rabbani F, Sheinfeld J, Farivar-Mohseni H, et al. Low-volume nodal metastases detected at retroperitoneal lymphadenectomy for testicular cancer: pattern and prognostic factors for relapse. J Clin Oncol. Apr. 1. 2001;19(7):2020-5. X-2, X-3. [pmid: 11283135].
1894 Raboch J. Spermiological findings in various disturbances of somatosexual development. Andrologia. Jul–Aug. 1982;14(4):347-51. X-2, X-3. [pmid: 6127043].
1895 Radicioni AF, De Marco E, Gianfrilli D, et al. Strategies and advantages of early diagnosis in Klinefelter’s syndrome. Molecular Human Reproduction. June. 2010;16(6):434-440. (gaq027). X-1, X-2, X-3. [pmid: 20392711].
1896 Radpour R, Gourabi H, Gilani MA, et al. Correlation between CFTR gene mutations in Iranian men with congenital absence of the vas deferens and anatomical genital phenotype. J Androl. Jan–Feb. 2008;29(1):35-40. X-2, X-3. [pmid: 17673436].
1897 Rafferty JA, Fan CY, Potter PM, et al. Tissue-specific expression and induction of human O^6^-alkylguanine-DNA alkyltransferase in transgenic mice. Molecular Carcinogenesis. 1992;6(1):26-31. X-2, X-3. [pmid: 1503642].
1898 Ragan DC, Casale AJ, Rink RC, et al. Genitourinary anomalies in the CHARGE association. J Urol. Feb. 1999;161(2):622-5. X-3. [pmid: 9915472].
1899 Raghavan D, Zalcberg JR, Grygiel JJ, et al. Multiple atypical nevi: A cutaneous marker of germ cell tumors. Journal of Clinical Oncology. Nov. 1994;12(11):2284-2287. X-2, X-3. [pmid: 7964941].
1900 Rahhal SN, Fuqua JS. Gynecomastia: Epidemiology, Pathophysiology, and Management. Endocrinology. (Current Clinical Neurology.). 2010:189-214. X-1, X-2, X-3.
1901 Raina V, Shukla NK, Gupta NP, et al. Germ fell tumours in uncorrected cryptorchid testis at Institute Rotary Cancer Hospital, New Delhi. British Journal of Cancer. 1995;71(2):380-382. X-2, X-3. [pmid: 7841056].
1902 Raina V, Shukla NK, Rath GK, et al. Clinical profile and problems of management of 108 cases of germ cell tumours of testis at Institute Rotary Cancer Hospital, All India Institute of Medical Sciences New Delhi 1985–1990. Br J Cancer. Mar. 1993;67(3):573-7. X-2, X-3. [pmid: 8439506].
1903 Raivio T. International Journal of Andrology. [Conference Abstract]. October. Conference: 6th European Congress of Andrology. Athens Greece. Conference Start: 20100929 Conference End: 20101001. Conference Publication: (var.pagings). 2010;33:38. X-3.
1904 Raivio T, Toppari J, Kaleva M, et al. Serum androgen bioactivity in cryptorchid and noncryptorchid boys during the postnatal reproductive hormone surge. J Clin Endocrinol Metab. Jun. 2003;88(6):2597-9. X-3. [pmid: 12788861].
1905 Rajfer J. Association between Wilms tumor and gonadal dysgenesis. J Urol. Mar. 1981;125(3):388-90. X-2, X-3. [pmid: 6110785].
1906 Rajfer J. Surgical and hormonal therapy for cryptorchidism: an overview. Horm Res. 1988;30(4–5):139-43. X-1, X-2, X-3. [pmid: 2907889].
1907 Rajfer J, Sikka SC, Rivera F, et al. Mechanism of inhibition of human testicular steroidogenesis by oral ketoconazole. J Clin Endocrinol Metab. Nov. 1986;63(5):1193-8. X-2, X-3. [pmid: 3760119].
1908 Rajfer J, Swerdloff RS, Heber DM. Testicular histology following chronic gonadotropin-releasing hormone agonist treatment. Fertil Steril. Nov. 1984;42(5):765-71. X-2, X-3. [pmid: 6436070].
1909 Rajimwale A, Brant WO, Koyle MA. High scrotal (Bianchi) single-incision orchidopexy: a “tailored” approach to the palpable undescended testis. Pediatr Surg Int. Aug. 2004;20(8):618-22. X-4, X-5, X-6. [pmid: 15338175].
1910 Rajwanshi A, Indudhara R, Goswami AK, et al. Fine-needle aspiration cytology in azoospermic males. Diagn Cytopathol. 1991;7(1):3-6. X-2, X-3. [pmid: 2026080].
1911 Ramadan SU, Gokharman D, Tuncbilek I, et al. Does the presence of a mesh have an effect on the testicular blood flow after surgical repair of indirect inguinal hernia?. J Clin Ultrasound. Feb. 2009;37(2):78-81. X-2, X-3. [pmid: 18642364].
1912 Raman JD, Goldstein M. The presence of vasal vessels in men with congenital bilateral absence of the vas deferens. J Urol. Nov. 2004;172(5 Pt 1):1941-3. X-2, X-3. [pmid: 15540760].
1913 Raman JD, Nobert CF, Goldstein M. Increased incidence of testicular cancer in men presenting with infertility and abnormal semen analysis. J Urol. Nov. 2005;174(5):1819-22. discussion 1822. X-2, X-3. [pmid: 16217294].
1914 Raman JD, Schlegel PN. Testicular sperm extraction with intracytoplasmic sperm injection is successful for the treatment of nonobstructive azoospermia associated with cryptorchidism. J Urol. Oct. 2003;170(4 Pt 1):1287-90. X-2, X-3. [pmid: 14501743].
1915 Ramlau-Hansen CH, Olesen AV, Parner ET, et al. Perinatal markers of estrogen exposure and risk of testicular cancer: Follow-up of 1,333,873 Danish males born between 1950 and 2002. Cancer Causes and Control. November. 2009;20(9):1587-1592. X-2, X-3. [pmid: 19636804].
1916 Ramos L, de Boer P, Meuleman EJ, et al. Chromatin condensation and DNA damage of human epididymal spermatozoa in obstructive azoospermia. Reprod Biomed Online. Apr. 2004;8(4):392-7. X-2, X-3. [pmid: 15149561].
1917 Ramsay M, Pfaffenzeller W, Kotze E, et al. Chimerism in black southern African patients with true hermaphroditism 46,XX/47XY,+21 and 46,XX/46,XY. Internal Medicine. (Annals of the New York Academy of Sciences. 1151). 2009:68-76. X-2, X-3.
1918 Rana C, Kumari N, Krishnani N. Adrenal histoplasmosis: a diagnosis on fine needle aspiration cytology. Diagn Cytopathol. Jun. 2011;39(6):438-42. X-2, X-3. [pmid: 20949473].
1919 Randolph J, Cavett C, Eng G. Surgical correction and rehabilitation for children with “Prune-belly” syndrome. Ann Surg. Jun. 1981;193(6):757-62. X-2, X-3. [pmid: 6113816].
1920 Ransley PG, Vordermark JS, Caldamone AA, et al. Preliminary ligation of the gonadal vessels prior to orchidopexy for the intra-abdominal testicle. A staged Fowler-Stephens procedure. World Journal of Urology. [Journal]. 1984;2(4):266-268. X-4, X-5, X-6.
1921 Rapley EA, Hockley S, Warren W, et al. Somatic mutations of KIT in familial testicular germ cell tumours. Br J Cancer. Jun. 14. 2004;90(12):2397-401. X-2, X-3. [pmid: 15150569].
1922 Rapola J, Salonen R. Visceral anomalies in the Meckel syndrome. Teratology. Apr. 1985;31(2):193-201. X-2, X-3. [pmid: 3992488].
1923 Rappe BJ, Zandberg AR, De Vries JD, et al. The value of laparoscopy in the management of the impalpable cryptorchid testis. Eur Urol. 1992;21(2):164-7. X-4, X-5, X-6. [pmid: 1354159].
1924 Rasmussen TB, Ingerslev HJ, Hostrup H. Natural history of the maldescended testis. Horm Res. 1988;30(4–5):164-6. X-3. [pmid: 2907893].
1925 Rasoulpour RJ, Schoenfeld HA, Gray DA, et al. Expression of a K48R mutant ubiquitin protects mouse testis from cryptorchid injury and aging. Am J Pathol. Dec. 2003;163(6):2595-603. X-2, X-3. [pmid: 14633631].
1926 Rauen KA, Schoyer L, McCormick F, et al. Proceedings from the 2009 genetic syndromes of the Ras/MAPK pathway: From bedside to bench and back. American Journal of Medical Genetics, Part A. January. 2010;152(1):4-24. X-1, X-2, X-3. [pmid: 20014119].
1927 Ravichandran R, Lafferty F, McGinniss MJ, et al. Congenital adrenal hyperplasia presenting as massive adrenal incidentalomas in the sixth decade of life: report of two patients with 21-hydroxylase deficiency. J Clin Endocrinol Metab. May. 1996;81(5):1776-9. X-2, X-3. [pmid: 8626833].
1928 Ray B, Jewett MAS, Donohue RE. Summary of distribution of retroperitoneal lymph node metastases in testicular germinal tumors (by Biswamay Ray, Steven I. Hajdu, and Willet F. Whitmore, Jr). Seminars in Urologic Oncology. 1997;15(2):130-135. X-2, X-3. [pmid: 9134608].
1929 Raynaud JP. Antiandrogens in combiantion with LH-RH agonists in prostate cancer. American Journal of Clinical Oncology: Cancer Clinical Trials. [Journal]. 1988;11(SUPPL 2):S132-147. X-2, X-3.
1930 Re M, Iannitelli M, Cerasaro A, et al. Histochemical study of glycogen and phosphorylase activity on bilateral biopsies of oligospermic men with varicocele. Arch Androl. Mar. 1983;10(1):79-83. X-2, X-3. [pmid: 6847309].
1931 Read G. Lymphomas of the testis-results of treatment 1960–77. Clin Radiol. Nov. 1981;32(6):687-92. X-2, X-3. [pmid: 7307442].
1932 Recker F, Goepel M, Otto T, et al. An intra-operative seminal and prostate emission test as a control for nerve-sparing procedures in primary and secondary retroperitoneal lymphadenectomy. Br J Urol. Jan. 1996;77(1):133-7. X-2, X-3. [pmid: 8653284].
1933 Reddy EK, Burke M, Giri S, et al. Testicular neoplasms: seminoma. J Natl Med Assoc. Sep. 1990;82(9):651-5. X-2, X-3. [pmid: 2120460].
1934 Reddy GS, Das LK, Pani SP. The preferential site of adult Wuchereria bancrofti: an ultrasound study of male asymptomatic microfilaria carriers in Pondicherry, India. Natl Med J India. Jul–Aug. 2004;17(4):195-6. X-2, X-3. [pmid: 15372761].
1935 Redman JF. Simplified technique for scrotal pouch orchiopexy. Urol Clin North Am. Feb. 1990;17(1):9-12. X-4, X-5, X-6. [pmid: 1968303].
1936 Redman JF. Applied anatomy of the cremasteric muscle and fascia. J Urol. Oct. 1996;156(4):1337-40. X-2, X-3. [pmid: 8808866].
1937 Redman JF. The secondary internal ring: applications to surgery of the inguinal canal. J Urol. Jan. 1996;155(1):170-3. X-4, X-5, X-6. [pmid: 7490824].
1938 Redman JF. Inguinal reoperation for undescended testis and hernia: approach to the spermatic cord through the cremaster fascia. J Urol. Nov. 2000;164(5):1705-7. X-4, X-5, X-6. [pmid: 11025754].
1939 Redman JF. Technique for repair of minimal distal balanitic hypospadias. Urology. Nov. 2006;68(5):1087-90. X-3. [pmid: 17095074].
1940 Redman JF, Barthold JS. A technique for atraumatic scrotal pouch orchiopexy in the management of testicular torsion. J Urol. Oct. 1995;154(4):1511-2. X-2, X-3. [pmid: 7658580].
1941 Redman JF, Reddy PP. Common urologic problems in children: guides to evaluation and referral, Part I. J Ark Med Soc. Jun. 2001;97(12):420-1. X-1, X-2, X-3. [pmid: 11383501].
1942 Redman JF, Reddy PP. Common urologic problems in children: guides to evaluation and referral, Part II. J Ark Med Soc. Jul. 2001;98(1):22-4. X-1, X-2, X-3. [pmid: 11452757].
1943 Redmond IJ, Samaha MA Jr, Charles RS, et al. Bilateral synchronous testicular germ cell cancer. Southern Medical Journal. 1995;88(3):305-308. X-2, X-3. [pmid: 7886527].
1944 Regadera J, Cobo P, Martinez-Garcia F, et al. Testosterone immunoexpression in human Leydig cells of the tunica albuginea testis and spermatic cord. A quantitative study in normal foetuses, young adults, elderly men and patients with cryptorchidism. Andrologia. May–Jun. 1993;25(3):115-22. X-2, X-3. [pmid: 8100125].
1945 Regadera J, Codesal J, Paniagua R, et al. Immunohistochemical and quantitative study of interstitial and intratubular Leydig cells in normal men, cryptorchidism, and Klinefelter’s syndrome. J Pathol. Aug. 1991;164(4):299-306. X-2, X-3. [pmid: 1681041].
1946 Regadera J, Martinez-Garcia F, Gonzalez-Peramato P, et al. Androgen receptor expression in sertoli cells as a function of seminiferous tubule maturation in the human cryptorchid testis. J Clin Endocrinol Metab. Jan. 2001;86(1):413-21. X-2, X-3. [pmid: 11232033].
1947 Reinges MHT, Kaiser WA, Miersch WD, et al. Dynamic magnetic resonance imaging of the contralateral testis in patients with malignant tumor of the testis. Urology. 1994;44(4):540-547. X-2, X-3. [pmid: 7941193].
1948 Reinprayoon D, Bunyavejchevin S. Premarital counseling clinic at Chulalongkorn Hospital. J Med Assoc Thai. Dec. 1998;81(12):993-7. X-2, X-3. [pmid: 9916389].
1949 Reis LM, Tyler RC, Abdul-Rahman O, et al. Mutation analysis of B3GALTL in Peters Plus syndrome. American Journal of Medical Genetics, Part A. 15. Oct. 2008;146(20):2603-2610. X-2, X-3. [pmid: 18798333].
1950 Reis-Filho JS, Ricardo S, Gartner F, et al. Bilateral gonadoblastomas in a dog with mixed gonadal dysgenesis. J Comp Pathol. Feb–Apr. 2004;130(2–3):229-33. X-2, X-3. [pmid: 15003485].
1951 Renshaw AA. Testicular calcifications: incidence, histology and proposed pathological criteria for testicular microlithiasis. J Urol. Nov. 1998;160(5):1625-8. X-2, X-3. [pmid: 9783919].
1952 Renzulli JF 2nd, Shetty R, Mangray S, et al. Clinical and histological significance of the testicular remnant found on inguinal exploration after diagnostic laparoscopy in the absence of a patent processus vaginalis. J Urol. Oct. 2005;174(4 Pt 2):1584-6. discussion 1586. X-4, X-5, X-6. [pmid: 16148657].
1953 Rescorla FJ, Grosfeld JL. Inguinal hernia repair in the perinatal period and early infancy: clinical considerations. J Pediatr Surg. Dec. 1984;19(6):832-7. X-3. [pmid: 6520682].
1954 Resorlu B, Abdulmajed MI, Kara C, et al. Is intracytoplasmic sperm injection essential for the treatment of hypogonadotrophic hypogonadism? A comparison between idiopathic and secondary hypogonadotrophic hypogonadism. Hum Fertil (Camb). Dec. 2009;12(4):204-8. X-2. [pmid: 19824804].
1955 Resorlu B, Kara C, Sahin E, et al. The significance of age on success of surgery for patients with varicocele. Int Urol Nephrol. Jun. 2010;42(2):351-6. X-2, X-3. [pmid: 19507047].
1956 Rey RA, Codner E, Iniguez G, et al. Low risk of impaired testicular Sertoli and Leydig cell functions in boys with isolated hypospadias. J Clin Endocrinol Metab. Nov. 2005;90(11):6035-40. X-3. [pmid: 16131574].
1957 Reynaud R, Albarel F, Saveanu A, et al. Pituitary stalk interruption syndrome in 83 patients: Novel HESX1 mutation and severe hormonal prognosis in malformative forms. European Journal of Endocrinology. 01. Apr. 2011;164(4):457-465. X-2, X-3. [pmid: 21270112].
1958 Reznik Y, Rieu M, Kuhn JM, et al. Luteinizing hormone regulation by sex steroids in men with germinal and Leydig cell tumours. Clin Endocrinol (Oxf). May. 1993;38(5):487-93. X-2, X-3. [pmid: 8392454].
1959 Ribe N, Manasia P, Sarquella J, et al. Clinical follow-up after subinguinal varicocele ligation to treat pain. Arch Ital Urol Androl. Jun. 2002;74(2):51-3. X-2, X-3. [pmid: 12161934].
1960 Riccabona M, Oswald J, Koen M, et al. Optimizing the operative treatment of boys with varicocele: sequential comparison of 4 techniques. J Urol. Feb. 2003;169(2):666-8. X-2, X-3, X-9. [pmid: 12544340].
1961 Richiardi L, Vizzini L, Nordenskjold A, et al. Rates of orchiopexies in Sweden: 1977–1991. Int J Androl. Oct. 2009;32(5):473-8. X-4, X-5, X-6. [pmid: 18336536].
1962 Richie JP. Clinical stage 1 testicular cancer: the role of modified retroperitoneal lymphadenectomy. J Urol. Nov. 1990;144(5):1160-3. X-2, X-3. [pmid: 2172569].
1963 Richthoff J, Rylander L, Hagmar L, et al. Higher sperm counts in Southern Sweden compared with Denmark. Hum Reprod. Sep. 2002;17(9):2468-73. X-2, X-3. [pmid: 12202443].
1964 Riebel T, Gonnermann D, Willig RP. Spermatic venography in undescended testes. Pediatr Radiol. 1987;17(1):39-44. X-3, X-9. [pmid: 2881244].
1965 Rifkin MD. Scrotal ultrasound. Urol Radiol. 1987;9(2):119-26. X-1, X-2, X-3. [pmid: 3303603].
1966 Rigatti P, Bua L, Lesma A, et al. Pediatric andrology. Acta Urologica Italica. 1997;11(5):389-395. X-2, X-3.
1967 Ring KS, Burbige KA, Benson MC, et al. The flow cytometric analysis of undescended testes in children. J Urol. Aug. 1990;144(2 Pt 2):494-8. discussion 512–3. X-3, X-4, X-5, X-6. [pmid: 1973738].
1968 Rio M, Malan V, Boissel S, et al. Familial interstitial Xq27.3q28 duplication encompassing the FMR1 gene but not the MECP2 gene causes a new syndromic mental retardation condition. European Journal of Human Genetics. March. 2010;18(3):285-290. X-2, X-3. [pmid: 19844254].
1969 Riquelme M, Aranda A, Riquelme QM. Laparoscopic pediatric inguinal hernia repair: no ligation, just resection. J Laparoendosc Adv Surg Tech A. Feb. 2010;20(1):77-80. X-3. [pmid: 19489678].
1970 Riquelme M, Aranda A, Rodriguez C, et al. Incidence and management of the inguinal hernia during laparoscopic orchiopexy in palpable cryptoorchidism: preliminary report. Pediatr Surg Int. Apr. 2007;23(4):301-4. X-4, X-5, X-6. [pmid: 17287944].
1971 Riquelme M, Aranda A, Rodriguez C, et al. Laparoscopic orchiopexy for palpable undescended testes: a five-year experience. J Laparoendosc Adv Surg Tech A. Jun. 2006;16(3):321-4. X-4, X-5, X-6. [pmid: 16796451].
1972 Riquet M, Berna P, Brian E, et al. Intrathoracic lymph node metastases from extrathoracic carcinoma: the place for surgery. Ann Thorac Surg. Jul. 2009;88(1):200-5. X-2, X-3. [pmid: 19559225].
1973 Robboy SJ, Jaubert F. Neoplasms and pathology of sexual developmental disorders (intersex). Pathology. Feb. 2007;39(1):147-163. X-1, X-2, X-3. [pmid: 17365831].
1974 Robboy SJ, Miller T, Donahoe PK, et al. Dysgenesis of testicular and streak gonads in the syndrome of mixed gonadal dysgenesis: perspective derived from a clinicopathologic analysis of twenty-one cases. Hum Pathol. Aug. 1982;13(8):700-16. X-2, X-3. [pmid: 7106733].
1975 Robinson TE. Behavioral sensitization: characterization of enduring changes in rotational behavior produced by intermittent injections of amphetamine in male and female rats. Psychopharmacology (Berl). 1984;84(4):466-75. X-2, X-3. [pmid: 6441946].
1976 Rock JA, Wentz AC, Cole KA. Fetal malformations following progesterone therapy during pregnancy: A preliminary report. Fertility and Sterility. 1985;44(1):17-19. X-2, X-3. [pmid: 4007191].
1977 Rodie M, McGowan R, Mayo A, et al. Factors that influence the decision to perform a karyotype in suspected disorders of sex development: lessons from the Scottish genital anomaly network register. Sex Dev. 2011;5(3):103-8. X-2, X-3. [pmid: 21474920].
1978 Rodriguez Pena M, Alescio L, Russell A, et al. Predictors of improved seminal parameters and fertility after varicocele repair in young adults. Andrologia. Oct. 2009;41(5):277-81. X-2, X-3. [pmid: 19737275].
1979 Roemer HC, Von Kathen M, Schops W, et al. Palpation of the testes in draftees: acceptance on the occasion of muster and implication for health promotion. Int J Occup Med Environ Health. 2006;19(4):254-9. X-2, X-3. [pmid: 17402221].
1980 Rogatsch H, Jezek D, Hittmair A, et al. Expression of vimentin, cytokeratin, and desmin in Sertoli cells of human fetal, cryptorchid, and tumour-adjacent testicular tissue. Virchows Arch. Feb. 1996;427(5):497-502. X-2, X-3. [pmid: 8624579].
1981 Rogers E, Teahan S, Gallagher H, et al. The role of orchiectomy in the management of postpubertal cryptorchidism. J Urol. Mar. 1998;159(3):851-4. X-2. [pmid: 9474167].
1982 Rohatgi M, Gupta DK, Menon PS, et al. Mixed gonadal dysgenesis and dysgenetic male pseudohermaphroditism--a critical analysis. Indian J Pediatr. Jul–Aug. 1992;59(4):487-500. X-3. [pmid: 1452268].
1983 Rohatgi M, Menon PS, Verma IC, et al. The presence of intersexuality in patients with advanced hypospadias and undescended gonads. J Urol. Feb. 1987;137(2):263-7. X-3. [pmid: 2879943].
1984 Rolle L, Tamagnone A, Destefanis P, et al. Microsurgical “testis-sparing” surgery for nonpalpable hypoechoic testicular lesions. Urology. Aug. 2006;68(2):381-5. X-2, X-3. [pmid: 16904457].
1985 Romeo R, Castorina S, Marcello MF. Intermediate filaments of human Sertoli cells in germinal alterations. Ital J Anat Embryol. Apr–Jun. 1995;100(2):75-81. X-2, X-3. [pmid: 8760487].
1986 Romeo R, Marcello MF. Some considerations on the human Leydig cell (immunohistochemical observations). Arch Ital Urol Androl. Jun. 1999;71(3):143-8. X-2, X-3. [pmid: 10431405].
1987 Rong R, Zhang CY, Wang XY. Normal appearance of large field diffusion weighted imaging on 3.0T MRI. Chin Med Sci J. Sep. 2008;23(3):158-61. X-2, X-3. [pmid: 18853850].
1988 Rose M, Aberg M, Bohn J. Testicular prosthetic implants in boys and teenagers with primary or secondary anorchism. Scand J Plast Reconstr Surg Hand Surg. 2008;42(2):101-4. X-2, X-3. [pmid: 18335355].
1989 Rosenfield AT, Blair DN, McCarthy S, et al. The pars infravaginalis gubernaculi: Importance in the identification of the undescended testis. American Journal of Roentgenology. [Journal]. 1989;153(4):775-778. X-2, X-3. [pmid: 2570518].
1990 Rosenfield AT, Blair DN, McCarthy S, et al. Society of Uroradiology Award paper. The pars infravaginalis gubernaculi: importance in the identification of the undescended testis. AJR Am J Roentgenol. Oct. 1989;153(4):775-8. X-1, X-3. [pmid: 2570518].
1991 Rosenfield AT, Hammers LW. Imaging of the testicle: the painful scrotum and nonpalpable masses. Urol Radiol. 1992;14(3):229-33. X-1, X-2, X-3. [pmid: 1363258].
1992 Rosito NC, Koff WJ, da Silva Oliveira TL, et al. Volumetric and histological findings in intra-abdominal testes before and after division of spermatic vessels. J Urol. Jun. 2004;171(6 Pt 1):2430-3. X-4, X-5, X-6. [pmid: 15126869].
1993 Ross LS, Ruppman N. Varicocele vein ligation in 565 patients under local anesthesia: a long-term review of technique, results and complications in light of proposed management by laparoscopy. J Urol. May. 1993;149(5 Pt 2):1361-3. X-2, X-3. [pmid: 8479037].
1994 Rossmann ED, Liljegren A, Bergh J. Male breast cancer - How to treat?. Breast Cancer Online. Aug. 2007;10(8):e15. X-1, X-2, X-3.
1995 Roth MY, Lin K, Amory JK, et al. Serum LH correlates highly with intratesticular steroid levels in normal men. Journal of Andrology. March–April. 2010;31(2):138-145. X-2, X-3. [pmid: 19779211].
1996 Rottembourg D, Linglart A, Adamsbaum C, et al. Gonadotrophic status in adolescents with pituitary stalk interruption syndrome. Clin Endocrinol (Oxf). Jul. 2008;69(1):105-11. X-3. [pmid: 18088398].
1997 Routh JC, Gong EM, Cannon GM Jr, et al. Does a controversial topic affect the quality of urologic information on the Internet?. Urology. Nov. 2011;78(5):1051-6. X-2, X-3. [pmid: 21945281].
1998 Routh JC, Huang L, Retik AB, et al. Contemporary epidemiology and characterization of newborn males with prune belly syndrome. Urology. Jul. 2010;76(1):44-8. X-3. [pmid: 20381841].
1999 Rozanski TA, Wojno KJ, Bloom DA. The remnant orchiectomy. J Urol. Feb. 1996;155(2):712-3. discussion 714. X-3, X-4, X-5, X-6. [pmid: 8558712].
2000 Rune GM, Mayr J, Neugebauer H, et al. Pattern of Sertoli cell degeneration in cryptorchid prepubertal testes. Int J Androl. Feb. 1992;15(1):19-31. X-3, X-4, X-5, X-6. [pmid: 1347512].
2001 Rusnack SL, Wu HY, Huff DS, et al. Testis histopathology in boys with cryptorchidism correlates with future fertility potential. J Urol. Feb. 2003;169(2):659-62. X-4, X-5, X-6. [pmid: 12544338].
2002 Russinko PJ, Siddiq FM, Tackett LD, et al. Prescrotal orchiopexy: an alternative surgical approach for the palpable undescended testis. J Urol. Dec. 2003;170(6 Pt 1):2436-8. X-4, X-5, X-6. [pmid: 14634447].
2003 Russu M, Stanculescu R, Nastasia S, et al. Pregnancy outcomes following preconception, early and late administration of vaginal micronized progesterone for recurrent pregnancy loss. Gineco.ro. February. 2009;5(1):10-15. X-2, X-3.
2004 Sabanegh E Jr, Thomas AJ Jr. Effectiveness of crossover transseptal vasoepididymostomy in treating complex obstructive azoospermia. Fertil Steril. Feb. 1995;63(2):392-5. X-2, X-3. [pmid: 7843448].
2005 Sabroe S, Olsen J. Perinatal correlates of specific histological types of testicular cancer in patients below 35 years of age: a case-cohort study based on midwives’ records in Denmark. Int J Cancer. Oct. 5. 1998;78(2):140-3. X-2, X-3. [pmid: 9754641].
2006 Sack J, Reichman B, Fix A. Normative values for testicular descent from infancy to adulthood. Horm Res. 1993;39(3–4):118-21. X-3. [pmid: 7903267].
2007 Sadri-Ardekani H, Mizrak SC, Koruji M, et al. Molecular Human Reproduction. [Conference Abstract]. June. Conference: 25th Annual Meeting of the European Society of Human Reproduction and Embryology, ESHRE. Amsterdam Netherlands. Conference Start: 20090628 Conference End: 20090701. Conference Publication: (var.pagings). 2009;24:i94-i95. X-2, X-3.
2008 Saeed A, Khan AR, Lee V, et al. Pain management for unilateral orchidopexy in children: an effective regimen. World J Surg. Mar. 2009;33(3):603-6. X-4, X-5, X-6. [pmid: 19115030].
2009 Safarinejad MR. Infertility among couples in a population-based study in Iran: prevalence and associated risk factors. Int J Androl. Jun. 2008;31(3):303-14. X-2, X-3. [pmid: 17488339].
2010 Sagnak L, Ersoy H, Ozok U, et al. The significance of Y chromosome microdeletion analysis in subfertile men with clinical variocele. Archives of Medical Science. June. 2010;6(3):382-387. X-2, X-3. [pmid: 22371775].
2011 Sagstuen H, Aass N, Fossa SD, et al. Blood pressure and body mass index in long-term survivors of testicular cancer. J Clin Oncol. Aug. 1. 2005;23(22):4980-90. X-2, X-3. [pmid: 16051950].
2012 Sahakitrungruang T, Tee MK, Blackett PR, et al. Partial defect in the cholesterol side-chain cleavage enzyme P450scc (CYP11A1) resembling nonclassic congenital lipoid adrenal hyperplasia. J Clin Endocrinol Metab. Mar. 2011;96(3):792-8. X-2, X-3. 3047228. [pmid: 21159840].
2013 Sahin C, Artan M, Aksoy Y. The effects of one- and two-stage orchiopexy on postoperative serum testosterone levels and testicular volume in adult patients with bilateral nonpalpable testes. J Laparoendosc Adv Surg Tech A. Oct. 2002;12(5):327-31. X-2. [pmid: 12470406].
2014 Sahin C, Yakut G, Haholu A. Laparoscopic orchiectomy and simultaneous inguinal herniorrhaphy technique by the transperitoneal route in adult patients. J Laparoendosc Adv Surg Tech A. Oct. 2003;13(5):301-4. X-2. [pmid: 14617386].
2015 Sahin C, Yigit T, Ozbey I. Adult nonpalpable testis: is laparoscopy always required?. J Laparoendosc Adv Surg Tech A. Dec. 2002;12(6):431-4. X-2. [pmid: 12590724].
2016 Sahoo T, Naeem R, Pham K, et al. A patient with isochromosome 18q, radial-thumb aplasia, thrombocytopenia, and an unbalanced 10;18 chromosome translocation. American Journal of Medical Genetics. 15. Feb. 2005;133 A(1):93-98. X-2, X-3. [pmid: 15637724].
2017 Sailors DM, Layman TS, Burns RP, et al. Laparoscopic hernia repair: a preliminary report. Am Surg. Feb. 1993;59(2):85-9. X-2, X-3. [pmid: 8476147].
2018 Saito K, Suzuki K, Noguchi K, et al. Semen cryopreservation for patients with malignant or non-malignant disease: our experience for 10 years. Nippon Hinyokika Gakkai Zasshi. May. 2003;94(4):513-20. X-2, X-3. [pmid: 12795166].
2019 Saito S, Kumamoto Y. The number of spermatogonia in various congenital testicular disorders. J Urol. May. 1989;141(5):1166-8. X-3. [pmid: 2565407].
2020 Saito S, Kumamoto Y, Ito N, et al. Human chorionic gonadotropin beta-subunit in human semen. Arch Androl. 1988;20(1):87-99. X-2, X-3. [pmid: 2455489].
2021 Saiyed H, Dewan A, Bhatnagar V, et al. Effect of endosulfan on male reproductive development. Environmental Health Perspectives. Dec. 2003;111(16):1958-1962. X-2, X-3. [pmid: 14644673].
2022 Sakamoto H, Ogawa Y, Yoshida H. Relationship between testicular volume and varicocele in patients with infertility. Urology. Jan. 2008;71(1):104-9. X-2, X-3. [pmid: 18242375].
2023 Sakamoto H, Saito K, Oohta M, et al. Testicular volume measurement: comparison of ultrasonography, orchidometry, and water displacement. Urology. Jan. 2007;69(1):152-7. X-2, X-3. [pmid: 17270639].
2024 Sakamoto H, Saito K, Shichizyo T, et al. Color Doppler ultrasonography as a routine clinical examination in male infertility. Int J Urol. Aug. 2006;13(8):1073-8. X-2, X-3. [pmid: 16903932].
2025 Sakamoto H, Shichizyou T, Saito K, et al. Testicular microlithiasis identified ultrasonographically in Japanese adult patients: prevalence and associated conditions. Urology. Sep. 2006;68(3):636-41. X-2, X-3. [pmid: 16979721].
2026 Sakellaris G, Georgogianaki P, Astyrakaki E, et al. Prevention of post-operative nausea and vomiting in children - A prospective randomized double-blind study. Acta Paediatrica, International Journal of Paediatrics. Jun. 2008;97(6):801-804. X-3.
2027 Sakellaris GS, Charissis GC. Acute epididymitis in Greek children: A 3-year retrospective study. European Journal of Pediatrics. Jul. 2008;167(7):765-769. X-3. [pmid: 17786475].
2028 Salanova M, Gandini L, Lenzi A, et al. Is hyperdiploidy of immature ejaculated germ cells predictive of testis malignancy? A comparative study in healthy normozoospermic, infertile, and testis tumor suffering subjects. Lab Invest. Sep. 1999;79(9):1127-35. X-2, X-3. [pmid: 10496531].
2029 Salenave S, Chanson P, Bry H, et al. Kallmann’s syndrome: a comparison of the reproductive phenotypes in men carrying KAL1 and FGFR1/KAL2 mutations. J Clin Endocrinol Metab. Mar. 2008;93(3):758-63. X-2, X-3. [pmid: 18160472].
2030 Salisz JA, Kass EJ, Steinert BW. The significance of elevated scrotal temperature in an adolescent with a varicocele. Adv Exp Med Biol. 1991;286:245-51. X-2, X-3. [pmid: 2042510].
2031 Sallami S, Dahmani A, Ben Rhouma S, et al. Urology. [Conference Abstract]. October. Conference: 30th Congress of the Societe Internationale d’Urologie, SIU 2009. Shanghai China. Conference Start: 20091101 Conference End: 20091105. Sponsor: SIU. Sponsor: SIU. Conference Publication: (var.pagings). 2009;74(4 SUPPL S):S43-44. X-2, X-3.
2032 Salman AB, Mutlu S, Iskit AB, et al. Hemodynamic monitoring of the contralateral testis during unilateral testicular torsion describes the mechanism of damage. Eur Urol. 1998;33(6):576-80. X-2, X-3. [pmid: 9743701].
2033 Salzhauer EW, Sokol A, Glassberg KI. Paternity after adolescent varicocele repair. Pediatrics. Dec. 2004;114(6):1631-3. X-2, X-3. [pmid: 15574626].
2034 Samnakay N, Cohen RJ, Orford J, et al. Androgen and oestrogen receptor status of the human appendix testis. Pediatr Surg Int. Sep. 2003;19(7):520-4. X-2, X-3. [pmid: 12961092].
2035 Sampaio FJ, Favorito LA, Freitas MA, et al. Arterial supply of the human fetal testis during its migration. J Urol. May. 1999;161(5):1603-5. X-2, X-3. [pmid: 10210426].
2036 Samuel DG, Izzidien AY. Bianchi high scrotal approach revisited. Pediatr Surg Int. Jun. 2008;24(6):741-4. X-4, X-5, X-6. [pmid: 18418610].
2037 Santamaria L, Martinez-Onsurbe P, Paniagua R, et al. Laminin, type IV collagen, and fibronectin in normal and cryptorchid human testes. An immunohistochemical study. Int J Androl. Apr. 1990;13(2):135-46. X-3. [pmid: 1971616].
2038 Santoro S, Boninsegni R, Bassi F, et al. Testosterone concentrations in spermatic venous blood plasma of prepubertal boys. Int J Androl. Feb. 1981;4(1):82-5. X-3, X-4, X-5, X-6. [pmid: 7203695].
2039 Saranga Bharathi R, Arora M, Baskaran V. Pediatric inguinal hernia: laparoscopic versus open surgery. JSLS. Jul–Sep. 2008;12(3):277-81. X-2, X-3. [pmid: 18765052].
2040 Sarfati J, Guiochon-Mantel A, Rondard P, et al. A comparative phenotypic study of kallmann syndrome patients carrying monoallelic and biallelic mutations in the prokineticin 2 or prokineticin receptor 2 genes. J Clin Endocrinol Metab. Feb. 2010;95(2):659-69. X-2, X-3. [pmid: 20022991].
2041 Sarrate Z, Blanco J, Egozcue S, et al. Identification of meiotic anomalies with multiplex fluorescence in situ hybridization: Preliminary results. Fertil Steril. Sep. 2004;82(3):712-7. X-2, X-3. [pmid: 15374719].
2042 Sasagawa I, Ichiyanagi O, Yazawa H, et al. Round spermatid transfer and embryo development. Archives of Andrology. 1998;41(3):151-157. X-2, X-3. [pmid: 9805142].
2043 Sasagawa I, Nakada T, Hashimoto T, et al. Hormone profiles and contralateral testicular histology in Down’s syndrome with unilateral testicular tumor. Arch Androl. Mar–Apr. 1993;30(2):93-8. X-2, X-3. [pmid: 8470946].
2044 Sasagawa I, Nakada T, Ishigooka M, et al. Chromosomal anomalies in cryptorchidism. Int Urol Nephrol. 1996;28(1):99-102. X-3. [pmid: 8738627].
2045 Sasagawa I, Nakada T, Ishigooka M, et al. Cryptorchidism and marker chromosomes: identification of marker chromosomes by fluorescence in situ hybridization. Urol Int. 1995;55(1):25-8. X-3. [pmid: 7571179].
2046 Sasagawa I, Nakada T, Yanagimachi R. Application of ICSI for cryptorchid therapy. Archives of Andrology. 2000;45(2):77-83. X-3. [pmid: 11028923].
2047 Sathyanarayana S, Beard L, Zhou C, et al. Measurement and correlates of ano-genital distance in healthy, newborn infants. Int J Androl. Apr. 2010;33(2):317-23. X-2, X-3. [pmid: 20132349].
2048 Sato K, Kihara K, Ando M, et al. Seminal emission by electrical stimulation of the spermatic nerve and epididymis. Int J Androl. Dec. 1991;14(6):461-7. X-2, X-3. [pmid: 1761326].
2049 Sattler B, Randall KS, Choiniere D. Reducing hazardous chemical exposures in the neonatal intensive care unit: A new role for nurses. Critical Care Nursing Quarterly. January-March. 2012;35(1):102-112. X-1, X-2, X-3. [pmid: 22157496].
2050 Saxena AK, Hulskamp G, Schleef J, et al. Gastroschisis: a 15-year, single-center experience. Pediatr Surg Int. Sep. 2002;18(5–6):420-4. X-3. [pmid: 12415370].
2051 Schaison G, Renoir M, Lagoguey M, et al. On the role of dihydrotestosterone in regulating luteinizing hormone secretion in man. J Clin Endocrinol Metab. Nov. 1980;51(5):1133-7. X-2, X-3. [pmid: 6106650].
2052 Schaison G, Young J, Pholsena M, et al. Failure of combined follicle-stimulating hormone-testosterone administration to initiate and/or maintain spermatogenesis in men with hypogonadotropic hypogonadism. J Clin Endocrinol Metab. Dec. 1993;77(6):1545-9. X-2, X-3. [pmid: 8263139].
2053 Scheiber K, Ackermann D, Studer UE. Bilateral testicular germ cell tumors: a report of 20 cases. J Urol. Jul. 1987;138(1):73-6. X-2, X-3. [pmid: 3037124].
2054 Scheiber K, Marberger H, Bartsch G. Exocrine and endocrine testicular function in patients with unilateral testicular disease. J R Soc Med. Aug. 1983;76(8):649-51. X-3, X-4, X-5, X-6. [pmid: 6136609].
2055 Scheiber K, Menardi G, Margerger H, et al. Late results after surgical treatment of maldescended testes with special regard to exocrine and endocrine testicular function. Eur Urol. 1981;7(5):268-73. X-4, X-5, X-6. [pmid: 6113961].
2056 Scheiber K, Mikuz G, Bartsch G. Exocrine and endocrine functions in unilateral testicular disease. World Journal of Urology. [Journal]. 1984;2(4):251-254. X-2, X-3.
2057 Scheiden R, Hein T, Wagener C, et al. Testicular cancer in Luxembourg: incidence and outcome in relation to the different histo-pathological types (1980–2004). Bull Soc Sci Med Grand Duche Luxemb. 2008;(4):521-39. X-2, X-3. [pmid: 19024372].
2058 Scherr D, Goldstein M. Comparison of bilateral versus unilateral varicocelectomy in men with palpable bilateral varicoceles. J Urol. Jul. 1999;162(1):85-8. X-2, X-3. [pmid: 10379746].
2059 Schier F, Montupet P, Esposito C. Laparoscopic inguinal herniorrhaphy in children: a three-center experience with 933 repairs. J Pediatr Surg. Mar. 2002;37(3):395-7. X-2, X-3. [pmid: 11877655].
2060 Schier F, Turial S, Huckstadt T, et al. Laparoscopic inguinal hernia repair does not impair testicular perfusion. J Pediatr Surg. Jan. 2008;43(1):131-5. discussion 135. X-2, X-3. [pmid: 18206470].
2061 Schiff J, Kelly C, Goldstein M, et al. Managing varicoceles in children: results with microsurgical varicocelectomy. BJU Int. Feb. 2005;95(3):399-402. X-2, X-3. [pmid: 15679802].
2062 Schinfeld JS, Schiff I, Newton R. Testicular hormone concentration in men with varicoceles: immediate effects of varicocelectomy. Int J Fertil. 1983;28(3):177-80. X-2, X-3. [pmid: 6140239].
2063 Schlegel PN, Goldstein M. Microsurgical vasoepididymostomy: refinements and results. J Urol. Oct. 1993;150(4):1165-8. X-2, X-3. [pmid: 8371380].
2064 Schmidt L, Vydra G. Current problems of the diagnostics of the retroperitoneum. Acta Chir Hung. 1986;27(1):35-44. X-2, X-3. [pmid: 3012918].
2065 Schnack TH, Poulsen G, Myrup C, et al. Familial coaggregation of cryptorchidism, hypospadias, and testicular Germ cell cancer: A nationwide cohort study. Journal of the National Cancer Institute. February. 2010;102(3):187-192. X-2, X-3. [pmid: 20026812].
2066 Schoor RA, Elhanbly SM, Ross LS, et al. The influence of obstructive interval on patency rates following microsurgical epididymovasostomy. World J Urol. Apr. 2002;19(6):453-6. X-2, X-3. [pmid: 12022714].
2067 Schoorl M, Frensdorf EL, Heijens JP. The results of surgical therapy for bilateral maldescended testes. Z Kinderchir. Jun. 1983;38(3):169-72. X-2. [pmid: 6138908].
2068 Schover LR, von Eschenbach AC. Sexual and marital relationships after treatment for nonseminomatous testicular cancer. Urology. Mar. 1985;25(3):251-5. X-2, X-3. [pmid: 4038829].
2069 Schrader M, Muller M, Sofikitis N, et al. “Onco-tese”: testicular sperm extraction in azoospermic cancer patients before chemotherapy-new guidelines?. Urology. Feb. 2003;61(2):421-5. X-2, X-3. [pmid: 12597960].
2070 Schrepferman CG, Carson MR, Sparks AE, et al. Need for sperm retrieval and cryopreservation at vasectomy reversal. J Urol. Nov. 2001;166(5):1787-9. X-2, X-3. [pmid: 11586225].
2071 Schulze KA, Pfister RR. Evaluating the undescended testis. Am Fam Physician. Jun. 1985;31(6):133-9. X-1, X-3. [pmid: 2861735].
2072 Schulze W, Thoms F, Knuth UA. Testicular sperm extraction: comprehensive analysis with simultaneously performed histology in 1418 biopsies from 766 subfertile men. Hum Reprod. Sep. 1999;14(Suppl 1):82-96. X-2, X-3. [pmid: 10573026].
2073 Schwager KL, Baines DB, Meyer RJ. Acupuncture and postoperative vomiting in day-stay paediatric patients. Anaesth Intensive Care. Dec. 1996;24(6):674-7. X-2, X-3. [pmid: 8971315].
2074 Schwarzer JU, Fiedler K, Hertwig IV, et al. Male factors determining the outcome of intracytoplasmic sperm injection with epididymal and testicular spermatozoa. Andrologia. Aug. 2003;35(4):220-226. X-2, X-3. [pmid: 12950406].
2075 Schwarzer JU, Fiedler K, Hertwig IV, et al. Sperm retrieval procedures and intracytoplasmatic spermatozoa injection with epididymal and testicular sperms. Urologia Internationalis. 2003;70(2):119-123. X-2, X-3. [pmid: 12592040].
2076 Scolfaro MR, Cardinalli IA, Stuchi-Perez EG, et al. Morphometry and histology of gonads from 13 children with dysgenetic male pseudohermaphroditism. Archives of Pathology and Laboratory Medicine. 2001;125(5):652-656. X-3. [pmid: 11300937].
2077 Scott JE. Laparoscopy as an aid in diagnosis and management of the impalpable testis. J Pediatr Surg. Feb. 1982;17(1):14-6. X-4, X-5, X-6. [pmid: 6122725].
2078 Sebold C, Roeder E, Zimmerman M, et al. Tetrasomy 18p: Report of the molecular and clinical findings of 43 individuals. American Journal of Medical Genetics, Part A. September. 2010;152(9):2164-2172. X-2, X-3. [pmid: 20803640].
2079 Seddon JM, Savory L, Scott-Conner C. Cryptorchidism: the role of medical education in diagnosis. South Med J. Oct. 1985;78(10):1201-4. X-3. [pmid: 2864743].
2080 Seibold J, Janetschek G, Bartsch G. Laparoscopic surgery in pediatric urology. Eur Urol. 1996;30(3):394-9. X-4, X-5, X-6. [pmid: 8931976].
2081 Seifer I, Amat S, Delgado-Viscogliosi P, et al. Screening for microdeletions on the long arm of chromosome Y in 53 infertile men. Int J Androl. Jun. 1999;22(3):148-54. X-2, X-3. [pmid: 10367234].
2082 Selice R, Di Mambro A, Garolla A, et al. Spermatogenesis in Klinefelter syndrome. Journal of Endocrinological Investigation. December. 2010;33(11):789-793. X-2, X-3. [pmid: 20332707].
2083 Seminara SB, Boepple PA, Nachtigall LB, et al. Inhibin B in males with gonadotropin-releasing hormone (GnRH) deficiency: changes in serum concentration after shortterm physiologic GnRH replacement--a clinical research center study. J Clin Endocrinol Metab. Oct. 1996;81(10):3692-6. X-2, X-3. [pmid: 8855824].
2084 Semmes OJ, Feng Z, Adam BL, et al. Evaluation of serum protein profiling by surface-enhanced laser desorption/ionization time-of-flight mass spectrometry for the detection of prostate cancer: I. Assessment of platform reproducibility. Clinical Chemistry. Jan. 2005;51(1):102-112. X-2, X-3. [pmid: 15613711].
2085 Sengupta B. A study on Pre-employment Medical Examination for non-gazetted Railway Services. Indian Journal of Occupational and Environmental Medicine. Jan. 2003;7(1):7-10. X-2, X-3.
2086 Sepulveda W, Dezerega V, Horvath E, et al. Prenatal sonographic diagnosis of Aarskog syndrome. J Ultrasound Med. Oct. 1999;18(10):707-10. X-2, X-3. [pmid: 10511304].
2087 Serban M, Poenaru D, Pop L, et al. Surgery--a challenge in haemophiliacs with inhibitors. Hamostaseologie. Oct. 2009;29(Suppl 1):S39-41. X-2, X-3. [pmid: 19763345].
2088 Serefoglu EC, Balbay MD. Slow zoledronic acid releasing testis prostheses in the treatment of prostate cancer patients with bone metastases. Med Hypotheses. Sep. 2009;73(3):387-8. X-1, X-2, X-3. [pmid: 19403241].
2089 Serio M, Forti G, Facchinetti F, et al. Steroid secretion by the prepubertal human testis. J Steroid Biochem. Jul. 1983;19(1C):897-9. X-3, X-4, X-5, X-6. [pmid: 6887909].
2090 Serter S, Orguc S, Gumus B, et al. Doppler sonographic findings in testicular microlithiasis. Int Braz J Urol. Jul–Aug. 2008;34(4):477-82. discussion 482–4. X-2, X-3. [pmid: 18778499].
2091 Sethia KK, Bickerstaff KI, Murie JA. Changing pattern of scrotal exploration for testicular torsion. Urology. May. 1988;31(5):408-10. X-2, X-3. [pmid: 2896408].
2092 Sexton WJ, Assimos DG. Diagnostic and therapeutic laparoscopy for the adult cryptorchid testicle. Tech Urol. Mar. 1999;5(1):24-8. X-2. [pmid: 10374791].
2093 Seyed-Ahadi MM, Khaleghnejad-Tabari A, Mirshemirani A, et al. Wilm’s tumor: A 10 year retrospective study. Archives of Iranian Medicine. Jan. 2007;10(1):65-69. X-3. [pmid: 17198457].
2094 Seymour JF, Solomon B, Wolf MM, et al. Primary large-cell non-Hodgkin’s lymphoma of the testis: a retrospective analysis of patterns of failure and prognostic factors. Clin Lymphoma. Sep. 2001;2(2):109-15. X-2, X-3. [pmid: 11707851].
2095 Shafik A, Bedeir GA. Venous tension patterns in cord veins. I. In normal and varicocele individuals. J Urol. Mar. 1980;123(3):383-5. X-2, X-3. [pmid: 7359642].
2096 Shafik A, Shafik AA, El Sibai O, et al. Inguinal canal dilatation: a novel technique for the repair of failed testicular descent despite hormonal treatment. Am Surg. Jan. 2008;74(1):69-72. X-4, X-5, X-6. [pmid: 18274434].
2097 Shahsiah R, Jahanbin B, Rabiei R, et al. Malignant ovarian germ cell tumours in gonadal Y chromosome mosaicism. J Clin Pathol. Nov. 2011;64(11):973-6. X-2, X-3. [pmid: 21752796].
2098 Shalaby R, Ismail M, Dorgham A, et al. Laparoscopic hernia repair in infancy and childhood: evaluation of 2 different techniques. J Pediatr Surg. Nov. 2010;45(11):2210-6. X-2, X-3. [pmid: 21034946].
2099 Shalet SM, Tsatsoulis A, Whitehead E, et al. Vulnerability of the human Leydig cell to radiation damage is dependent upon age. J Endocrinol. Jan. 1989;120(1):161-5. X-3. [pmid: 2493061].
2100 Sham JS, Choy D, Chan KW, et al. Seminoma of normally-descended and cryptorchid testis. Eur J Surg Oncol. Feb. 1990;16(1):33-6. X-3, X-4, X-5, X-6. [pmid: 1968400].
2101 Shamsa A, Shakeri MT, Amirzarghar MA, et al. Male fertility after spermatocele formation from tunica vaginalis in patients with bilateral vas agenesis. Saudi J Kidney Dis Transpl. Jul. 2008;19(4):583-6. X-2, X-3. [pmid: 18580017].
2102 ShangGuan W, Lian Q, Li J, et al. Clinical pharmacology of cisatracurium during nitrous oxide-propofol anesthesia in children. Journal of Clinical Anesthesia. September. 2008;20(6):411-414. X-4, X-5, X-6. [pmid: 18929279].
2103 Shannon RS, Mann JR, Harper E, et al. Wilms’s tumour and aniridia: clinical and cytogenetic features. Arch Dis Child. Sep. 1982;57(9):685-90. X-2, X-3. [pmid: 6289758].
2104 Sharfuddin A, Kumar S. Renal colic: Keys to diagnosis and management. Consultant. Aug. 2002;42(9):1189-1198. X-2, X-3.
2105 Sharland M, Burch M, McKenna WM, et al. A clinical study of Noonan syndrome. Arch Dis Child. Feb. 1992;67(2):178-83. X-2, X-3. [pmid: 1543375].
2106 Sharlip ID. Surgery of scrotal contents. Urologic Clinics of North America. 1987;14(1):145-148. X-3, X-4, X-5, X-6. [pmid: 3811048].
2107 Sharma S, Gupta DK. Gender assignment and hormonal treatment for disorders of sexual differentiation. Pediatr Surg Int. Oct. 2008;24(10):1131-5. X-3. [pmid: 18704450].
2108 Sharma SK, Aggarwal R. Prediction of large esophageal varices in patients with cirrhosis of the liver using clinical, laboratory and imaging parameters. Journal of Gastroenterology and Hepatology. Nov. 2007;22(11):1909-1915. X-2, X-3. [pmid: 17914969].
2109 Shastry S, Simha V, Godbole K, et al. A novel syndrome of mandibular hypoplasia, deafness, and progeroid features associated with lipodystrophy, undescended testes, and male hypogonadism. Journal of Clinical Endocrinology and Metabolism. October. 2010;95(10):E192-197. X-3. [pmid: 20631028].
2110 Sheehan SJ, Tobbia IN, Ismail MA, et al. Persistent Mullerian duct syndrome. Review and report of 3 cases. Br J Urol. Oct. 1985;57(5):548-51. X-3. [pmid: 2866011].
2111 Shefi S, Kaplan K, Turek PJ. Analysis of spermatogenesis in non-obstructive azoospermic and virtually azoospermic men with known testicular pathology. Reprod Biomed Online. Apr. 2009;18(4):460-4. X-2, X-3. [pmid: 19400985].
2112 Shehata SM. Laparoscopically assisted gradual controlled traction on the testicular vessels: a new concept in the management of abdominal testis. A preliminary report. Eur J Pediatr Surg. Dec. 2008;18(6):402-6. X-4, X-5, X-6. [pmid: 19012232].
2113 Sheynkin YR, Hendin BN, Schlegel PN, et al. Microsurgical repair of iatrogenic injury to the vas deferens. J Urol. Jan. 1998;159(1):139-41. X-2, X-3. [pmid: 9400456].
2114 Sheynkin YR, Sukkarieh T, Lipke M, et al. Management of nonpalpable testicular tumors. Urology. Jun. 2004;63(6):1163-7. discussion 1167. X-2, X-3. [pmid: 15183972].
2115 Shima H, Yabumoto H, Okamoto E, et al. Testicular function in patients with hypospadias associated with enlarged prostatic utricle. Br J Urol. Feb. 1992;69(2):192-5. X-2, X-3. [pmid: 1346978].
2116 Shimada K, Hosokawa S, Tohda A, et al. Histology of the fetal prune belly syndrome with reference to the efficacy of prenatal decompression. Int J Urol. May. 2000;7(5):161-6. X-2, X-3. [pmid: 10830822].
2117 Shin D, Lipshultz LI, Goldstein M, et al. Herniorrhaphy with polypropylene mesh causing inguinal vasal obstruction: a preventable cause of obstructive azoospermia. Ann Surg. Apr. 2005;241(4):553-8. X-2, X-3. [pmid: 15798455].
2118 Shioshvili TI. Bilateral abdominal cryptorchidism in males: autotransplantation of the testis. Eur Urol. 1985;11(6):386-7. X-4, X-5, X-6. [pmid: 2867909].
2119 Shipp TD, Benacerraf BR. The significance of prenatally identified isolated clubfoot: is amniocentesis indicated?. Am J Obstet Gynecol. Mar. 1998;178(3):600-2. X-2, X-3. [pmid: 9539532].
2120 Shiraishi K, Shimabukuro T, Naito K. Effects of hemodialysis on testicular volume and oxidative stress in humans. J Urol. Aug. 2008;180(2):644-50. X-2, X-3. [pmid: 18554652].
2121 Shiraishi K, Takihara H, Matsuyama H. Effects of grade 1 varicocele detected in the pediatric age-group on testicular development. J Pediatr Surg. Oct. 2009;44(10):1995-8. X-2, X-3. [pmid: 19853761].
2122 Shiryazdi SM, Modir A, Benrazavi S, et al. Causes of delay in proper treatment of patients with undescended testis. Iranian Journal of Reproductive Medicine. 2011;9(1):37-40. X-3, X-4, X-5, X-6.
2123 Shrestha GK, Ikoma F, Schumacher S, et al. Asymptomatic vesicoureteral reflux in children. Int Urol Nephrol. 1994;26(3):283-91. X-3. [pmid: 7960539].
2124 Shukla AR, Huff DS, Canning DA, et al. Juvenile granulosa cell tumor of the testis: Contemporary clinical management and pathological diagnosis. Journal of Urology. May. 2004;171(5):1900-1902. X-2, X-3. [pmid: 15076304].
2125 Sica GS, Di Lorenzo N, Sileri P, et al. Microsurgery and changes in the testicular and epididymal production of spermatozoa. Ann Ital Chir. Sep–Oct. 1996;67(5):677-80. discussion 681. X-2, X-3. [pmid: 9008977].
2126 Sidler D, Brown RA, Millar AJ, et al. A 25-year review of the acute scrotum in children. S Afr Med J. Dec. 1997;87(12):1696-8. X-2, X-3. [pmid: 9497837].
2127 Sigman M, Jarow JP. Ipsilateral testicular hypotrophy is associated with decreased sperm counts in infertile men with varicoceles. J Urol. Aug. 1997;158(2):605-7. X-2, X-3. [pmid: 9224376].
2128 Sih R, Morley JE, Kaiser FE, et al. Testosterone replacement in older hypogonadal men: a 12-month randomized controlled trial. J Clin Endocrinol Metab. Jun. 1997;82(6):1661-7. X-2, X-3. [pmid: 9177359].
2129 Sijstermans K, Hack WW, van der Voort-Doedens LM, et al. Long-term testicular growth and position after orchidopexy for congenital undescended testis. Urol Int. 2009;83(4):438-45. X-4, X-5, X-6. [pmid: 19996652].
2130 Sijstermans K, Hack WW, van der Voort-Doedens LM, et al. Puberty stage and spontaneous descent of acquired undescended testis: implications for therapy?. Int J Androl. Dec. 2006;29(6):597-602. X-3. [pmid: 16817910].
2131 Sikka M, Agarwal S. Bilateral testicular biopsy--is it necessary?. Indian J Pathol Microbiol. Jul. 1991;34(3):172-5. X-2, X-3. [pmid: 1818852].
2132 Siklar Z, Berberoglu M, Adiyaman P, et al. Disorders of gonadal development: a broad clinical, cytogenetic and histopathologic spectrum. Pediatr Endocrinol Rev. Mar. 2007;4(3):210-7. X-2, X-3. [pmid: 17551482].
2133 Silber SJ. The intra-abdominal testes: microvascular autotransplantation. J Urol. Mar. 1981;125(3):329-33. X-3, X-4, X-5, X-6. [pmid: 6110784].
2134 Silber SJ, Nagy Z, Devroey P, et al. Distribution of spermatogenesis in the testicles of azoospermic men: the presence or absence of spermatids in the testes of men with germinal failure. Hum Reprod. Nov. 1997;12(11):2422-8. X-2, X-3. [pmid: 9436677].
2135 Silber SJ, Nagy ZP, Liu J, et al. Conventional in-vitro fertilization versus intracytoplasmic sperm injection for patients requiring microsurgical sperm aspiration. Hum Reprod. Sep. 1994;9(9):1705-9. X-2, X-3. [pmid: 7836522].
2136 Simoni M, Tuttelmann F, Gromoll J, et al. Clinical consequences of microdeletions of the Y chromosome: the extended Munster experience. Reprod Biomed Online. Feb. 2008;16(2):289-303. X-2, X-3. [pmid: 18284889].
2137 Simoni M, Tuttelmann F, Michel C, et al. Polymorphisms of the luteinizing hormone/chorionic gonadotropin receptor gene: Association with maldescended testes and male infertility. Pharmacogenetics and Genomics. Mar. 2008;18(3):193-200. X-3. [pmid: 18300940].
2138 Simpson AS, Laugesen M, Silva PA, et al. The prevalence of retained testes in Dunedin. N Z Med J. Sep. 11. 1985;98(786):758-60. X-3. [pmid: 2864676].
2139 Simsek F, Hayran O, Tarcan T, et al. Social and medical aspects of undescended testes in Turkey. Eur Urol. 1995;28(2):161-4. X-3. [pmid: 8529744].
2140 Singer R, Dickerman Z, Sagiv M, et al. Endocrinological parameters and cell-mediated immunity postoperation for cryptorchidism. Arch Androl. 1988;20(2):153-7. X-3. [pmid: 2899421].
2141 Singer R, Lahav M, Barnet M, et al. Acrosome reaction of sperm/binding of peanut agglutinin in sperm of varicocele patients. Molecular Andrology. 1995;7(3–4):215-221. X-2, X-3.
2142 Singh H, Sharma B. Vasoplasty: flap operation. Br J Urol. Apr. 1983;55(2):233-4. X-2, X-3. [pmid: 6839101].
2143 Singh JP, Chaturvedi NK, Chawla R. A new approach in evaluation of fertility in surgically treated cryptorchids. Acta Eur Fertil. Sep–Oct. 1987;18(5):321-7. X-3, X-4, X-5, X-6. [pmid: 2899941].
2144 Singh PA, Singh M, Misra V, et al. Testicular biopsy in infertility. J Indian Med Assoc. Dec. 1999;97(12):482-5. X-2, X-3. [pmid: 10638122].
2145 Singh TG, Sarma BB, Chinglensana L, et al. Surgical management of inguinal hernia and hydrocele in children: A retrospective study. JMS - Journal of Medical Society. Sep. 2006;20(3):132-135. X-3.
2146 Sinha CK, Vinay S, Kulkarni R, et al. Delayed diagnosis for undescended testes. Indian Pediatr. Jun. 2008;45(6):503-4. X-3. [pmid: 18599940].
2147 Sinisi AA, Di Finizio B, Lettieri F, et al. Late gonadal function and autoimmunization in familial testicular torsion. Arch Androl. May–Jun. 1993;30(3):147-52. X-2, X-3. [pmid: 8498865].
2148 Sinnema M, Maaskant MA, van Schrojenstein Lantman-de, Valk HM, et al. Physical health problems in adults with Prader-Willi syndrome. American Journal of Medical Genetics, Part A. September. 2011;155(9):2112-2124. X-2, X-3. [pmid: 21834028].
2149 Siracusa F, Di Pace MR, Cataliotti F, et al. Testicular tumors in childhood: A national report. Pediatric Surgery International. 1993;8(3):244-247. X-2, X-3.
2150 Sirvent JJ, Bernat R, Rodriguez Tolra J, et al. Postpubertal cryptorchism. Morphofunctional study with special reference to Leydig’s cells. Eur Urol. 1989;16(6):433-9. X-2, X-3. [pmid: 2574110].
2151 Skakkebaek NE. Endocrine Abstracts. [Conference Abstract]. Conference: 12th European Congress of Endocrinology 2010, ECE 2010. Prague Czech Republic. Conference Start: 20100424 Conference End: 20100428. Conference Publication: (var.pagings). 2010;22:PL2. X-3.
2152 Skakkebaek NE, Holm M, Hoei-Hansen C, et al. Association between testicular dysgenesis syndrome (TDS) and testicular neoplasia: evidence from 20 adult patients with signs of maldevelopment of the testis. APMIS. Jan. 2003;111(1):1-9. discussion 9–11. X-2, X-3. [pmid: 12752226].
2153 Skawran S, Weyhe D, Schmitz B, et al. Bilateral endoscopic total extraperitoneal (TEP) inguinal hernia repair does not induce obstructive azoospermia: data of a retrospective and prospective trial. World J Surg. Jul. 2011;35(7):1643-8. X-2, X-3. [pmid: 21487852].
2154 Skinner DG. Advanced metastatic testicular cancer: the need for reporting results according to initial extent of disease. J Urol. Aug. 1982;128(2):312-4. X-2, X-3. [pmid: 7109098].
2155 Skinnider BF, Young RH. Infarcted adenomatoid tumor: a report of five cases of a facet of a benign neoplasm that may cause diagnostic difficulty. Am J Surg Pathol. Jan. 2004;28(1):77-83. X-2, X-3. [pmid: 14707867].
2156 Skotheim RI, Kraggerud SM, Fossa SD, et al. Familial/bilateral and sporadic testicular germ cell tumors show frequent genetic changes at loci with suggestive linkage evidence. Neoplasia. May–Jun. 2001;3(3):196-203. X-2, X-3. [pmid: 11494113].
2157 Slater AJ, James KW, Fifield R, et al. The investigation and treatment of germ cell tumours of the testis. Clin Radiol. Jan. 1981;32(1):25-30. X-2, X-3. [pmid: 6783360].
2158 Slot B, Meijenhorst GC. Venography of the left internal spermatic vein in patients with fertility problems. Diagn Imaging. 1982;51(5):214-23. X-1, X-2, X-3. [pmid: 7128396].
2159 Slowikowska-Hilczer J, Guminska A, Kula K. Pathogenesis and active prevention of testicular germ cell neoplasia. Journal fur Reproduktionsmedizin und Endokrinologie. 2007;4(6):313-321. X-3.
2160 Slowikowska-Hilczer J, Romer TE, Kula K. Neoplastic potential of germ cells in relation to disturbances of gonadal organogenesis and changes in karyotype. J Androl. Mar–Apr. 2003;24(2):270-8. X-2, X-3. [pmid: 12634315].
2161 Slowikowska-Hilczer J, Walczak-Jedrzejowska R, Kula K. Immunohistochemical diagnosis of preinvasive germ cell cancer of the testis. Folia Histochem Cytobiol. 2001;39(2):67-72. X-2, X-3. [pmid: 11374842].
2162 Small CM, DeCaro JJ, Terrell ML, et al. Maternal exposure to a brominated flame retardant and genitourinary conditions in male offspring. Environ Health Perspect. Jul. 2009;117(7):1175-9. X-2, X-3. [pmid: 19654930].
2163 Smalley SR, Evans RG, Richardson RL, et al. Radiotherapy as initial treatment for bulky stage II testicular seminomas. J Clin Oncol. Oct. 1985;3(10):1333-8. X-2, X-3. [pmid: 4045525].
2164 Smevik B, Klepp O. The risk of spontaneous pneumothorax in patients with osteogenic sarcoma and testicular cancer. Cancer. Apr. 15. 1982;49(8):1734-7. X-2, X-3. [pmid: 6950803].
2165 Smit M, Romijn JC, Wildhagen MF, et al. Decreased Sperm DNA Fragmentation After Surgical Varicocelectomy is Associated With Increased Pregnancy Rate. Journal of Urology. January. 2010;183(1):270-274. X-2, X-3. [pmid: 19913801].
2166 Smit M, Romijn JC, Wildhagen MF, et al. Sperm chromatin structure is associated with the quality of spermatogenesis in infertile patients. Fertility and Sterility. October. 2010;94(5):1748-1752. X-2, X-3. [pmid: 20004379].
2167 Smith GC, Powell A, Reynolds K, et al. The five year school medical--time for change. Arch Dis Child. Feb. 1990;65(2):225-7. X-3. [pmid: 2317070].
2168 Smith JA, Hutson JM, Beasley SW, et al. The relationship between cerebral palsy and cryptorchidism. J Pediatr Surg. Dec. 1989;24(12):1303-5. X-3. [pmid: 2574233].
2169 Smith JA Jr, Urry RL. Testicular histology after prolonged treatment with a gonadotropin-releasing hormone analogue. J Urol. Apr. 1985;133(4):612-4. X-2, X-3. [pmid: 3920405].
2170 Smith JF, Wayment RO, Cartwright PC, et al. Genitourinary anomalies of pediatric FG syndrome. J Urol. Aug. 2007;178(2):656-9. X-3. [pmid: 17574621].
2171 Smith NM, Byard RW, Bourne AJ. Testicular regression syndrome - A pathological study of 77 cases. Histopathology. 1991;19(3):269-272. X-2, X-3. [pmid: 1916702].
2172 Smith NM, Byard RW, Bourne AJ. Testicular regression syndrome--a pathological study of 77 cases. Histopathology. Sep. 1991;19(3):269-72. X-2, X-3. [pmid: 1916702].
2173 Snodgrass W, Chen K, Harrison C. Initial scrotal incision for unilateral nonpalpable testis. J Urol. Oct. 2004;172(4 Pt 2):1742-5. discussion 1745. X-4, X-5, X-6. [pmid: 15371803].
2174 Snodgrass WT, Yucel S, Ziada A. Scrotal exploration for unilateral nonpalpable testis. J Urol. Oct. 2007;178(4 Pt 2):1718-21. X-4, X-5, X-6. [pmid: 17707015].
2175 Snyder HM 3rd. Bilateral undescended testes. Eur J Pediatr. Suppl 2. 1993;152:S45-6. X-1, X-3. [pmid: 8101815].
2176 Soderstrom KO. Tubular hyalinization in human testis. Andrologia. Jan–Feb. 1986;18(1):97-103. X-3. [pmid: 2869720].
2177 Soito IC, Favorito LA, Costa WS, et al. Extracellular matrix remodeling in the human gubernaculum during fetal testicular descent and in cryptorchidic children. World J Urol. Aug. 2011;29(4):535-40. X-2, X-3. [pmid: 21626117].
2178 Sokal M, Peckham MJ, Hendry WF. Bilateral germ cell tumours of the testis. Br J Urol. Apr. 1980;52(2):158-62. X-2, X-3. [pmid: 6107141].
2179 Sokol RZ. Endocrinology of male infertility: Evaluation and treatment. Seminars in Reproductive Medicine. March. 2009;27(2):149-158. X-3. [pmid: 19247916].
2180 Soler C, Perez F, Pertusa J, et al. Morphological and quantitative study of multinucleated bodies appearing in rat seminiferous tubules after bilateral caput epididymectomy. International Journal of Fertility. 1992;37(4):237-243. X-2, X-3. [pmid: 1354211].
2181 Solivetti FM, Drusco A, Pizzi G, et al. Percutaneous vesiculodeferentography in the diagnosis of male infertility: A review of our results and the data reported in the literature. Journal of Ultrasound. September. 2008;11(3):102-106. X-3.
2182 Song GS, Seo JT. Changes in the scrotal temperature of subjects in a sedentary posture over a heated floor. Int J Androl. Aug. 2006;29(4):446-57. X-2, X-3. [pmid: 16893399].
2183 Song NH, Wu HF, Zhang W, et al. Screening for Y chromosome microdeletions in idiopathic and nonidiopathic infertile men with varicocele and cryptorchidism. Chin Med J (Engl). Sep. 5. 2005;118(17):1462-7. X-2, X-3. [pmid: 16157049].
2184 Sonke GS, Chang S, Strom SS, et al. Prenatal and perinatal risk factors and testicular cancer: a hospital-based case-control study. Oncol Res. 2007;16(8):383-7. X-2, X-3. [pmid: 17913046].
2185 Sonksen J, Ohl DA, Giwercman A, et al. Effect of repeated ejaculation on semen quality in spinal cord injured men. J Urol. Apr. 1999;161(4):1163-5. X-2, X-3. [pmid: 10081861].
2186 Sonne SB, Hoei-Hansen CE, Fisher JS, et al. Do environmental factors play a role in the aetiology of carcinoma in situ testis and the testicular dysgenesis syndrome?. Verh Dtsch Ges Pathol. 2004;88:144-51. X-2, X-3. [pmid: 16892545].
2187 Sonneveld DJ, Schraffordt Koops H, Sleijfer DT, et al. Bilateral testicular germ cell tumours in patients with initial stage I disease: prevalence and prognosis--a single centre’s 30 years’ experience. Eur J Cancer. Aug. 1998;34(9):1363-7. X-2, X-3. [pmid: 9849418].
2188 Soosay GN, Bobrow L, Happerfield L, et al. Morphology and immunohistochemistry of carcinoma in situ adjacent to testicular germ cell tumours in adults and children: implications for histogenesis. Histopathology. Dec. 1991;19(6):537-44. X-2, X-3. [pmid: 1723958].
2189 Sorber M, Feitz WF, de Vries JD. Short- and mid-term outcome of different types of one-stage hypospadias corrections. Eur Urol. 1997;32(4):475-9. X-3. [pmid: 9412809].
2190 Sorensen MD, Galansky SH, Striegl AM, et al. Perinatal extravaginal torsion of the testis in the first month of life is a salvageable event. Urology. 01. Jul. 2003;62(1):132-134. X-2, X-3. [pmid: 12837441].
2191 Sousa A, Gayoso R, Lopez-Bellido D, et al. Laparoscopic assessment and orchidectomy for the adult undescended testis. Surg Laparosc Endosc Percutan Tech. Dec. 2000;10(6):420-2. X-2. [pmid: 11147924].
2192 Sousa AP, Tavares RS, Velez de la Calle JF, et al. Dual use of Diff-Quik-like stains for the simultaneous evaluation of human sperm morphology and chromatin status. Hum Reprod. Jan. 2009;24(1):28-36. X-2, X-3. [pmid: 18835873].
2193 Soyer T, Tosun A, Aydin G, et al. Evaluation of genitofemoral nerve motor conduction in inguinoscrotal pathologies. J Pediatr Surg. Aug. 2008;43(8):1540-2. X-3. [pmid: 18675649].
2194 Sparnon A, Guiney EJ, Puri P. The vanishing testis. Pediatric Surgery International. [Journal]. 1986;1(4):227-228. X-3, X-4, X-5, X-6.
2195 Spermon JR, Kiemeney LA, Meuleman EJ, et al. Fertility in men with testicular germ cell tumors. Fertil Steril. Jun. 2003;79(Suppl 3):1543-9. X-2, X-3. [pmid: 12801557].
2196 Spires SE, Woolums CS, Pulito AR, et al. Testicular regression syndrome: a clinical and pathologic study of 11 cases. Arch Pathol Lab Med. May. 2000;124(5):694-8. X-2, X-3. [pmid: 10782149].
2197 Spitz MR, Sider JG, Pollack ES, et al. Incidence and descriptive features of testicular cancer among United States whites, blacks, and Hispanics, 1973–1982. Cancer. Oct. 15. 1986;58(8):1785-90. X-2, X-3. [pmid: 2875786].
2198 Spivak H, Nudelman I, Fuco V, et al. Laparoscopic extraperitoneal inguinal hernia repair with spinal anesthesia and nitrous oxide insufflation. Surg Endosc. Oct. 1999;13(10):1026-9. X-2, X-3. [pmid: 10526041].
2199 Springer A, Huber C, Reck CA, et al. Delayed referral despite appropriate knowledge in cryptorchidism as a cause of delayed orchidopexies in Austria. Klin Padiatr. Jul. 2010;222(4):248-51. X-3. [pmid: 20464649].
2200 Srikanth MS, West BR, Ishitani M, et al. Benign testicular tumors in children with congenital adrenal hyperplasia. J Pediatr Surg. May. 1992;27(5):639-41. X-2, X-3. [pmid: 1320675].
2201 Sripada S, Amezaga MR, Hamilton M, et al. Absence of chlamydial deoxyribonucleic acid from testicular and epididymal samples from men with obstructive azoospermia. Fertil Steril. Feb. 2010;93(3):833-6. X-2, X-3. [pmid: 19111293].
2202 Sripathi V. Laparoscopy in pediatric practice. Indian Journal of Practical Pediatrics. Jul. 2004;6(3):243-248. X-1, X-2, X-3.
2203 Srivastava A, Raghavendran M, Jain M, et al. Fine-needle aspiration cytology of the testis: can it be a single diagnostic modality in azoospermia?. Urol Int. 2004;73(1):23-7. X-2, X-3. [pmid: 15263788].
2204 Stahl PJ, Mielnik A, Schlegel PN, et al. Heat shock factor y chromosome (HSFY) mRNA level predicts the presence of retrievable testicular sperm in men with nonobstructive azoospermia. Fertility and Sterility. August. 2011;96(2):303-308. X-2, X-3. [pmid: 21676392].
2205 Stang A, Ahrens W, Bromen K, et al. Undescended testis and the risk of testicular cancer: importance of source and classification of exposure information. Int J Epidemiol. Oct. 2001;30(5):1050-6. X-2, X-3. [pmid: 11689521].
2206 Stang A, Jockel KH, Baumgardt-Elms C, et al. Firefighting and risk of testicular cancer: results from a German population-based case-control study. Am J Ind Med. Mar. 2003;43(3):291-4. X-2, X-3. [pmid: 12594776].
2207 Stanley MW, Powers CN, Pitman MB, et al. Cytology of germ cell tumors: extragonadal, extracranial masses and intraoperative problems. Cancer. Aug. 25. 1997;81(4):220-7. X-2, X-3. [pmid: 9292737].
2208 Stanley P. Computed tomographic evaluation of the retroperitoneum in infants and children. J Comput Tomogr. Feb. 1983;7(1):63-75. X-3. [pmid: 6133700].
2209 Steckel J, Dicker AP, Goldstein M. Relationship between varicocele size and response to varicocelectomy. J Urol. Apr. 1993;149(4):769-71. X-2, X-3. [pmid: 8455240].
2210 Steigman CK, Sotelo-Avila C, Weber TR. The incidence of spermatic cord structures in inguinal hernia sacs from male children. American Journal of Surgical Pathology. Aug. 1999;23(8):880-885. X-2, X-3. [pmid: 10435556].
2211 Steinbach P, Wolf M, Schmidt H. Multiple congenital anomalies/mental retardation (MCA/MR) syndrome due to interstitial deletion 1q. Am J Med Genet. Sep. 1984;19(1):131-6. X-2, X-3. [pmid: 6496565].
2212 Steinbrecher HA, Malone PS. Testicular problems in children. Paediatrics and Child Health. Jun. 2008;18(6):264-267. X-1, X-2, X-3.
2213 Steiner H, Holtl L, Maneschg C, et al. Frozen section analysis-guided organ-sparing approach in testicular tumors: technique, feasibility, and long-term results. Urology. Sep. 2003;62(3):508-13. X-2, X-3. [pmid: 12946756].
2214 Steiner H, Muller T, Gozzi C, et al. Two cycles of cisplatin-based chemotherapy for low-volume retroperitoneal stage II nonseminomatous germ cell tumours. BJU International. Aug. 2006;98(2):349-352. X-3, X-4, X-5, X-6. [pmid: 16626306].
2215 Steiner H, Peschel R, Bartsch G. Retroperitoneal lymph node dissection after chemotherapy for germ cell tumours: Is a full bilateral template always necessary?. BJU International. August. 2008;102(3):310-314. X-2, X-3. [pmid: 18325053].
2216 Steiner H, Zangerl F, Stohr B, et al. Results of bilateral nerve sparing laparoscopic retroperitoneal lymph node dissection for testicular cancer. J Urol. Oct. 2008;180(4):1348-52. discussion 1352–3. X-2, X-3. [pmid: 18707723].
2217 Steinmetz L, Rocha MN, Longui CA, et al. Inhibin A production after gonadotropin stimulus: a new method to detect ovarian tissue in ovotesticular disorder of sex development. Horm Res. 2009;71(2):94-9. X-3. [pmid: 19129714].
2218 Steven M, Greene O, Nelson A, et al. Contralateral inguinal exploration in premature neonates: Is it necessary?. Pediatric Surgery International. July. 2010;26(7):703-706. X-2, X-3. [pmid: 20454795].
2219 Stewart RJ, Boyd S, Brown S, et al. The blood-testis barrier in experimental unilateral cryptorchidism. J Pathol. Jan. 1990;160(1):51-5. X-2, X-3. [pmid: 1968969].
2220 Steyerberg EW, Keizer HJ, Messemer JE, et al. Residual pulmonary masses after chemotherapy for metastatic nonseminomatous germ cell tumor. Prediction of histology. ReHiT Study Group. Cancer. Jan. 15. 1997;79(2):345-55. X-2, X-3. [pmid: 9010108].
2221 Stikkelbroeck NM, Otten BJ, Pasic A, et al. High prevalence of testicular adrenal rest tumors, impaired spermatogenesis, and Leydig cell failure in adolescent and adult males with congenital adrenal hyperplasia. J Clin Endocrinol Metab. Dec. 2001;86(12):5721-8. X-2, X-3. [pmid: 11739428].
2222 Stikkelbroeck NM, Suliman HM, Otten BJ, et al. Testicular adrenal rest tumours in postpubertal males with congenital adrenal hyperplasia: sonographic and MR features. Eur Radiol. Jul. 2003;13(7):1597-603. X-2, X-3. [pmid: 12835972].
2223 Stipoljev F, Vujisic S, Parazajder J, et al. Cytogenetic analysis of azoospermic patients: karyotype comparison of peripheral blood lymphocytes and testicular tissue. Eur J Obstet Gynecol Reprod Biol. Feb. 1. 2006;124(2):197-203. X-2, X-3. [pmid: 16157443].
2224 Stoehr B, Zangerl F, Steiner E, et al. Routine scrotal ultrasonography during the follow-up of patients with testicular cancer leads to earlier detection of asynchronous tumours and a high rate of organ preservation. BJU International. April. 2010;105(8):1118-1120. X-2, X-3. [pmid: 19793379].
2225 Stone JM, Cruickshank DG, Sandeman TF, et al. Laterality, maldescent, trauma and other clinical factors in the epidemiology of testis cancer in Victoria, Australia. Br J Cancer. Jul. 1991;64(1):132-8. X-2, X-3. [pmid: 1677257].
2226 Storm D, Redden T, Aguiar M, et al. Histologic evaluation of the testicular remnant associated with the vanishing testes syndrome: is surgical management necessary?. Urology. Dec. 2007;70(6):1204-6. X-2, X-3. [pmid: 18158048].
2227 Storm DW, Baxter C, Koff SA, et al. The relationship between obesity and complications after neonatal circumcision. J Urol. Oct. 2011;186(4 Suppl):1638-41. X-2, X-3. [pmid: 21862040].
2228 Strader CH, Weiss NS, Daling JR. Vasectomy and the incidence of testicular cancer. Am J Epidemiol. Jul. 1988;128(1):56-63. X-2, X-3. [pmid: 2837898].
2229 Strader CH, Weiss NS, Daling JR, et al. Cryptorchism, orchiopexy, and the risk of testicular cancer. Am J Epidemiol. May. 1988;127(5):1013-8. X-2, X-3. [pmid: 2895979].
2230 Strandberg-Larsen K, Jensen MS, Ramlau-Hansen CH, et al. Alcohol binge drinking during pregnancy and cryptorchidism. Hum Reprod. Dec. 2009;24(12):3211-9. X-3. [pmid: 19767622].
2231 Stratakis CA, Papageorgiou T, Premkumar A, et al. Ovarian lesions in Carney complex: clinical genetics and possible predisposition to malignancy. J Clin Endocrinol Metab. Nov. 2000;85(11):4359-66. X-2, X-3. [pmid: 11095480].
2232 Strom KH, Levine LA. Microsurgical denervation of the spermatic cord for chronic orchialgia: long-term results from a single center. J Urol. Sep. 2008;180(3):949-53. X-2, X-3. [pmid: 18639271].
2233 Sucullu I, Filiz AI, Sen B, et al. The effects of inguinal hernia repair on testicular function in young adults: a prospective randomized study. Hernia. Apr. 2010;14(2):165-9. X-2, X-3. [pmid: 19937077].
2234 Suga K, Ariyoshi I, Nakanishi T, et al. Clinical study of varicocele by sequential scrotal scintigraphy. Andrologia. Nov–Dec. 1990;22(6):525-9. X-2, X-3. [pmid: 2099671].
2235 Sujansky E, Smith AC, Peakman DC, et al. Familial pericentric inversion of chromosome 8. Am J Med Genet. 1981;10(3):229-35. X-2, X-3. [pmid: 6171164].
2236 Sukhotnik I, Bernshteyn A, Mogilner JG. The basic biology of apoptosis and its implications for pediatric surgery. European Journal of Pediatric Surgery. Aug. 2005;15(4):229-235. X-1, X-2, X-3. [pmid: 16163587].
2237 Sullivan JG, Gohel M, Kinder RB. Ectopic adrenocortical tissue found at groin exploration in children: incidence in relation to diagnosis, age and sex. BJU Int. Feb. 2005;95(3):407-10. X-3. [pmid: 15679804].
2238 Sultan Sheriff D. Further studies on testicular lipids and glycogen in human patients with unilateral varicocele. Andrologia. Sep–Oct. 1984;16(5):442-5. X-2, X-3. [pmid: 6496964].
2239 Sun N, Cheung TT, Khong PL, et al. Varicocele: Laparoscopic clipping and color Doppler follow-up. J Pediatr Surg. Nov. 2001;36(11):1704-7. X-2, X-3. [pmid: 11685706].
2240 Surana R, Puri P. Is contralateral exploration necessary in infants with unilateral inguinal hernia?. J Pediatr Surg. Aug. 1993;28(8):1026-7. X-2, X-3. [pmid: 8229590].
2241 Surana R, Puri P. Iatrogenic ascent of the testis: an under-recognized complication of inguinal hernia operation in children. Br J Urol. May. 1994;73(5):580-1. X-2, X-3. [pmid: 7912159].
2242 Suskind A, Hayner-Buchan A, Feustel PJ, et al. Fibrosis correlates with detailed histological analysis of human undescended testes. BJU Int. Jun. 2008;101(11):1441-5. X-4, X-5, X-6. [pmid: 18218059].
2243 Sussi PL, Azzolina LS, Erbici L, et al. Heterogeneous distribution of nuclear DNA content in tumors of the adrenal glands. Journal of Experimental and Clinical Cancer Research. Jun. 1996;15(2):115-121. X-2, X-3.
2244 Sutcliffe JR, Wilson-Storey D, Smith NM. Ante-natal testicular torsion: only one cause of the testicular regression syndrome?. J R Coll Surg Edinb. Apr. 1996;41(2):99-101. X-2, X-3. [pmid: 8632401].
2245 Sutherland RS, Kogan BA. Therapeutic laparoscopy for the nonpalpable testicle. Tech Urol. Fall. 1996;2(3):142-6. X-4, X-5, X-6. [pmid: 9118422].
2246 Suzuki Y, Sasagawa I, Ashida J, et al. Screening for mutations of the androgen receptor gene in patients with isolated cryptorchidism. Fertil Steril. Oct. 2001;76(4):834-6. X-2, X-3. [pmid: 11591424].
2247 Suzuki Y, Sasagawa I, Itoh K, et al. 5Alpha-reductase type 2 genes in Japanese males do not appear to be associated with cryptorchidism. Fertil Steril. Aug. 2002;78(2):330-4. X-2, X-3. [pmid: 12137870].
2248 Suzuki Y, Sasagawa I, Tateno T, et al. Absence of microdeletions in the Y chromosome in patients with Prader-Willi syndrome with cryptorchidism. Int J Androl. Feb. 2002;25(1):1-5. X-3. [pmid: 11869370].
2249 Swartz MA, Morgan TM, Krieger JN. Complications of Scrotal Surgery for Benign Conditions. Urology. Apr. 2007;69(4):616-619. X-3. [pmid: 17445635].
2250 Swerdlow AJ, De Stavola BL, Swanwick MA, et al. Risk factors for testicular cancer: a case-control study in twins. Br J Cancer. Jun. 1999;80(7):1098-102. X-2, X-3. [pmid: 10362123].
2251 Swerdlow AJ, Huttly SR, Smith PG. Testicular cancer and antecedent diseases. Br J Cancer. Jan. 1987;55(1):97-103. X-2, X-3. [pmid: 2880604].
2252 Swerdlow AJ, Huttly SR, Smith PG. Is the incidence of testis cancer related to trauma or temperature?. Br J Urol. Jun. 1988;61(6):518-21. X-2, X-3. [pmid: 3401662].
2253 Swerdlow AJ, Melzer D. The value of England and Wales congenital malformation notification scheme data for epidemiology: male genital tract malformations. J Epidemiol Community Health. Mar. 1988;42(1):8-13. X-3. [pmid: 2901455].
2254 Swerdlow AJ, Wood KH, Smith PG. A case-control study of the aetiology of cryptorchidism. J Epidemiol Community Health. Sep. 1983;37(3):238-44. X-3. [pmid: 6137506].
2255 Sylvia S, Kakarlapudi SV, Vollala VR, et al. Bilateral variant testicular arteries with double renal arteries. Cases Journal. 2009;2(1):114. X-2, X-3. [pmid: 19187540].
2256 Szabo R, Kessler R. Hydrocele following internal spermatic vein ligation: a retrospective study and review of the literature. J Urol. Nov. 1984;132(5):924-5. X-2, X-3. [pmid: 6492283].
2257 Szczerba K, Kulhawik J, Wylezek D, et al. Shouldice’s primary inguinal hernia repair - 5-Year results. [Polish, English]. Polski Przeglad Chirurgiczny. 2002;74(12):1157-1162. X-2, X-3.
2258 Szpinda M, Frackiewicz P, Flisinski P, et al. The retroperitoneal anastomoses of the gonadal veins in human foetuses. Folia Morphol (Warsz). May. 2005;64(2):72-7. X-2, X-3. [pmid: 16121322].
2259 Tackett LD, Patel SR, Caldamone AA. A history of cryptorchidism: Lessons from the eighteenth century. Journal of Pediatric Urology. Dec. 2007;3(6):426-432. X-1, X-2, X-3. [pmid: 18947789].
2260 Tackett LD, Wacksman J, Billmire D, et al. The high intra-abdominal testis: technique and long-term success of laparoscopic testicular autotransplantation. J Endourol. Aug. 2002;16(6):359-61. X-4, X-5, X-6. [pmid: 12227909].
2261 Taha SA. Male pseudohermaphroditism: factors determining the gender of rearing in Saudi Arabia. Urology. Mar. 1994;43(3):370-4. X-3. [pmid: 8134993].
2262 Tajima Y, Watanabe D, Koshimizu U, et al. Insulin-like growth factor-I and transforming growth factor-alpha stimulate differentiation of type A spermatogonia in organ culture of adult mouse cryptorchid testes. Int J Androl. Feb. 1995;18(1):8-12. X-2, X-3. [pmid: 7782132].
2263 Takahashi M, Kurokawa Y, Nakanishi R, et al. Low transscrotal orchidopexy is a safe and effective approach for undescended testes distal to the external inguinal ring. Urol Int. 2009;82(1):92-6. X-4, X-5, X-6. [pmid: 19172105].
2264 Takano T, Matsuwake K, Yoshioka S, et al. Congenital polymicrogyria including the perisylvian region in early childhood. Congenital Anomalies. March. 2010;50(1):64-67. X-2, X-3. [pmid: 20201970].
2265 Takehara H, Yakabe S, Kameoka K. Laparoscopic percutaneous extraperitoneal closure for inguinal hernia in children: clinical outcome of 972 repairs done in 3 pediatric surgical institutions. J Pediatr Surg. Dec. 2006;41(12):1999-2003. X-2, X-3. [pmid: 17161191].
2266 Takihara H, Baba Y, Ishizu K, et al. Testicular development following unilateral orchiopexy measured by a new orchiometer. Urology. Oct. 1990;36(4):370-2. X-4, X-5, X-6. [pmid: 1977231].
2267 Tal R, Holland R, Belenky A, et al. Incidental testicular tumors in infertile men. Fertil Steril. Aug. 2004;82(2):469-71. X-2, X-3. [pmid: 15302304].
2268 Talati J, Sheikh H. Sertoli cell only syndrome (SECOS): lessons from case studies. J Pak Med Assoc. Sep. 1991;41(9):219-23. X-2, X-3. [pmid: 1744970].
2269 Tallen G, Hernaiz Driever P, Degenhardt P, et al. High reliability of scrotal ultrasonography in the management of childhood primary testicular neoplasms. Klin Padiatr. May. 2011;223(3):131-7. X-2, X-3. [pmid: 21462100].
2270 Tam YH, Lee KH, Sihoe JD, et al. Laparoscopic hernia repair in children by the hook method: a single-center series of 433 consecutive patients. J Pediatr Surg. Aug. 2009;44(8):1502-5. X-2, X-3. [pmid: 19635295].
2271 Tamhne RC, Jarvis SN, Waterston AJ. Auditing community screening for undescended testes. Arch Dis Child. Aug. 1990;65(8):888-90. X-3. [pmid: 1976004].
2272 Tan TW, Lee KM, Chua EJ. Testicular seminoma--the results of treatment by radiotherapy in Singapore. Ann Acad Med Singapore. May. 1996;25(3):363-6. X-2, X-3. [pmid: 8876902].
2273 Tan TWK, Lee KM, Chua EJ. Testicular seminoma - The results of treatment by radiotherapy in Singapore. Annals of the Academy of Medicine Singapore. May. 1996;25(3):363-366. X-2, X-3.
2274 Tanaka H, Fujisawa M, Okada H, et al. Apoptosis-related proteins in the testes of infertile men with varicocele. BJU Int. Jun. 2002;89(9):905-9. X-2, X-3. [pmid: 12010237].
2275 Tanaka T, Kitamura H, Kunishima Y, et al. Modified and bilateral retroperitoneal lymph node dissection for testicular cancer: peri- and postoperative complications and therapeutic outcome. Jpn J Clin Oncol. Jun. 2006;36(6):381-6. X-2, X-3. [pmid: 16762970].
2276 Tanaka Y, Mizote H, Asakawa T, et al. Clinical significance of plasma diamine oxidase activity in pediatric patients: influence of nutritional therapy and chemotherapy. Kurume Med J. 2003;50(3–4):131-7. X-3. [pmid: 14768475].
2277 Tannour-Louet M, Han S, Corbett ST, et al. Identification of de novo copy number variants associated with human disorders of sexual development. PLoS One. 2010;5(10):e15392. X-3. [pmid: 21048976].
2278 Tanyel FC, Dagdeviren A, Muftuoglu S, et al. Inguinal hernia revisited through comparative evaluation of peritoneum, processus vaginalis, and sacs obtained from children with hernia, hydrocele, and undescended testis. J Pediatr Surg. Apr. 1999;34(4):552-5. X-3. [pmid: 10235320].
2279 Tanyel FC, Erdem S, Altunay H, et al. Distribution and morphometry of fiber types in cremaster muscles of boys with inguinal hernia or undescended testis. Pathol Res Pract. 2000;196(9):613-7. X-2, X-3. [pmid: 10997735].
2280 Tanyel FC, Erdem S, Buyukpamukcu N, et al. Cremaster muscles obtained from boys with an undescended testis show significant neurological changes. BJU Int. Jan. 2000;85(1):116-9. X-3. [pmid: 10619958].
2281 Tanyel FC, Erdem S, Buyukpamukcu N, et al. Cremaster muscle is not sexually dimorphic, but that from boys with undescended testis reflects alterations related to autonomic innervation. J Pediatr Surg. Jun. 2001;36(6):877-80. X-3. [pmid: 11381416].
2282 Tanyel FC, Erdem S, Buyukpamukcu N, et al. Smooth muscle within incomplete obliterations of processus vaginalis lacks apoptotic nuclei. Urol Int. 2002;69(1):42-5. X-3. [pmid: 12119438].
2283 Tanyel FC, Muftuoglu S, Dagdeviren A, et al. Ultrastructural deficiency in autonomic innervation in cremasteric muscle of boys with undescended testis. J Pediatr Surg. Apr. 2001;36(4):573-8. X-3. [pmid: 11283880].
2284 Tanyel FC, Ocal T, Karaagaoglu E, et al. Individual and associated effects of length of inguinal canal and caliber of the sac on clinical outcome in children. J Pediatr Surg. Aug. 2000;35(8):1165-9. X-3. [pmid: 10945687].
2285 Tanyel FC, Okur HD. Autonomic nervous system appears to play a role in obliteration of processus vaginalis. Hernia. May. 2004;8(2):149-54. X-3. [pmid: 14730435].
2286 Tanyel FC, Sara Y, Ertunc M, et al. Lack of carbachol response indicates the absence of cholinergic receptors in sacs associated with undescended testis. J Pediatr Surg. Sep. 1999;34(9):1339-44. X-3. [pmid: 10507425].
2287 Tanyel FC, Talim B, Atilla P, et al. Myogenesis within the human gubernaculum: histological and immunohistochemical evaluation. Eur J Pediatr Surg. Jun. 2005;15(3):175-9. X-2, X-3. [pmid: 15999310].
2288 Tanyel FC, Talim B, Kale G, et al. Differences in the morphology of the processus vaginalis with sex and underlying disease condition. Pathol Res Pract. 2000;196(11):767-70. X-2, X-3. [pmid: 11186172].
2289 Tanyel FC, Yuzbasioglu A, Kocaefe C, et al. Androgen receptor immunostaining and androgen receptor messenger ribonucleic acid expression are increased in cremaster muscles associated with undescended testis. Urology. Apr. 2006;67(4):855-8. X-3, X-9. [pmid: 16566985].
2290 Tarantino L, Giorgio A, de Stefano G, et al. Echo color Doppler findings in postpubertal mumps epididymo-orchitis. J Ultrasound Med. Nov. 2001;20(11):1189-95. X-2, X-3. [pmid: 11758024].
2291 Tartaglia M, Gelb BD, Zenker M. Noonan syndrome and clinically related disorders. Best Practice and Research: Clinical Endocrinology and Metabolism. February. 2011;25(1):161-179. X-1, X-2, X-3. [pmid: 21396583].
2292 Tartaglia N, Davis S, Hench A, et al. A new look at XXYY syndrome: medical and psychological features. Am J Med Genet A. Jun. 15. 2008;146A(12):1509-22. X-3. [pmid: 18481271].
2293 Tartar VM, Trambert MA, Balsara ZN, et al. Tubular ectasia of the testicle: sonographic and MR imaging appearance. AJR Am J Roentgenol. Mar. 1993;160(3):539-42. X-2, X-3. [pmid: 8430548].
2294 Tasian GE, Hittelman AB, Kim GE, et al. Age at orchiopexy and testis palpability predict germ and Leydig cell loss: clinical predictors of adverse histological features of cryptorchidism. J Urol. Aug. 2009;182(2):704-9. X-3, X-4, X-5, X-6. [pmid: 19539332].
2295 Tasian GE, Yiee JH, Copp HL. Imaging use and cryptorchidism: determinants of practice patterns. J Urol. May. 2011;185(5):1882-7. X-2. [pmid: 21421239].
2296 Tasian GE, Zaid H, Cabana MD, et al. Proximal hypospadias and risk of acquired cryptorchidism. J Urol. Aug. 2010;184(2):715-20. X-3. [pmid: 20639045].
2297 Taskinen S, Fagerholm R, Aronniemi J, et al. Testicular tumors in children and adolescents. J Pediatr Urol. Apr. 2008;4(2):134-7. X-2, X-3. [pmid: 18631909].
2298 Taskinen S, Lehtinen A, Hovatta O, et al. Ultrasonography and colour Doppler flow in the testes of adult patients after treatment of cryptorchidism. Br J Urol. Aug. 1996;78(2):248-51. X-4, X-5, X-6. [pmid: 8813922].
2299 Taskinen S, Taavitsainen M, Wikstrom S. Measurement of testicular volume: comparison of 3 different methods. J Urol. Mar. 1996;155(3):930-3. X-3, X-4, X-5, X-6. [pmid: 8583610].
2300 Taskinen S, Wikstrom S. Growth patterns in young men treated for undescended testes in childhood. Pediatr Surg Int. May. 2004;20(5):360-2. X-3, X-4, X-5, X-6. [pmid: 15138788].
2301 Tauber M, Barbeau C, Jouret B, et al. Auxological and endocrine evolution of 28 children with Prader-Willi syndrome: effect of GH therapy in 14 children. Horm Res. 2000;53(6):279-87. X-3. [pmid: 11146368].
2302 Taurog JD, Rival C, Dorris M, et al. Arthritis and Rheumatism. [Conference Abstract]. Conference: American College of Rheumatology/Association of Rheumatology Health Professionals Annual Scientific Meeting, ACR/ARHP 10. Philadelphia, PA United States. Conference Start: 20091016 Conference End: 20091021. Conference Publication: (var.pagings). 2010;62:1448. X-2, X-3.
2303 Taurog JD, Satumtira N, Dorris ML. Arthritis and Rheumatism. [Conference Abstract]. Conference: American College of Rheumatology/Association of Rheumatology Health Professionals Annual Scientific Meeting, ACR/ARHP 09. Atlanta, GA United States. Conference Start: 20101106 Conference End: 20101111. Conference Publication: (var.pagings). 2009;60:1168. X-2, X-3, X-9.
2304 Tavolini IM, Bettella A, Boscolo Berto R, et al. Immunostaining for placental alkaline phosphatase on fine-needle aspiration specimens to detect noninvasive testicular cancer: a prospective evaluation in cryptorchid men. BJU Int. May. 2006;97(5):950-4. X-3, X-4, X-5, X-6. [pmid: 16643476].
2305 Taye K, Bedru A. Pattern of neural tube defects at Tikur Anbessa Hospital, Addis Ababa, Ethiopia. Ethiop Med J. Jan. 2009;47(1):71-6. X-3. [pmid: 19743784].
2306 Taylor SG, Hair A, Baxter GM, et al. Does contraction of mesh following tension free hernioplasty effect testicular or femoral vessel blood flow?. Hernia. Mar. 2001;5(1):13-5. X-2, X-3. [pmid: 11387716].
2307 Taylor WN. Urological implications of the beckwith-wiedemann syndrome. J Urol. Mar. 1981;125(3):439-41. X-3. [pmid: 6110787].
2308 Tchovelidze C, Sibony M, Callard P, et al. The testicular biopsy and spermatogenesis disturbance of infertile patients with bilateral varicocele. Arkh Patol. Mar–Apr. 2004;66(2):40-5. X-2, X-3. [pmid: 15154383].
2309 Teebi AS, Rucquoi JK, Meyn MS. Aarskog syndrome: Report of a family with review and discussion of nosology. American Journal of Medical Genetics. 1993;46(5):501-509. X-2, X-3. [pmid: 8322809].
2310 Tekin A, Aygun YC, Aki FT, et al. Bilateral germ cell cancer of the testis: a report of 11 patients with a long-term follow-up. BJU Int. May. 2000;85(7):864-8. X-2, X-3. [pmid: 10792167].
2311 Termine C, Parigi G, Rossi M, et al. WAGR syndrome: is the ‘R’ always justified?. Clin Dysmorphol. Jan. 2007;16(1):69-70. X-3. [pmid: 17159522].
2312 Ternavasio-De La, Vega HG, Boronat M, Ojeda A, et al. Mumps orchitis in the post-vaccine era (1967–2009) a single-center series of 67 patients and review of clinical outcome and trends. Medicine. March. 2010;89(2):96-116. X-2, X-3. [pmid: 20517181].
2313 Terquem A, Dadoune JP. Morphological findings in varicocele: an ultrastructural study of 30 bilateral testicular biopsies. Int J Androl. Oct. 1981;4(5):515-31. X-2, X-3. [pmid: 7319642].
2314 Testini M, Miniello S, Piccinni G, et al. Microsurgical treatment of varicocele in outpatients using the subinguinal approach. Minerva Chir. Dec. 2001;56(6):655-9. X-2, X-3. [pmid: 11721208].
2315 Tetik C, Arregui ME, Dulucq JL, et al. Complications and recurrences associated with laparoscopic repair of groin hernias. A multi-institutional retrospective analysis. Surg Endosc. Nov. 1994;8(11):1316-22. discussion 1322–3. X-2, X-3. [pmid: 7831605].
2316 Theodore C, Terrier-Lacombe MJ, Laplanche A, et al. Bilateral germ-cell tumours: 22-year experience at the Institut Gustave Roussy. Br J Cancer. Jan. 12. 2004;90(1):55-9. X-2, X-3. [pmid: 14710206].
2317 Thijssens K, Vaneerdeweg W, Schrijvers D, et al. Retroperitoneal lymph node dissection as adjuvant therapy in the treatment of non-seminomatous testicular cancer. Acta Chir Belg. Nov–Dec. 2003;103(6):599-602. X-2, X-3. [pmid: 14743567].
2318 Thomas DB, Jimenez LM, McTiernan A, et al. Breast cancer in men: risk factors with hormonal implications. Am J Epidemiol. Apr. 1. 1992;135(7):734-48. X-2, X-3. [pmid: 1350708].
2319 Thomas GM, Rider WD, Dembo AJ, et al. Seminoma of the testis: results of treatment and patterns of failure after radiation therapy. Int J Radiat Oncol Biol Phys. Feb. 1982;8(2):165-74. X-2, X-3. [pmid: 7085374].
2320 Thomas JC, Elder JS. Testicular growth arrest and adolescent varicocele: does varicocele size make a difference?. J Urol. Oct. 2002;168(4 Pt 2):1689-91. discussion 1691. X-2, X-3. [pmid: 12352335].
2321 Thomas K, Wood SJ, Thompson AJ, et al. The incidence and significance of testicular microlithiasis in a subfertile population. Br J Radiol. May. 2000;73(869):494-7. X-2, X-3. [pmid: 10884745].
2322 Thomas WE, Cooper MJ, Crane GA, et al. Testicular exocrine malfunction after torsion. Lancet. Dec. 15. 1984;2(8416):1357-60. X-2, X-3. [pmid: 6150364].
2323 Thompson J, Williams CJ, Whitehouse JM, et al. Bilateral testicular germ cell tumours: an increasing incidence and prevention by chemotherapy. Br J Urol. Oct. 1988;62(4):374-6. X-2, X-3. [pmid: 2847848].
2324 Thong M, Lim C, Fatimah H. Undescended testes: incidence in 1,002 consecutive male infants and outcome at 1 year of age. Pediatr Surg Int. Jan. 1998;13(1):37-41. X-3, X-4, X-5, X-6. [pmid: 9391202].
2325 Thornhill JA, Conroy RM, Kelly DG, et al. An evaluation of predisposing factors for testis cancer in Ireland. Eur Urol. 1988;14(6):429-33. X-2, X-3. [pmid: 2903056].
2326 Thorup J, Cortes D, Petersen BL. The incidence of bilateral cryptorchidism is increased and the fertility potential is reduced in sons born to mothers who have smoked during pregnancy. J Urol. Aug. 2006;176(2):734-7. X-3, X-4, X-5, X-6. [pmid: 16813933].
2327 Thorup J, Jensen CL, Langballe O, et al. The challenge of early surgery for cryptorchidism. Scandinavian Journal of Urology and Nephrology. April. 2011;45(3):184-189. X-4, X-5, X-6. [pmid: 21244213].
2328 Thorup JM, Cortes D, Visfeldt J. Germ cells may survive clipping and division of the spermatic vessels in surgery for intra-abdominal testes. J Urol. Sep. 1999;162(3 Pt 1):872-4. X-4, X-5, X-6. [pmid: 10458398].
2329 Tiemstra JD, Kapoor S. Evaluation of scrotal masses. Am Fam Physician. Nov. 15. 2008;78(10):1165-70. X-1, X-2, X-3. [pmid: 19035065].
2330 Timmermann G, Acs N, Banhidy F, et al. Congenital abnormalities of 88 children born to mothers who attempted suicide with phenobarbital during pregnany: the use of a disaster epidemiological model for the evaluation of drug teratogenicity. Pharmacoepidemiol Drug Saf. Sep. 2009;18(9):815-25. X-2, X-3. [pmid: 19551756].
2331 Tiwary CM. Testicular injury in breech delivery: possible implications. Urology. Oct. 1989;34(4):210-2. X-3. [pmid: 2800086].
2332 Toledano MB, Hansell AL, Jarup L, et al. Temporal trends in orchidopexy, Great Britain, 1992–1998. Environ Health Perspect. Jan. 2003;111(1):129-32. X-4, X-5, X-6. [pmid: 12515691].
2333 Tollerud DJ, Blattner WA, Fraser MC, et al. Familial testicular cancer and urogenital developmental anomalies. Cancer. Apr. 15. 1985;55(8):1849-54. X-2, X-3. [pmid: 2858262].
2334 Tomamichel GR, Bandhauer K. Seminal carnitine content in obstructive azoospermia. Correlation with the anatomic level of obstruction. J Androl. Sep–Oct. 1986;7(5):328-30. X-2, X-3. [pmid: 3771371].
2335 Tomita E, Kondo T, Nakazawa H, et al. Successful testis preservation for bilateral testicular tumors with a new chemotherapy-based protocol: initial results of three cases. Int J Urol. Sep. 2007;14(9):879-82. X-2, X-3. [pmid: 17760764].
2336 Tomita M. Consecutive administrative of synthetic LRH in the evaluation of gonadotrophin reserve in children. Acta Endocrinol (Copenh). Jul. 1980;94(3):289-96. X-2, X-3. [pmid: 6106993].
2337 Tomomasa H, Oshio S, Amemiya H, et al. Testicular injury: late results of semen analyses after uniorchiectomy. Arch Androl. Jul–Aug. 1992;29(1):59-63. X-3, X-4, X-5, X-6. [pmid: 1503525].
2338 Tomomasa H, Shimizu H, Sato S, et al. Clinical study of testicular germ cell tumors. Hinyokika Kiyo. Jun. 2001;47(6):389-95. X-2, X-3. [pmid: 11496394].
2339 Toth J, Merksz M, Szonyi P. States causing infertility in adulthood in children with undescended testis. Acta Chir Hung. 1987;28(3):243-6. X-3, X-4, X-5, X-6. [pmid: 2889302].
2340 Toth L, Bodrogi I, Baki M, et al. Thoracic surgery of testicular cancer patients. Eur J Surg Oncol. Dec. 1993;19(6):609-13. X-1, X-2, X-3. [pmid: 8270052].
2341 Townsend CL, Willey BA, Cortina-Borja M, et al. Antiretroviral therapy and congenital abnormalities in infants born to HIV-infected women in the UK and Ireland, 1990–2007. Aids. 20. Feb. 2009;23(4):519-524. X-3. [pmid: 19165088].
2342 Trabert B, Sigurdson AJ, Sweeney AM, et al. Marijuana use and testicular germ cell tumors. Cancer. Feb. 15. 2011;117(4):848-53. X-2, X-3. [pmid: 20925043].
2343 Traupe H, Happle R. Clinical spectrum of steroid sulfatase deficiency: X-linked recessive ichthyosis, birth complications and cryptorchidism. European Journal of Pediatrics. 1983;140(1):19-21. X-3. [pmid: 6135610].
2344 Tres LL, Mesrobian HG, Abdullah M, et al. Human Sertoli-spermatogenic cell cocultures prepared from biopsies of cryptorchid testes performed during orchidopexy. J Urol. Apr. 1989;141(4):1003-9. X-3. [pmid: 2564441].
2345 Trifiro G, Livieri C, Bosio L, et al. Neonatal hypotonia: don’t forget the Prader-Willi syndrome. Acta Paediatr. Sep. 2003;92(9):1085-9. X-3. [pmid: 14599075].
2346 Trigg ME, Steinherz PG, Chappell R, et al. Early testicular biopsy in males with acute lymphoblastic leukemia: lack of impact on subsequent event-free survival. J Pediatr Hematol Oncol. Jan–Feb. 2000;22(1):27-33. X-2, X-3. [pmid: 10695818].
2347 Tripodi L, Tripodi A, Mammi C, et al. Pharmacological action and therapeutic effects of glutathione on hypokinetic spermatozoa for enzymatic-dependent pathologies and correlated genetic aspects. Clin Exp Obstet Gynecol. 2003;30(2–3):130-6. X-2, X-3. [pmid: 12854860].
2348 Trivin C, Gluckman E, Leblanc T, et al. Factors and markers of growth hormone secretion and gonadal function in Fanconi anemia. Growth Horm IGF Res. Apr. 2007;17(2):122-9. X-3. [pmid: 17336561].
2349 Trobs RB, Hoepffner W, Buhligen U, et al. Video-assisted gonadectomy in children with Ullrich Turner syndrome or 46,XY gonadal dysgenesis. Eur J Pediatr Surg. Jun. 2004;14(3):179-84. X-2, X-3. [pmid: 15211408].
2350 Trombetta C, Savoca G, Siracusano S, et al. Prevalence and incidence of urologic diseases before puberty. Acta Urologica Italica. 1996;10(3):209-220. X-2, X-3.
2351 Trotter C, Martin P, Youngson G, et al. A comparison between ilioinguinal-iliohypogastric nerve block performed by anaesthetist or surgeon for postoperative analgesia following groin surgery in children. Paediatr Anaesth. 1995;5(6):363-7. X-3. [pmid: 8597968].
2352 Troughton AH, Waring J, Longstaff A, et al. The role of magnetic resonance imaging in the investigation of undescended testes. Clin Radiol. Mar. 1990;41(3):178-81. X-2. [pmid: 1969786].
2353 Trump DL, Havlin KH, Messing EM, et al. High-dose ketoconazole in advanced hormone-refractory prostate cancer: endocrinologic and clinical effects. J Clin Oncol. Aug. 1989;7(8):1093-8. X-2, X-3. [pmid: 2474059].
2354 Trussell JC, Haas GP, Wojtowycz A, et al. High prevalence of bilateral varicoceles confirmed with ultrasonography. Int Urol Nephrol. 2003;35(1):115-8. X-2, X-3. [pmid: 14620299].
2355 Tsai YC, Wu CC, Yang SS. Minilaparoscopic herniorrhaphy with hernia sac transection in children and young adults: a preliminary report. Surg Endosc. Sep. 2007;21(9):1623-5. X-2, X-3. [pmid: 17353989].
2356 Tsametis C, Mintziori G, Iliadou PK, et al. International Journal of Andrology. [Conference Abstract]. October. Conference: 6th European Congress of Andrology. Athens Greece. Conference Start: 20100929 Conference End: 20101001. Conference Publication: (var.pagings). 2010;33:52. X-2.
2357 Tsatsoulis A, Shalet SM, Morris ID, et al. Immunoactive inhibin as a marker of Sertoli cell function following cytotoxic damage to the human testis. Horm Res. 1990;34(5–6):254-9. X-2, X-3. [pmid: 2129227].
2358 Tsevi I, Vicente R, Grande M, et al. KCNQ1/KCNE1 channels during germ-cell differentiation in the rat: expression associated with testis pathologies. J Cell Physiol. Feb. 2005;202(2):400-10. X-2, X-3. [pmid: 15389592].
2359 Tsuruta S, Satsumae T, Mizutani T, et al. Minimum alveolar concentrations of sevoflurane for maintaining bispectral index below 50 in children. Paediatr Anaesth. Nov. 2011;21(11):1124-7. X-2, X-3. [pmid: 21535300].
2360 Tuerlings JH, Ligtenberg MJ, Kremer JA, et al. Screening male intracytoplasmic sperm injection candidates for mutations of the follicle stimulating hormone receptor gene. Hum Reprod. Aug. 1998;13(8):2098-101. X-2, X-3. [pmid: 9756276].
2361 Tukmen M, Temocin K, Acar C, et al. Short rib-polydactyly syndrome: A case report. Turkish Journal of Pediatrics. Oct. 2003;45(4):359-362. X-2, X-3. [pmid: 14768808].
2362 Tung MC, Huang WJ, Chen KK. Modified subinguinal varicocelectomy for painful varicocele and varicocele-associated infertility. J Chin Med Assoc. Jun. 2004;67(6):296-300. X-2, X-3. [pmid: 15366407].
2363 Turek PJ, Ewalt DH, Snyder HM 3rd, et al. Normal epididymal anatomy in boys. J Urol. Mar. 1994;151(3):726-7. X-2, X-3. [pmid: 8308996].
2364 Turek PJ, Ewalt DH, Snyder HM 3rd, et al. The absent cryptorchid testis: surgical findings and their implications for diagnosis and etiology. J Urol. Mar. 1994;151(3):718-20. discussion 720–1. X-4, X-5, X-6. [pmid: 7905931].
2365 Turek PJ, Kim M, Gilbaugh JH 3rd, et al. The clinical characteristics of 82 patients with Sertoli cell-only testis histology. Fertil Steril. Dec. 1995;64(6):1197-200. X-2, X-3. [pmid: 7589676].
2366 Turgut AT, Kosar U, Kosar P, et al. Scrotal sonographic findings in equestrians. J Ultrasound Med. Jul. 2005;24(7):911-7. quiz 919. X-2, X-3. [pmid: 15972705].
2367 Turgut AT, Olcucuoglu E, Turan C, et al. Preoperative ultrasonographic evaluation of testicular volume and blood flow in patients with inguinal hernias. J Ultrasound Med. Dec. 2007;26(12):1657-66. quiz 1667–9. X-2, X-3. [pmid: 18029917].
2368 Turgut AT, Ozden E, Unsal A, et al. A novel parameter by EFOV US for the quantification and the distinction of physiological amount of scrotal fluid and hydrocele: ratio of testis volume/scrotum volume. Eur J Radiol. Sep. 2007;63(3):414-9. X-2, X-3. [pmid: 17339090].
2369 Turgut AT, Unsal A, Ozden E, et al. Unilateral idiopathic hydrocele has a substantial effect on the ipsilateral testicular geometry and resistivity indices. J Ultrasound Med. Jul. 2006;25(7):837-43. X-2, X-3. [pmid: 16798894].
2370 Turial S, Enders J, Krause K, et al. Laparoscopic inguinal herniorrhaphy in premature infants. Eur J Pediatr Surg. Nov. 2010;20(6):371-4. X-2, X-3. [pmid: 20669094].
2371 Turial S, Enders J, Krause K, et al. Laparoscopic inguinal herniorrhaphy in babies weighing 5 kg or less. Surg Endosc. Jan. 2011;25(1):72-8. X-2, X-3. [pmid: 20532570].
2372 Turner TT. On unilateral testicular and epididymal torsion: No effect on the contralateral testis. Journal of Urology. 1987;138(5):1285-1290. X-2, X-3. [pmid: 3499519].
2373 Turner TT. The study of varicocele through the use of animal models. Human Reproduction Update. 2001;7(1):78-84. X-1, X-2, X-3. [pmid: 11212079].
2374 Tuttelmann F, Dykstra N, Themmen AP, et al. Anti-Mullerian hormone in men with normal and reduced sperm concentration and men with maldescended testes. Fertil Steril. May. 2009;91(5):1812-9. X-2, X-3. [pmid: 18423454].
2375 Tuttelmann F, Werny F, Cooper TG, et al. Clinical experience with azoospermia: aetiology and chances for spermatozoa detection upon biopsy. Int J Androl. Aug. 2011;34(4):291-8. X-2, X-3. [pmid: 20609027].
2376 Tzvetkova P. Congenital anomalies of the mesonephric duct and fertility. Acta Chir Iugosl. 2007;54(2):63-7. X-2, X-3. [pmid: 18044318].
2377 Tzvetkova P, Tzvetkov D. Etiopathogenesis of cryptorchidism and male infertility. Arch Androl. Sep–Oct. 1996;37(2):117-25. X-4, X-5, X-6. [pmid: 8886261].
2378 Uderzo C, Grazia Zurlo M, Adamoli L, et al. Treatment of isolated testicular relapse in childhood acute lymphoblastic leukemia: an Italian multicenter study. Associazione Italiana Ematologia ed Oncologia Pediatrica. J Clin Oncol. Apr. 1990;8(4):672-7. X-2, X-3. [pmid: 2179480].
2379 Uemura S, Woodward AA, Amerena R, et al. Early repair of inguinal hernia in premature babies. Pediatr Surg Int. 1999;15(1):36-9. X-2, X-3. [pmid: 9914352].
2380 Ul Haq I, Ali G, Haq I, et al. Morbidity of mesh repair in inguinal hernias. Medical Forum Monthly. August. 2009;20(8):43-46. X-2, X-3.
2381 Ul Hasan N. Management of inguinal hernia of childhood as practiced in Karachi, Pakistan. Pediatric Surgery International. 1993;8(6):462-463. X-1, X-2, X-3.
2382 Ulbright TM, Amin MB, Young RH. Intratubular large cell hyalinizing Sertoli cell neoplasia of the testis: A report of 8 cases of a distinctive lesion of the Peutz-Jeghers syndrome. American Journal of Surgical Pathology. Jun. 2007;31(6):827-835. X-2, X-3. [pmid: 17527069].
2383 Ulbright TM, Roth LM, Stehman FB, et al. Poorly differentiated (small cell) carcinoma of the ovary in young women: evidence supporting a germ cell origin. Hum Pathol. Feb. 1987;18(2):175-84. X-2, X-3. [pmid: 3026945].
2384 Ulbright TM, Young RH. Metastatic carcinoma to the testis: a clinicopathologic analysis of 26 nonincidental cases with emphasis on deceptive features. Am J Surg Pathol. Nov. 2008;32(11):1683-93. X-2, X-3. [pmid: 18769334].
2385 Ulusu NN, Tandogan B, Tanyel FC. Sarco(endo)plasmic reticulum and plasmalemmal Ca(2+)-ATPase activities in cremaster muscles and sacs differ according to the associated inguinal pathology. Cell Biochem Funct. Sep–Oct. 2007;25(5):515-9. X-3. [pmid: 16933204].
2386 Underwood W, Kim HL. Intermediate-term oncological efficacy of laparoscopic retroperitoneal lymph node dissection for non-seminomatous germ cell testicular cancer. BJU International. January. 2012;109(2):281-285. X-3. [pmid: 21631699].
2387 Upadhyay V, Hammodat HM, Pease PW. Post circumcision meatal stenosis: 12 years’ experience. N Z Med J. Feb. 27. 1998;111(1060):57-8. X-2, X-3. [pmid: 9539919].
2388 Upadhyay V, Kothari M, Manoharan M. The referral pattern for undescended testes in Auckland. N Z Med J. Jul. 13. 2001;114(1135):310-1. X-3, X-4, X-5, X-6. [pmid: 11556444].
2389 Upton J, Schuster SR, Colodny AH, et al. Testicular autotransplantation in children. Am J Surg. Apr. 1983;145(4):514-9. X-3, X-4, X-5, X-6. [pmid: 6132562].
2390 Urman B, Ata B, Yakin K, et al. Luteal phase empirical low molecular weight heparin administration in patients with failed ICSI embryo transfer cycles: A randomized open-labeled pilot trial. Human Reproduction. July. 2009;24(7):1640-1647. X-2, X-3. [pmid: 19357135].
2391 Urry RL, Carrell DT, Starr NT, et al. The incidence of antisperm antibodies in infertility patients with a history of cryptorchidism. J Urol. Feb. 1994;151(2):381-3. X-3, X-4, X-5, X-6. [pmid: 7904310].
2392 Utine GE, Alanay Y, Aktas D, et al. Kabuki syndrome and trisomy 10p. Genetic Counseling. 2008;19(3):291-300. X-2, X-3. [pmid: 18990985].
2393 Uygur MC, Arik AI, Erol D, et al. Quantitative evaluation of biopty gun testis needle biopsy. Correlation between biopsy score of varicocele-bearing testis and sperm count. J Reprod Med. May. 1999;44(5):445-9. X-2, X-3. [pmid: 10360258].
2394 Valenti G, Baldassarre E, Testa A, et al. Dynamic self-regulating prosthesis (protesi autoregolantesi dinamica): the long-term results in the treatment of primary inguinal hernias. Am Surg. Mar. 2006;72(3):244-8. X-2, X-3. [pmid: 16553127].
2395 Valenti G, Banchini A, Zavaroni D, et al. Pituitary-thyroid axis after bilateral orchiectomy in men. Arch Androl. Sep. 1982;9(2):171-4. X-2, X-3. [pmid: 6816159].
2396 Valentino M, Bertolotto M, Ruggirello M, et al. Cystic lesions and scrotal fluid collections in adults: Ultrasound findings. Journal of Ultrasound. December. 2011;14(4):208-215. X-2, X-3.
2397 van Basten JP, Hoekstra HJ, van Driel MF, et al. Cisplatin-based chemotherapy changes the incidence of bilateral testicular cancer. Ann Surg Oncol. Jun. 1997;4(4):342-8. X-2, X-3. [pmid: 9181235].
2398 van Basten JP, van Driel MF, Jonker-Pool G, et al. Sexual functioning in testosterone-supplemented patients treated for bilateral testicular cancer. Br J Urol. Mar. 1997;79(3):461-7. X-2, X-3. [pmid: 9117232].
2399 Van Bon BWM, Koolen DA, Brueton L, et al. The 2q23.1 microdeletion syndrome: Clinical and behavioural phenotype. European Journal of Human Genetics. February. 2010;18(2):163-170. X-3. [pmid: 19809484].
2400 van Casteren NJ, Stoop H, Dohle GR, et al. Noninvasive detection of testicular carcinoma in situ in semen using OCT3/4. Eur Urol. Jul. 2008;54(1):153-8. X-2, X-3. [pmid: 17996359].
2401 Van der Aa N, Rooms L, Vandeweyer G, et al. Fourteen new cases contribute to the characterization of the 7q11.23 microduplication syndrome. European Journal of Medical Genetics. March. 2009/June. 2009;52(2–3):94-100. X-2, X-3. [pmid: 19249392].
2402 van der Burgt I, Thoonen G, Roosenboom N, et al. Patterns of cognitive functioning in school-aged children with Noonan syndrome associated with variability in phenotypic expression. J Pediatr. Dec. 1999;135(6):707-13. X-3. [pmid: 10586173].
2403 van der Sluijs JW, den Hollander JC, Lequin MH, et al. Prenatal testicular torsion: diagnosis and natural course. An ultrasonographic study. Eur Radiol. Feb. 2004;14(2):250-5. X-2, X-3. [pmid: 12955451].
2404 van der Zanden LF, van Rooij IA, Feitz WF, et al. Genetics of hypospadias: are single-nucleotide polymorphisms in SRD5A2, ESR1, ESR2, and ATF3 really associated with the malformation?. J Clin Endocrinol Metab. May. 2010;95(5):2384-90. X-2, X-3. [pmid: 20215396].
2405 Van Dop C, Burstein S, Conte FA, et al. Isolated gonadotropin deficiency in boys: clinical characteristics and growth. J Pediatr. Nov. 1987;111(5):684-92. X-3. [pmid: 2889818].
2406 Van Landuyt L, Lissens W, Stouffs K, et al. Validation of a simple Yq deletion screening programme in an ICSI candidate population. Mol Hum Reprod. Apr. 2000;6(4):291-7. X-2, X-3. [pmid: 10729309].
2407 Van Savage JG. Avoidance of inguinal incision in laparoscopically confirmed vanishing testis syndrome. J Urol. Oct. 2001;166(4):1421-4. X-3, X-4, X-5, X-6. [pmid: 11547102].
2408 Van Walleghem J, Muller W. Seven cases of testicular tumors with two cryptorchidism. Acta Chir Belg. May–Jun. 1980;79(3):211-8. X-3. [pmid: 6105754].
2409 Vanzulli A, DelMaschio A, Paesano P, et al. Testicular masses in association with adrenogenital syndrome: US findings. Radiology. May. 1992;183(2):425-9. X-2, X-3. [pmid: 1561344].
2410 Vaos G, Zavras N, Boukouvalea I. Ectopic adrenocortical tissue along the inguinoscrotal path of children. Int Surg. May–Jun. 2006;91(3):125-8. X-2, X-3. [pmid: 16845852].
2411 Varela-Cives R, Bautista-Casasnovas A, Taboada-Santomil P, et al. Relevance of herniography for accurate diagnosis of patent processus vaginalis in cryptorchidism. Int Braz J Urol. Jan–Feb. 2008;34(1):57-62. X-3. [pmid: 18341722].
2412 Varlet F, Becmeur F. Laparoscopic treatment of varicoceles in children. Multicentric prospective study of 90 cases. Eur J Pediatr Surg. Dec. 2001;11(6):399-403. X-2, X-3. [pmid: 11807670].
2413 Vasudevan G, Manivarmane, Bhat BV, et al. Genital standards for south Indian male newborns. Indian J Pediatr. Sep–Oct. 1995;62(5):593-6. X-2, X-3. [pmid: 10829928].
2414 Vaysse P. Laparoscopy and impalpable testis--a prospective multicentric study (232 cases). GECI. Groupe d’Etude en Coeliochirurgie Infantile. Eur J Pediatr Surg. Dec. 1994;4(6):329-32. X-4, X-5, X-6. [pmid: 7748830].
2415 Vegni-Talluri M, Bigliardi E, Vanni MG, et al. Testicular microliths: their origin and structure. J Urol. Jul. 1980;124(1):105-7. X-3. [pmid: 6106071].
2416 Venara M, Rey R, Bergada I, et al. Sertoli cell proliferations of the infantile testis: an intratubular form of Sertoli cell tumor?. Am J Surg Pathol. Oct. 2001;25(10):1237-44. X-2, X-3. [pmid: 11688457].
2417 Venkatachala S, Malur PR, Nerli RB, et al. Testicular biopsies--histomorphologic patterns in male infertility. Indian J Pathol Microbiol. Oct. 2007;50(4):726-9. X-2, X-3. [pmid: 18306537].
2418 Venugopal S. Inguinal hernia in children. West Indian Med J. Mar. 1993;42(1):24-6. X-2, X-3. [pmid: 8503210].
2419 Verdorfer I, Hollrigl A, Strasser U, et al. Molecular-cytogenetic characterisation of sex cord-stromal tumours: CGH analysis in sertoli cell tumours of the testis. Virchows Arch. Apr. 2007;450(4):425-31. X-2, X-3. [pmid: 17333264].
2420 Verdyck P, Holder-Espinasse M, Hul WV, et al. Clinical and molecular analysis of nine families with Adams-Oliver syndrome. Eur J Hum Genet. Jun. 2003;11(6):457-63. X-2, X-3. [pmid: 12774039].
2421 Verghese ST, Hannallah RS, Rice LJ, et al. Caudal anesthesia in children: effect of volume versus concentration of bupivacaine on blocking spermatic cord traction response during orchidopexy. Anesth Analg. Nov. 2002;95(5):1219-23. table of contents. X-3, X-4, X-5, X-6. [pmid: 12401597].
2422 Vermeulen A, Schelfhout W, De Sy W. Plasma androgen levels after subcapsular orchiectomy or estrogen treatment for prostatic carcinoma. Prostate. 1982;3(2):115-21. X-2, X-3. [pmid: 6211662].
2423 Vermouth NT, Carriazo CS, Gallara RV, et al. Maternal coordination of the daily rhythm of malate dehydrogenase activity in testes from young rats: effect of maternal sympathetic denervation of the pineal gland and administration of melatonin. Chronobiol Int. Feb. 1995;12(1):8-18. X-2, X-3. [pmid: 7750160].
2424 Vernaeve V, Krikilion A, Verheyen G, et al. Outcome of testicular sperm recovery and ICSI in patients with non-obstructive azoospermia with a history of orchidopexy. Hum Reprod. Oct. 2004;19(10):2307-12. X-2, X-3. [pmid: 15310729].
2425 Versiani BR, Trarbach E, Koenigkam-Santos M, et al. Clinical assessment and molecular analysis of GnRHR and KAL1 genes in males with idiopathic hypogonadotrophic hypogonadism. Clin Endocrinol (Oxf). Feb. 2007;66(2):173-9. X-2, X-3. [pmid: 17223984].
2426 Vicentini FC, Denes FT, Gomes CM, et al. Urogenital involvement in the Klippel-Trenaunay-Weber syndrome. Treatment options and results. Int Braz J Urol. Nov–Dec. 2006;32(6):697-703. discussion 703–4. X-2, X-3. [pmid: 17201948].
2427 Vickers MA Jr, Lamontagne DP, Guru KA, et al. Autologous tunica vaginalis and subcapsular orchiectomy: a hormonal therapy for prostate cancer. J Androl. May–Jun. 2004;25(3):375-81. X-2, X-3. [pmid: 15064315].
2428 Vignozzi L, Filippi S, Morelli A, et al. Cavernous neurotomy in the rat is associated with the onset of an overt condition of hypogonadism. J Sex Med. May. 2009;6(5):1270-83. X-2, X-3. [pmid: 19210708].
2429 Vigueras RM, Moreno-Mendoza N, Reyes G, et al. Androgen receptor and calcitonin gene-related peptide in neurons of the genitofemoral nerve during testicular descent induced with human chorionic gonadotropin. Arch Med Res. May–Jun. 2003;34(3):166-70. X-2, X-3. [pmid: 14567394].
2430 Vijjan VK, Malik VK, Agarwal PN. The role of laparoscopy in the localization and management of adult impalpable testes. JSLS. Jan–Mar. 2004;8(1):43-6. X-2. [pmid: 14974662].
2431 Vilain C, Mortier G, Van Vliet G, et al. Hartsfield holoprosencephaly-ectrodactyly syndrome in five male patients: Further delineation and review. American Journal of Medical Genetics, Part A. July. 2009;149(7):1476-1481. X-2, X-3. [pmid: 19504604].
2432 Vilain E. The genetics of ovotesticular disorders of sex development. Pediatrics and Pediatric Surgery. (Advances in Experimental Medicine and Biology. 707). 2011:105-106. X-1, X-3.
2433 Vilain E, Jaubert F, Fellous M, et al. Pathology of 46,XY pure gonadal dysgenesis: absence of testis differentiation associated with mutations in the testis-determining factor. Differentiation. Jan. 1993;52(2):151-9. X-2, X-3. [pmid: 8472885].
2434 Vinardi S, Magro P, Manenti M, et al. Testicular function in men treated in childhood for undescended testes. J Pediatr Surg. Feb. 2001;36(2):385-8. X-2. [pmid: 11172441].
2435 Vinci G, Anjot MN, Trivin C, et al. An analysis of the genetic factors involved in testicular descent in a cohort of 14 male patients with anorchia. J Clin Endocrinol Metab. Dec. 2004;89(12):6282-5. X-2, X-3. [pmid: 15579790].
2436 Virtanen HE, Tapanainen AE, Kaleva MM, et al. Mild gestational diabetes as a risk factor for congenital cryptorchidism. J Clin Endocrinol Metab. Dec. 2006;91(12):4862-5. X-3. [pmid: 17032715].
2437 Visfeldt J, Cortes D, Thorup JM, et al. Anti-MIC2 as a tool in examination of testicular biopsies. APMIS. Jul. 1999;107(7):631-5. X-3, X-4, X-5, X-6. [pmid: 10440058].
2438 Visser HK. Associated anomalies in undescended testes. Eur J Pediatr. Dec. 1982;139(4):272-4. X-3. [pmid: 6133754].
2439 Viswaroop BS, Kekre N, Gopalakrishnan G. Isolated tuberculous epididymitis: a review of forty cases. J Postgrad Med. Apr–Jun. 2005;51(2):109-11. discussion 111. X-2, X-3. [pmid: 16006701].
2440 Viville S, Warter S, Meyer JM, et al. Histological and genetic analysis and risk assessment for chromosomal aberration after ICSI for patients presenting with CBAVD. Hum Reprod. Jul. 2000;15(7):1613-8. X-2, X-3. [pmid: 10875876].
2441 Vogels A, Moerman P, Frijns JP, et al. Testicular histology in boys with Prader-Willi syndrome: fertile or infertile?. J Urol. Oct. 2008;180(4 Suppl):1800-4. X-3, X-4, X-5, X-6. [pmid: 18721940].
2442 Vogels HD, Bruijnen CJ, Beasley SW. Establishing benchmarks for the outcome of herniotomy in children. Br J Surg. Jul. 2010;97(7):1135-9. X-2, X-3. [pmid: 20632283].
2443 Vogt-Moykopf I, Bulzebruck H, Merkle NM, et al. Results of surgical treatment of pulmonary metastases. Eur J Cardiothorac Surg. 1988;2(4):224-32. X-3. [pmid: 3272226].
2444 Vogt-Moykopf I, Meyer G, Merkle NM, et al. Late results of surgical treatment of pulmonary metastases. Thorac Cardiovasc Surg. Nov. 1986;34(Spec No 2):143-8. X-3. [pmid: 2432688].
2445 Volkmann J, Muller D, Feuerstacke C, et al. Disturbed spermatogenesis associated with thickened lamina propria of seminiferous tubules is not caused by dedifferentiation of myofibroblasts. Human Reproduction. June. 2011;26(6):1450-1461. X-2, X-3. [pmid: 21467201].
2446 von der Maase H, Giwercman A, Muller J, et al. Management of carcinoma-in-situ of the testis. Int J Androl. Feb. 1987;10(1):209-20. X-3. [pmid: 2438219].
2447 von der Maase H, Rorth M, Walbom-Jorgensen S, et al. Carcinoma in situ of contralateral testis in patients with testicular germ cell cancer: study of 27 cases in 500 patients. Br Med J (Clin Res Ed). Nov. 29. 1986;293(6559):1398-401. X-3.
2448 von Eckardstein S, Simoni M, Bergmann M, et al. Serum inhibin B in combination with serum follicle-stimulating hormone (FSH) is a more sensitive marker than serum FSH alone for impaired spermatogenesis in men, but cannot predict the presence of sperm in testicular tissue samples. J Clin Endocrinol Metab. Jul. 1999;84(7):2496-501. X-2, X-3. [pmid: 10404826].
2449 von Eyben FE, Skude G, Krabbe S. Serum lactate dehydrogenase and its isoenzymes in men with maldescended testes. J Urol. Dec. 1982;128(6):1195-7. X-2, X-3. [pmid: 6130162].
2450 von Krogh J, Lien HH, Ous S, et al. Alterations in the CT image following retroperitoneal lymphadenectomy in early stage non-seminomatous testicular tumor. Acta Radiol Diagn (Stockh). Mar–Apr. 1985;26(2):187-91. X-3. [pmid: 3993423].
2451 Vugrin D, Whitmore WF Jr. The role of chemotherapy and surgery in the treatment of retroperitoneal metastases in advanced nonseminomatous testis cancer. Cancer. May. 1. 1985;55(9):1874-8. X-2, X-3. [pmid: 4038913].
2452 Vugrin D, Whitmore WF Jr, Golbey RB. VAB-5 combination chemotherapy in prognostically poor risk patients with germ cell tumors. Cancer. Mar. 15. 1983;51(6):1072-5. X-2, X-3. [pmid: 6185211].
2453 Vydra G, Magasi P, Rozsahegyi J. Ultrastructural investigations of undescended testicles. Acta Chir Hung. 1984;25(2):75-86. X-3. [pmid: 6147058].
2454 Wacksman J, Billmire DA, Lewis AG, et al. Laparoscopically assisted testicular autotransplantation for management of the intraabdominal undescended testis. J Urol. Aug. 1996;156(2 Pt 2):772-4. X-4, X-5, X-6. [pmid: 8683780].
2455 Wacksman J, Dinner M, Staffon RA. Technique of testicular autotransplantation using a microvascular anastomosis. Surg Gynecol Obstet. Mar. 1980;150(3):399-400. X-4, X-5, X-6. [pmid: 6101922].
2456 Wagner-Mahler K, Kurzenne JY, Delattre I, et al. Prospective study on the prevalence and associated risk factors of cryptorchidism in 6246 newborn boys from Nice area, France. International Journal of Andrology. October. 2011;34(5 PART 2):e499-e510. X-3. [pmid: 21831232].
2457 Wakhlu A, Dalela D, Tandon RK, et al. The single ectopic ureter. Br J Urol. Aug. 1998;82(2):246-51. X-2, X-3. [pmid: 9722761].
2458 Walcott FL, Hauptmann M, Duphorne CM, et al. A case-control study of dietary phytoestrogens and testicular cancer risk. Nutr Cancer. 2002;44(1):44-51. X-2, X-3. [pmid: 12672640].
2459 Waldschmidt J, Schier F. Laparoscopic surgery in neonates and infants. Eur J Pediatr Surg. Jun. 1991;1(3):145-50. X-3, X-4, X-5, X-6. [pmid: 1679999].
2460 Walker BR, Skoog SJ, Winslow BH, et al. Testis sparing surgery for steroid unresponsive testicular tumors of the adrenogenital syndrome. J Urol. Apr. 1997;157(4):1460-3. X-3. [pmid: 9120982].
2461 Wallace DM, Gunter PA, Landon GV, et al. Sympathetic orchiopathia--an experimental and clinical study. Br J Urol. Dec. 1982;54(6):765-8. X-3. [pmid: 7150939].
2462 Walschaerts M, Muller A, Auger J, et al. Environmental, occupational and familial risks for testicular cancer: a hospital-based case-control study. Int J Androl. Aug. 2007;30(4):222-9. X-2, X-3. [pmid: 17708752].
2463 Walsh TJ, Wu AK, Croughan MS, et al. Differences in the clinical characteristics of primarily and secondarily infertile men with varicocele. Fertil Steril. Mar. 2009;91(3):826-30. X-2, X-3. [pmid: 18314114].
2464 Wan J, Corvino TF, Greenfield SP, et al. The incidence of recreational genitourinary and abdominal injuries in the Western New York pediatric population. J Urol. Oct. 2003;170(4 Pt 2):1525-7. discussion 1527. X-2, X-3. [pmid: 14501651].
2465 Wanderas EH, Fossa SD, Heilo A, et al. Serum follicle stimulating hormone--predictor of cancer in the remaining testis in patients with unilateral testicular cancer. Br J Urol. Sep. 1990;66(3):315-7. X-3. [pmid: 2119845].
2466 Wandless JG. A comparison of nalbuphine with morphine for post-orchidopexy pain. Eur J Anaesthesiol. Mar. 1987;4(2):127-32. X-3, X-4, X-5, X-6. [pmid: 2885187].
2467 Wang KS, Shaul DB. Two-stage laparoscopic orchidopexy with gubernacular preservation: Preliminary report of a new approach to the intra-abdominal testis. Pediatric Endosurgery and Innovative Techniques. Sep. 2004;8(3):250-253. X-4, X-5, X-6.
2468 Wang WJ, Yeh YA, Stout P, et al. Inverse relationship between Leydig cell density and metastatic potential of prostatic adenocarcinoma. Anal Cell Pathol. 1999;19(3–4):169-73. X-2, X-3. [pmid: 10866279].
2469 Wang Y, Barthold J, Figueroa E, et al. Analysis of five single nucleotide polymorphisms in the ESR1 gene in cryptorchidism. Birth Defects Res A Clin Mol Teratol. Jun. 2008;82(6):482-5. X-3. [pmid: 18452179].
2470 Wang YX, Lei C, Dong SG, et al. Study of bilateral histology and meiotic analysis in men undergoing varicocele ligation. Fertil Steril. Jan. 1991;55(1):152-5. X-2, X-3. [pmid: 1986956].
2471 Wang Z, Yang S, Shi H, et al. Histopathological and immunophenotypic features of testicular tumour of the adrenogenital syndrome. Histopathology. June. 2011;58(7):1013-1018. X-2, X-3. [pmid: 21707702].
2472 Ward JF, Cilento BG Jr, Kaplan GW, et al. The ultrasonic description of postpubertal testicles in men who have undergone prepubertal orchiopexy for cryptorchidism. J Urol. May. 2000;163(5):1448-50. X-2, X-3. [pmid: 10751855].
2473 Wasniewska M, Matarazzo P, Weber G, et al. Clinical presentation of McCune-Albright syndrome in males. J Pediatr Endocrinol Metab. May. 2006;19(Suppl 2):619-22. X-2, X-3. [pmid: 16789625].
2474 Watanabe M, Kashiwakura Y, Kusumi N, et al. Adeno-associated virus-mediated human IL-10 gene transfer suppresses the development of experimental autoimmune orchitis. Gene Ther. Jul. 2005;12(14):1126-32. X-2, X-3. [pmid: 15920464].
2475 Waters WB, Garnick MB, Richie JP. Complications of retroperitoneal lymphadenectomy in the management of nonseminomatous tumors of the testis. Surg Gynecol Obstet. Apr. 1982;154(4):501-4. X-2, X-3. [pmid: 7064080].
2476 Watkin NA, Reiger NA, Moisey CU. Is the conservative management of the acute scrotum justified on clinical grounds?. British Journal of Urology. 1996;78(4):623-627. X-2, X-3. [pmid: 8944521].
2477 Waxman S, Beekley A, Morey A, et al. Penetrating trauma to the external genitalia in Operation Iraqi Freedom. Int J Impot Res. Mar–Apr. 2009;21(2):145-8. X-2, X-3. [pmid: 19020522].
2478 Weingarten BJ, Kellman GM, Middleton WD, et al. Tubular ectasia within the mediastinum testis. J Ultrasound Med. Jul. 1992;11(7):349-53. X-3. [pmid: 1522625].
2479 Weir HK, Marrett LD, Kreiger N, et al. Pre-natal and peri-natal exposures and risk of testicular germ-cell cancer. Int J Cancer. Aug. 1. 2000;87(3):438-43. X-2, X-3. [pmid: 10897052].
2480 Weisberger EC, McBride LC. Modified neck dissection for metastatic nonseminomatous testicular carcinoma. Laryngoscope. Aug. 1999;109(8):1241-4. X-3. [pmid: 10443827].
2481 Weiske WH, Salzler N, Schroeder-Printzen I, et al. Clinical findings in congenital absence of the vasa deferentia. Andrologia. Jan. 2000;32(1):13-8. X-3. [pmid: 10702861].
2482 Weiss RM, Seashore JH. Laparoscopy in the management of the nonpalpable testis. J Urol. Aug. 1987;138(2):382-4. X-4, X-5, X-6. [pmid: 2885429].
2483 Welch VW. The management of urologic disorders in the neonate. J Perinat Neonatal Nurs. Jun. 1994;8(1):48-58. X-3, X-4, X-5, X-6. [pmid: 7911828].
2484 Welvaart K, Tijssen JG. Management of the undescended testis in relation to the development of cancer. J Surg Oncol. 1981;17(3):219-23. X-3. [pmid: 6114187].
2485 Wennstrom B, Bergh I. Bodily and verbal expressions of postoperative symptoms in 3- to 6-year-old boys. J Pediatr Nurs. Feb. 2008;23(1):65-76. X-3. [pmid: 18207049].
2486 Wenzler DL, Bloom DA, Park JM. What is the rate of spontaneous testicular descent in infants with cryptorchidism?. J Urol. Feb. 2004;171(2 Pt 1):849-51. X-3. [pmid: 14713841].
2487 West AF, Leung HY, Powell PH. Epididymectomy is an effective treatment for scrotal pain after vasectomy. BJU Int. Jun. 2000;85(9):1097-9. X-3. [pmid: 10848703].
2488 Westermann DH, Schefer H, Thalmann GN, et al. Long-term followup results of 1 cycle of adjuvant bleomycin, etoposide and cisplatin chemotherapy for high risk clinical stage I nonseminomatous germ cell tumors of the testis. J Urol. Jan. 2008;179(1):163-6. X-3. [pmid: 18001800].
2489 Wheatley JK, Bergman WA, Green B, et al. Transvenous occlusion of clinical and subclinical varicoceles. Urology. Apr. 1991;37(4):362-5. X-2, X-3. [pmid: 2014603].
2490 Wheeler M, Peakman D, Robinson A, et al. 45,X/46,XY mosaicism: contrast of prenatal and postnatal diagnosis. Am J Med Genet. Mar. 1988;29(3):565-71. X-3. [pmid: 3376999].
2491 Wheeler PG, Quigley CA, Sadeghi-Nejad A, et al. Hypogonadism and CHARGE association. American Journal of Medical Genetics. 18. Sep. 2000;94(3):228-231. X-2, X-3. [pmid: 10995509].
2492 Whitaker P, De Kock ML. Laparoscopy for the non-palpable testis--look before you cut!. S Afr J Surg. Mar. 1992;30(1):26-8. X-4, X-5, X-6. [pmid: 1348878].
2493 White BJ, Rogol AD, Brown KS. The syndrome of anosmia with hypogonadotropic hypogonadism: A genetic study of 18 new families and a review. American Journal of Medical Genetics. 1983;15(3):417-435. X-2, X-3. [pmid: 6881209].
2494 Wiener JS, Marcelli M, Gonzales ET Jr, et al. Androgen receptor gene alterations are not associated with isolated cryptorchidism. J Urol. Sep. 1998;160(3 Pt 1):863-5. X-3, X-4, X-5, X-6. [pmid: 9720578].
2495 Wikramanayake E. Testicular size in young adult Sinhalese. Int J Androl. Jun. 1995;18(Suppl 1):29-31. X-2, X-3. [pmid: 7558385].
2496 Wilkerson ML, Bartone FF, Fox L, et al. Fertility potential: a comparison of intra-abdominal and intracanalicular testes by age groups in children. Horm Res. 2001;55(1):18-20. X-3. [pmid: 11423737].
2497 Willan BD, McGowan DG. Seminoma of the testis: a 22-year experience with radiation therapy. Int J Radiat Oncol Biol Phys. Oct. 1985;11(10):1769-75. X-2, X-3. [pmid: 4044339].
2498 Willemse PH, Sleijfer DT, Schraffordt Koops H, et al. Leydig cell function in patients with testicular cancer during and after chemotherapy. Int J Androl. Dec. 1983;6(6):497-508. X-3. [pmid: 6421750].
2499 Willemse PH, Sleijfer DT, Sluiter WJ, et al. Altered Leydig cell function in patients with testicular cancer: evidence for bilateral testicular defect. Acta Endocrinol (Copenh). Apr. 1983;102(4):616-24. X-2, X-3. [pmid: 6133401].
2500 Willemse PM, Hamdy NA, van Wulften L, et al. Prevalence of vertebral fractures independent of BMD and anticancer treatment in patients with testicular germ cell tumors. J Clin Endocrinol Metab. Nov. 2010;95(11):4933-42. X-3. [pmid: 20702527].
2501 Williams EV, Appanna T, Foster ME. Management of the impalpable testis: a six year review together with a national experience. Postgrad Med J. May. 2001;77(907):320-2. X-3, X-4, X-5, X-6. [pmid: 11320275].
2502 Williamson RC, Thomas WE. Sympathetic orchidopathia. Ann R Coll Surg Engl. Jul. 1984;66(4):264-6. X-3. [pmid: 6742739].
2503 Willschke H, Marhofer P, Bosenberg A, et al. Ultrasonography for ilioinguinal/iliohypogastric nerve blocks in children. Br J Anaesth. Aug. 2005;95(2):226-30. X-3, X-4, X-5, X-6. [pmid: 15923270].
2504 Winquist EW, Bauman GS, Balogh J. Nontraumatic osteonecrosis after chemotherapy for testicular cancer: A systematic review. American Journal of Clinical Oncology: Cancer Clinical Trials. 2001;24(6):603-606. X-2, X-3.
2505 Winters SJ, Troen P. A reexamination of pulsatile luteinizing hormone secretion in primary testicular failure. J Clin Endocrinol Metab. Aug. 1983;57(2):432-5. X-2, X-3. [pmid: 6134749].
2506 Wisanuyotin S, Dell KM, Vogt BA, et al. Complications of peritoneal dialysis in children with Eagle-Barrett syndrome. Pediatr Nephrol. Feb. 2003;18(2):159-63. X-2, X-3. [pmid: 12579407].
2507 Wiser A, Raviv G, Weissenberg R, et al. Does age at orchidopexy impact on the results of testicular sperm extraction?. Reprod Biomed Online. Dec. 2009;19(6):778-83. X-2. [pmid: 20031016].
2508 Wisser J, Kurmanavicius J, Lauper U, et al. Successful treatment of fetal megavesica in the first half of pregnancy. Am J Obstet Gynecol. Sep. 1997;177(3):685-9. X-2, X-3. [pmid: 9322643].
2509 Witt MA, Heron S, Lipshultz LI. The post-vasectomy length of the testicular vasal remnant: a predictor of surgical outcome in microscopic vasectomy reversal. J Urol. Apr. 1994;151(4):892-4. X-3. [pmid: 8126819].
2510 Wobbes T, Eibergen R, Oldhoff J, et al. Results of retroperitoneal lymph node dissection and postoperative adjuvant chemotherapy with dactinomycin in the treatment of retroperitoneal metastases of nonseminomatous testicular germ cell tumors. Cancer. Mar. 15. 1983;51(6):1076-9. X-3. [pmid: 6295621].
2511 Wobbes T, Schraffordt Koops H, Oldhoff J. The relation between testicular tumours, undescended testes, and inguinal hernias. J Surg Oncol. 1980;14(1):45-51. X-3. [pmid: 6103979].
2512 Wobbes T, Schraffordt Koops H, Oldhoff J. Results of treatment of non-seminomatous tumours of the testis in pathological stage I. Netherlands Journal of Surgery. 1983;35(3):89-93. X-2, X-3. [pmid: 6310445].
2513 Wofford MM, Smith SD, Shuster JJ, et al. Treatment of occult or late overt testicular relapse in children with acute lymphoblastic leukemia: a Pediatric Oncology Group study. J Clin Oncol. Apr. 1992;10(4):624-30. X-3. [pmid: 1548525].
2514 Wohlfahrt-Veje C, Boisen KA, Boas M, et al. Acquired cryptorchidism is frequent in infancy and childhood. Int J Androl. Aug. 2009;32(4):423-8. X-3. [pmid: 19515170].
2515 Woldu SL, Van Batavia JP, Poon SA, et al. Is adolescent varicocelectomy safe after previous inguinal surgery?. J Urol. Oct. 2010;184(4 Suppl):1716-21. X-3. [pmid: 20728158].
2516 Wolf AR, Hughes D, Wade A, et al. Postoperative analgesia after paediatric orchidopexy: evaluation of a bupivacaine-morphine mixture. Br J Anaesth. Apr. 1990;64(4):430-5. X-3, X-4, X-5, X-6. [pmid: 1970738].
2517 Wolf SA, Hopkins JW. Laparoscopic incidence of contralateral patent processus vaginalis in boys with clinical unilateral inguinal hernias. J Pediatr Surg. Aug. 1994;29(8):1118-20. discussion 1120–1. X-3. [pmid: 7965517].
2518 Wolloch Y, Shahar E, Shachter A, et al. Fertility and sexual development after bilateral orchiopexy for cryptorchidism. Isr J Med Sci. Sep–Oct. 1980;16(9–10):707-10. X-4, X-5, X-6. [pmid: 6107281].
2519 Wong HB, Chua TS. Aspects of male hypogonadism. Journal of the Singapore Paediatric Society. 1985;27(1–2):47-60. X-1, X-2, X-3. [pmid: 4033084].
2520 Wood S, Vang E, Manning J, et al. The ratio of second to fourth digit length in azoospermic males undergoing surgical sperm retrieval: predictive value for sperm retrieval and on wubsequent fertilization and pregnancy rates in IVF/ICSI cycles. J Androl. Nov–Dec. 2003;24(6):871-7. X-2, X-3. [pmid: 14581513].
2521 Wood S, Vang E, Troup S, et al. Surgical sperm retrieval after previous vasectomy and failed reversal: clinical implications for in vitro fertilization. BJU Int. Aug. 2002;90(3):277-81. X-2, X-3. [pmid: 12133065].
2522 Woodhouse CR. Prospects for fertility in patients born with genitourinary anomalies. J Urol. Jun. 2001;165(6 Pt 2):2354-60. X-3, X-4, X-5, X-6. [pmid: 11371977].
2523 Woodhouse CR, Ransley PG, Innes-Williams D. Prune belly syndrome--report of 47 cases. Arch Dis Child. Nov. 1982;57(11):856-9. X-3. [pmid: 6128960].
2524 Woodhouse CR, Snyder HM 3rd. Testicular and sexual function in adults with prune belly syndrome. J Urol. Apr. 1985;133(4):607-9. X-3, X-4, X-5, X-6. [pmid: 3920404].
2525 Woodhouse J, Ferguson MM. Multiple hyperechoic testicular lesions are a common finding on ultrasound in Cowden disease and represent lipomatosis of the testis. Br J Radiol. Oct. 2006;79(946):801-3. X-2, X-3. [pmid: 16980675].
2526 Woodhouse JB, Delahunt B, English SF, et al. Testicular lipomatosis in Cowden’s syndrome. Mod Pathol. Sep. 2005;18(9):1151-6. X-2, X-3. [pmid: 15920539].
2527 Worischeck JH, Parra RO. Transrectal ultrasound in the evaluation of men with low volume azoospermia. J Urol. May. 1993;149(5 Pt 2):1341-4. X-2, X-3. [pmid: 8479032].
2528 Wright EJ, Young GP, Goldstein M. Reduction in testicular temperature after varicocelectomy in infertile men. Urology. Aug. 1997;50(2):257-9. X-2, X-3. [pmid: 9255298].
2529 Wu AK, Walsh TJ, Phonsombat S, et al. Bilateral but not unilateral testicular hypotrophy predicts for severe impairment of semen quality in men with varicocele undergoing infertility evaluation. Urology. Jun. 2008;71(6):1114-8. X-2, X-3. [pmid: 18538693].
2530 Wu HY, Rusnack SL, Bellah RD, et al. Genitourinary malformations in chromosome 22q11.2 deletion. J Urol. Dec. 2002;168(6):2564-5. X-3. [pmid: 12441983].
2531 Wu WH, Chuang JH, Ting YC, et al. Developmental anomalies and disabilities associated with hypospadias. J Urol. Jul. 2002;168(1):229-32. X-2, X-3. [pmid: 12050549].
2532 Wuernschimmel E, Lipsky H, Noest G. Laparoscopic varicocele ligation: a recommendable standard procedure with good long-term results. Eur Urol. 1995;27(1):18-22. X-3. [pmid: 7744135].
2533 Wyllie GC. The retractile testis. Medical Journal of Australia. 1984;140(7):403-405. X-3. [pmid: 6142410].
2534 Wyns C, Curaba M, Martinez-Madrid B, et al. Spermatogonial survival after cryopreservation and short-term orthotopic immature human cryptorchid testicular tissue grafting to immunodeficient mice. Hum Reprod. Jun. 2007;22(6):1603-11. X-3. [pmid: 17483089].
2535 Wysowski DK. Use of fertility drugs in the United States, 1973 through 1991. Fertil Steril. Dec. 1993;60(6):1096-8. X-2, X-3. [pmid: 7902301].
2536 Xavier A, Maxwell AP. Which patients with renal colic should be referred?. Practitioner. Feb. 2011;255(1737):15. 7–2. X-1, X-2, X-3. [pmid: 21539143].
2537 Xing G, Zhang L, Heynen T, et al. Rat nurr1 is prominently expressed in perirhinal cortex, and differentially induced in the hippocampal dentate gyrus by electroconvulsive vs. kindled seizures. Brain Res Mol Brain Res. Jul. 1997;47(1–2):251-61. X-2, X-3. [pmid: 9221923].
2538 Yagan N. Testicular US findings after biopsy. Radiology. Jun. 2000;215(3):768-73. X-3. [pmid: 10831698].
2539 Yakirevich E, Yanai O, Sova Y, et al. Cytotoxic phenotype of intra-epithelial lymphocytes in normal and cryptorchid human testicular excurrent ducts. Hum Reprod. Feb. 2002;17(2):275-83. X-3. [pmid: 11821263].
2540 Yalcin B, Komesli GH, Ozgok Y, et al. Vascular anatomy of normal and undescended testes: surgical assessment of anastomotic channels between testicular and deferential arteries. Urology. Oct. 2005;66(4):854-7. X-2, X-3. [pmid: 16230152].
2541 Yamaguchi M, Sakatoku J, Takihara H. The application of intrascrotal deep body temperature measurement for the noninvasive diagnosis of varicoceles. Fertil Steril. Aug. 1989;52(2):295-301. X-2, X-3. [pmid: 2753177].
2542 Yamamoto M, Hibi H, Katsuno S, et al. Management of chronic orchialgia of unknown etiology. Int J Urol. Mar. 1995;2(1):47-9. X-2, X-3. [pmid: 7542163].
2543 Yamamoto M, Katsuno S, Yokoi K, et al. The effect of varicocelectomy on testicular volume in infertile patients with varicoceles. Nagoya J Med Sci. Mar. 1995;58(1–2):47-50. X-2, X-3. [pmid: 7659147].
2544 Yamamoto M, Tsuji Y, Ohmura M, et al. Comparison of artery-ligating and artery-preserving varicocelectomy: effect on post-operative spermatogenesis. Andrologia. Jan–Feb. 1995;27(1):37-40. X-2, X-3. [pmid: 7755188].
2545 Yaman Soygur T, Yilmaz E, et al. The significance of testicular reactive oxygen species on testicular histology in infertile patients. Int Urol Nephrol. 1999;31(3):395-9. X-2, X-3. [pmid: 10672960].
2546 Yaman A, Saatci P, Arikan G, et al. Ocular findings in children with nonsyndromic cleft lip and palate. Turk J Pediatr. Jul–Aug. 2009;51(4):350-3. X-2, X-3. [pmid: 19950842].
2547 Yamanaka J, Baker M, Metcalfe S, et al. Serum levels of Mullerian inhibiting substance in boys with cryptorchidism. J Pediatr Surg. May. 1991;26(5):621-3. X-3. [pmid: 1676417].
2548 Yamazaki Y, Suzuki M, Shiroyanagi Y, et al. Scrotal nubbins associated with blind-ending spermatic vessels and a normal vas deferens on laparoscopy. Int J Urol. Nov. 2009;16(11):902-4. X-3, X-4, X-5, X-6. [pmid: 19863626].
2549 Yan J, Huang G, Sun Y, et al. Birth defects after assisted reproductive technologies in China: Analysis of 15,405 offspring in seven centers (2004 to 2008). Fertility and Sterility. January. 2011;95(1):458-460. X-3. [pmid: 20850722].
2550 Yang C, Liu X, Wei GH. Foreskin development in 10 421 Chinese boys aged 0–18 years. World J Pediatr. Nov. 2009;5(4):312-5. X-2, X-3. [pmid: 19911150].
2551 Yang G, Walsh TJ, Shefi S, et al. The kinetics of the return of motile sperm to the ejaculate after vasectomy reversal. J Urol. Jun. 2007;177(6):2272-6. X-2, X-3. [pmid: 17509339].
2552 Yang GS, Lu RK, Chen ZD. Clinical significance of EGF and EGFR expression changes in cryptorchid boys. Asian J Androl. Dec. 2002;4(4):255-8. X-3, X-4, X-5, X-6. [pmid: 12508124].
2553 Yang RJ, Sheu JJ, Chen HS, et al. Morbidity at elementary school entry differs by sex and level of residence urbanization: A comparative cross-sectional study. BMC Public Health. 2007;7(358). X-2, X-3.
2554 Yang W, Ding J, Jin X, et al. The plication and splinting procedure for idiopathic sclerosing encapsulating peritonitis. J Invest Surg. Jul–Aug. 2009;22(4):286-91. X-2, X-3. [pmid: 19842905].
2555 Yanke BV, Horowitz M. Safety of the Veress needle in pediatric laparoscopy. J Endourol. Jul. 2007;21(7):695-7. X-3, X-4, X-5, X-6. [pmid: 17705752].
2556 Yazama F, Tai A. Unexpected role of alpha-fetoprotein in spermatogenesis. PLoS One. 2011;6(5):e19387. X-2, X-3. 3087797. [pmid: 21573244].
2557 Yeboah ED, Wadhwani JM, Wilson JB. Etiological factors of male infertility in Africa. Int J Fertil. Sep–Oct. 1992;37(5):300-7. X-2, X-3. [pmid: 1358843].
2558 Yeniyol CO, Sorguc S, Minareci S, et al. Role of interferon-alpha-2B in prevention of testicular atrophy with unilateral mumps orchitis. Urology. Jun. 2000;55(6):931-3. X-2, X-3. [pmid: 10840112].
2559 Yetkin MA, Erdinc FS, Bulut C, et al. Epididymoorchitis due to brucellosis in central Anatolia, Turkey. Urol Int. 2005;75(3):235-8. X-2, X-3. [pmid: 16215312].
2560 Yeung L, Palmer D, Holland D, et al. Journal of Endourology. [Conference Abstract]. 01. Jun. Conference: 24th Annual Meeting of the Engineering and Urology Society. Chicago, IL United States. Conference Start: 20090425 Conference End: 20090425. Conference: 24th Annual Meeting of the Engineering and Urology Society. Chicago, IL United States. Conference Start: 20090425 Conference End: 20090425. Conference Publication: (var.pagings). 2009;23(6):1032-1033. X-2, X-3.
2561 Yeung YP, Cheng MS, Ho KL, et al. Day-case inguinal herniotomy in Chinese children: retrospective study. Hong Kong Med J. Aug. 2002;8(4):245-8. X-3. [pmid: 12167727].
2562 Yikilmaz A, Lee EY. MRI findings of bilateral juvenile granulosa cell tumor of the testis in a newborn presenting as intraabdominal masses. Pediatr Radiol. Oct. 2007;37(10):1031-4. X-3. [pmid: 17661024].
2563 Yip KF, Tam PK, Li MK. Laparoscopic flip-flap hernioplasty: an innovative technique for pediatric hernia surgery. Surg Endosc. Jul. 2004;18(7):1126-9. X-2, X-3. [pmid: 15162239].
2564 Yoon DJ, Golimbu M, Schinella R, et al. Immunocytochemical localization of hFSH as an index of Sertoli cell function in the human testis. Acta Endocrinol (Copenh). Nov. 1987;116(3):333-8. X-2, X-3. [pmid: 2891236].
2565 Yordam N, Alikasifoglu A, Kandemir N, et al. True hermaphroditism: clinical features, genetic variants and gonadal histology. J Pediatr Endocrinol Metab. Apr. 2001;14(4):421-7. X-3. [pmid: 11327376].
2566 Yoshida K, Kitahara S, Chiba K, et al. Predictive indicators of successful varicocele repair in men with infertility. Int J Fertil Womens Med. Jul–Aug. 2000;45(4):279-84. X-2, X-3. [pmid: 10997484].
2567 Yoshida T, Ohno K, Morotomi Y, et al. Clinical and pathological features of ascending testis. Osaka City Med J. Dec. 2009;55(2):81-7. X-3. [pmid: 20088407].
2568 Younes AK. Low plasma testosterone in varicocele patients with impotence and male infertility. Arch Androl. Nov–Dec. 2000;45(3):187-95. X-2, X-3. [pmid: 11111867].
2569 Younes AK. Improvement of sexual activity, pregnancy rate, and low plasma testosterone after bilateral varicocelectomy in impotence and male infertility patients. Arch Androl. May–Jun. 2003;49(3):219-28. X-2, X-3. [pmid: 12746101].
2570 Young J, Couzinet B, Pholsena M, et al. Plasma 3 beta-hydroxy-delta 5-steroids in patients with congenital adrenal hyperplasia due to 21-hydroxylase deficiency. J Clin Endocrinol Metab. Feb. 1994;78(2):299-304. X-2, X-3. [pmid: 8106615].
2571 Young RH, Koelliker DD, Scully RE. Sertoli cell tumors of the testis, not otherwise specified: a clinicopathologic analysis of 60 cases. Am J Surg Pathol. Jun. 1998;22(6):709-21. X-2, X-3. [pmid: 9630178].
2572 Young RH, Scully RE. Ovarian Sertoli-Leydig cell tumors with a retiform pattern: A problem in histopathologic diagnosis. A report of 25 cases. American Journal of Surgical Pathology. 1983;7(8):755-771. X-2, X-3. [pmid: 6660351].
2573 Youngren KK, Nadeau JH, Matin A. Testicular cancer susceptibility in the 129.MOLF-Chr19 mouse strain: additive effects, gene interactions and epigenetic modifications. Hum Mol Genet. Feb. 15. 2003;12(4):389-98. X-2, X-3. [pmid: 12566386].
2574 Youssef T, Abd-Elaal E, Gaballah G, et al. Varicocelectomy in men with nonobstructive azoospermia: is it beneficial?. Int J Surg. Aug. 2009;7(4):356-60. X-2, X-3. [pmid: 19482096].
2575 Yu TJ. The character of variant persistent mullerian-duct structures. Pediatr Surg Int. Sep. 2002;18(5–6):455-8. X-3. [pmid: 12415380].
2576 Yuan X, Wei G, Lin T, et al. Uncommon pediatric painless scrotal masses: a puzzle of pediatricians and urologists. Int Urol Nephrol. Dec. 2010;42(4):979-84. X-3. [pmid: 20077136].
2577 Yuasa J, Ito H, Toyama Y, et al. Postnatal development of the testis in Japanese children based on observations of undescended testes. Int J Urol. Sep. 2001;8(9):490-4. X-3. [pmid: 11683969].
2578 Yucel S, Celik O, Kol A, et al. Initial pre-scrotal approach for palpable cryptorchid testis: results during a 3-year period. J Urol. Feb. 2011;185(2):669-72. X-4, X-5, X-6. [pmid: 21172700].
2579 Yue Z, Pei Y, Sun L, et al. Clinical pictures and novel mutations of WT1-associated Denys-Drash syndrome in two Chinese children. Renal Failure. October. 2011;33(9):910-914. X-2, X-3. [pmid: 21851196].
2580 Yun YJ, Lee HC, Kim JE, et al. Preliminary analysis of the G178A polymorphism of insulin-like factor 3 in male infertility. Fertil Steril. Dec. 2007;88(6):1706-8. X-3. [pmid: 17559848].
2581 Yunusov MY. Microsurgery of cryptorchidism II: Managing arterial caliber discrepancy. Annals of Plastic Surgery. 1993;31(2):151-153. X-1, X-2, X-3. [pmid: 8105744].
2582 Yunusov MY, Kajumchodzaev AA. Microsurgery of cryptorchidism I: Lengthening the short vas deferens. Annals of Plastic Surgery. 1993;31(2):149-150. X-1, X-2, X-3. [pmid: 8105743].
2583 Yurtcu M, Gunel E, Sahin TK, et al. Effects of fasting and preoperative feeding in children. World Journal of Gastroenterology. 2009;15(39):4919-4922. X-3. [pmid: 19842222].
2584 Zacest AC, Magill ST, Anderson VC, et al. Long-term outcome following ilioinguinal neurectomy for chronic pain. Journal of Neurosurgery. April. 2010;112(4):784-789. X-2, X-3. [pmid: 19780646].
2585 Zachmann M, Tassinari D, Prader A. Clinical and biochemical variability of congenital adrenal hyperplasia due to 11 beta-hydroxylase deficiency. A study of 25 patients. J Clin Endocrinol Metab. Feb. 1983;56(2):222-9. X-3. [pmid: 6296182].
2586 Zafaranloo S, Gerard PS, Wise G. Sonographic assessment of fetal male genitalia. Journal of Diagnostic Medical Sonography. 1991;7(4):205-207. X-2, X-3.
2587 Zagars GK, Babaian RJ. The role of radiation in stage II testicular seminoma. Int J Radiat Oncol Biol Phys. Feb. 1987;13(2):163-70. X-3. [pmid: 3818384].
2588 Zagars GK, Babaian RJ. Stage I testicular seminoma: rationale for postorchiectomy radiation therapy. Int J Radiat Oncol Biol Phys. Feb. 1987;13(2):155-62. X-2, X-3. [pmid: 3818383].
2589 Zampieri N, Dall’Agnola A. Subclinical varicocele and sports: a longitudinal study. Urology. May. 2011;77(5):1199-202. X-2, X-3. [pmid: 21195464].
2590 Zampieri N, Mantovani A, Ottolenghi A, et al. Testicular catch-up growth after varicocelectomy: does surgical technique make a difference?. Urology. Feb. 2009;73(2):289-92. X-2, X-3. [pmid: 18817958].
2591 Zampieri N, Pellegrino M, Ottolenghi A, et al. Effects of bioflavonoids in the management of subclinical varicocele. Pediatr Surg Int. May. 2010;26(5):505-8. X-2, X-3. [pmid: 20162420].
2592 Zampieri N, Zamboni C, Ghidini A, et al. Prenatal sonographic evaluation of male genitalia development. Minerva Ginecol. Aug. 2008;60(4):317-21. X-2, X-3. [pmid: 18560347].
2593 Zampieri N, Zuin V, Burro R, et al. A prospective study in children: Pre- and post-surgery use of vitamin E in surgical incisions. J Plast Reconstr Aesthet Surg. Sep. 2010;63(9):1474-8. X-3. [pmid: 19766552].
2594 Zarrabi AD, Heyns CF. Clamp ablation of the testes compared to bilateral orchiectomy as androgen deprivation therapy for advanced prostate cancer. Int Braz J Urol. May–Jun. 2011;37(3):347-54. discussion 354. X-2, X-3. [pmid: 21756382].
2595 Zarrilli S, Lombardi G, Paesano L, et al. Hormonal and seminal evaluation of Leydig cell tumour patients before and after orchiectomy. Andrologia. May. 2000;32(3):147-54. X-2, X-3. [pmid: 10863969].
2596 Zaupa P, Mayr J, Hollwarth ME. Antegrade scrotal sclerotherapy for treating primary varicocele in children. BJU Int. Apr. 2006;97(4):809-12. X-2, X-3. [pmid: 16536779].
2597 Zenaty D, Dijoud F, Morel Y, et al. Bilateral anorchia in infancy: occurence of micropenis and the effect of testosterone treatment. J Pediatr. Nov. 2006;149(5):687-91. X-2, X-3. [pmid: 17095345].
2598 Zenke U, Jalalian L, Shen S, et al. The difficult MESA: findings from tubuli recti sperm aspiration. J Assist Reprod Genet. Feb. 2004;21(2):31-5. X-2, X-3. [pmid: 15186019].
2599 Zerella JT, McGill LC. Survival of nonpalpable undescended testicles after orchiopexy. J Pediatr Surg. Feb. 1993;28(2):251-3. X-4, X-5, X-6. [pmid: 8094746].
2600 Zheng YQ, Gao X, Li ZJ, et al. Efficacy of bilateral and left varicocelectomy in infertile men with left clinical and right subclinical varicoceles: a comparative study. Urology. Jun. 2009;73(6):1236-40. X-2, X-3. [pmid: 19371942].
2601 Zhengwei Y, Wreford NG, Royce P, et al. Stereological evaluation of human spermatogenesis after suppression by testosterone treatment: heterogeneous pattern of spermatogenic impairment. J Clin Endocrinol Metab. Apr. 1998;83(4):1284-91. X-2, X-3. [pmid: 9543157].
2602 Zhuo Y, Klaen R, Sauter TW, et al. Laparoscopic retroperitoneal lymph node dissection in clinical stage I nonseminomatous germ cell tumor: a minimal invasive alternative. Chin Med J (Engl). Jun. 1998;111(6):537-41. X-2, X-3. [pmid: 11245075].
2603 Zilberman D, Inbar Y, Heyman Z, et al. Torsion of the cryptorchid testis--can it be salvaged?. J Urol. Jun. 2006;175(6):2287-9. discussion 2289. X-3, X-4, X-5, X-6. [pmid: 16697859].
2604 Zilberman D, Winkler H, Kleinmann N, et al. Testicular prosthesis insertion following testicular loss or atrophy during early childhood - Technical aspects and evaluation of patient satisfaction. Journal of Pediatric Urology. Dec. 2007;3(6):461-465. X-3. [pmid: 18947795].
2605 Zingg EJ, Zehntner C. Bilateral testicular germ cell tumors. Prog Clin Biol Res. 1985;203:673-80. X-3. [pmid: 3008188].
2606 Zini A, Buckspan M, Berardinucci D, et al. The influence of clinical and subclinical varicocele on testicular volume. Fertil Steril. Oct. 1997;68(4):671-4. X-2, X-3. [pmid: 9341609].
2607 Zini A, Buckspan M, Berardinucci D, et al. Loss of left testicular volume in men with clinical left varicocele: correlation with grade of varicocele. Arch Androl. Jul–Aug. 1998;41(1):37-41. X-2, X-3. [pmid: 9642459].
2608 Zivkovic D, Hadziselimovic F. Development of Sertoli cells during mini-puberty in normal and cryptorchid testes. Urol Int. 2009;82(1):89-91. X-3, X-4, X-5, X-6. [pmid: 19172104].
2609 Zivkovic D, Varga J, Konstantinidis G, et al. Regional differences in maturation of germ cells of cryptorchid testes: role of environment. Acta Paediatr. Aug. 2009;98(8):1339-43. X-3, X-4, X-5, X-6. [pmid: 19594475].
2610 Zondek LH, Zondek T. Normal and abnormal development of the epididymis of the fetus and infant. Eur J Pediatr. Jun. 1980;134(1):39-44. X-2, X-3. [pmid: 6105963].
2611 Zorba UO, Sanli OM, Tezer M, et al. Effect of infertility duration on postvaricocelectomy sperm counts and pregnancy rates. Urology. Apr. 2009;73(4):767-71. X-2, X-3. [pmid: 19215972].
2612 Zorgniotti AW. Testis temperature, infertility, and the varicocele paradox. Urology. Jul. 1980;16(1):7-10. X-1, X-2, X-3. [pmid: 7395013].
2613 Zornow DH, Landes RR. Scrotal palpation. Am Fam Physician. Jan. 1981;23(1):150-4. X-1, X-2, X-3. [pmid: 6109445].
2614 Zuccarello D, Morini E, Douzgou S, et al. Preliminary data suggest that mutations in the CgRP pathway are not involved in human sporadic cryptorchidism. J Endocrinol Invest. Sep. 2004;27(8):760-4. X-3. [pmid: 15636430].
2615 Zukerberg LR, Young RH, Scully RE. Sclerosing Sertoli cell tumor of the testis. A report of 10 cases. Am J Surg Pathol. Sep. 1991;15(9):829-34. X-2, X-3. [pmid: 1719830].
2616 Zumrutbas AE, Resorlu B, Yesil M, et al. Is the presence of venous reflux really significant in the diagnosis of varicocele?. Int Urol Nephrol. 2008;40(4):983-7. X-2, X-3. [pmid: 18500566].
2617 Zuvela M. The modified Lichtenstein technique for complex inguinal hernia repair--how I do it. Acta Chir Iugosl. 2011;58(1):15-28. X-2, X-3. [pmid: 21630548].
2618 Zwierstra RP, Bleichrodt RP, Suurmeyer AJ. Undescended testes and puberty. Orchidopexia or orchiectomy. Z Kinderchir. Aug. 1984;39(4):255-8. X-3, X-4, X-5, X-6. [pmid: 6149659].

## Excluded During Full Text Review

1 Boys with late descending testes: the source of patients with “retractile” testes undergoing orchidopexy?. Br Med J (Clin Res Ed). Sep. 27. 1986;293(6550):789-90. X-5, X-6, X-7.
2 Effect of corticosteroid creams on descent of testes in infants. John Radcliffe Hospital Cryptorchidism Study Group. BMJ. Jul. 28. 1990;301(6745):214-5. X-5, X-6, X-7. [pmid: 1975507].
3 Timing of elective surgery on the genitalia of male children with particular reference to the risks, benefits, and psychological effects of surgery and anesthesia. American Academy of Pediatrics. Pediatrics. Apr. 1996;97(4):590-4. X-1. [pmid: 8632952].
4 Bibliography. Current world literature. Paediatric urology. Curr Opin Urol. Jul. 2008;18(4):442-5. X-1. [pmid: 18536129].
5 Screening for testicular cancer: Reaffirmation recommendation statement. American Family Physician. August. 15. 2011;84(4):444-445. X-1. [pmid: 21842794].
6 Abd-Alrhman H, Abd-Alkareem A, Ibrahim Ezzat M. Ultrasound localization of undescended testicles. Saudi Medical Journal. [Journal]. 1984;5(4):421-424. X-2.
7 Abyholm T, Oian P, Gordeladze JO. True cryptorchidism and retractile testes in infertile men. Acta Eur Fertil. Jan–Feb. 1986;17(1):15-8. X-4, X-5, X-6, X-7. [pmid: 2873702].
8 Adamsen S, Aronson S, Borjesson B. Prospective evaluation of human chorionic gonadotropin in the treatment of cryptorchidism. Acta Chir Scand. Oct. 1989;155(10):509-14. X-4, X-5, X-6, X-7. [pmid: 2574929].
9 Adiyaman P, Ocal G, Berberoglu M, et al. Plasma testosterone response at 1st and 4th day after short- and long-term hCG stimulation test. Turkish Journal of Pediatrics. Oct. 2004;46(4):309-314. X-4. [pmid: 15641263].
10 Afzal M. Airway management in pediatric anesthesia: laryngeal mask airway vs endotracheal tube. Internet Journal of Anesthesiology. 2007;13(1):6. X-5, X-6, X-7.
11 Aggarwal SK, Sinha SK, Ratan SK, et al. Laparoscopic or laparoscopic-assisted pelvic surgery in small infants: Our experience. Journal of Laparoendoscopic and Advanced Surgical Techniques. 01. Jul. 2011;21(6):543-548. X-4, X-5, X-6. [pmid: 21391829].
12 Akhtar J, Orr JD. Minimally invasive orchidopexy: The transscrotal approach. Minimally Invasive Therapy. 1993;2(3):135-137. X-4, X-5, X-6, X-8.
13 Al-Momani HM. Surgical anatomy of the inguinal canal in children. Annals of Saudi Medicine. July/August. 2006;26(4):300-302. X-5, X-6, X-7. [pmid: 16883087].
14 Alpert PF, Klein RS. Spermatogenesis in the unilateral cryptorchid testis after orchiopexy. J Urol. Feb. 1983;129(2):301-2. X-5, X-6, X-7. [pmid: 6132013].
15 Amati S, Petrini E, Ceresi E, et al. Some ultrastructural aspects of Sertoli cells in cryptorchid man. Boll Soc Ital Biol Sper. Sep. 30. 1983;59(9):1336-42. X-5, X-6, X-7. [pmid: 6138049].
16 Ameh EA, Mbibu HN. Management of undescended testes in children in Zaria, Nigeria. East Afr Med J. Sep. 2000;77(9):485-7. X-4, X-5, X-6. [pmid: 12862139].
17 Andersson KE. This Month in Investigative Urology. Journal of Urology. March. 2009;181(3):940-944. X-1.
18 Ang CW, Forrest J. Diagnostic laparoscopy and management of the impalpable testis--a review of 10 years’ practice at a non-paediatric specialist centre. J Pediatr Urol. Jun. 2008;4(3):214-7. X-4, X-5, X-6. [pmid: 18631929].
19 Arcuri VM, Serrao F, Arcuri PP, et al. Imaging of scrofum in pediatric age: Role of ultrasounds. [Italian, English]. Rivista Italiana di Medicina dell’Adolescenza. May. 2005;3(2 SUPPL 2):9-13. X-1, X-9.
20 Argos Rodriguez MD, Unda Freire A, Ruiz Orpez A, et al. Diagnostic and therapeutic laparoscopy for nonpalpable testis. Surg Endosc. Nov. 2003;17(11):1756-8. X-4, X-5, X-6. [pmid: 12820056].
21 Ariyaprakai W. Single stage repair for severe hypospadias. J Med Assoc Thai. Jan. 1988;71(1):20-4. X-4, X-5, X-6, X-7. [pmid: 2896224].
22 Aso C, Enriquez G, Fite M, et al. Gray-scale and color Doppler sonography of scrotal disorders in children: an update. Radiographics. Sep–Oct. 2005;25(5):1197-214. X-5, X-6, X-7. [pmid: 16160106].
23 Aziz SA, Ahmad M, Singh B. Cryptorchidism. Saudi Medical Journal. 01. Dec. 2002;23(12):1549. X-5, X-6, X-7. [pmid: 12518213].
24 Backhouse KM. Development and descent of the testis. Eur J Pediatr. Dec. 1982;139(4):249-52. X-1. [pmid: 6133750].
25 Baillie CT, Fearns G, Kitteringham L, et al. Management of the impalpable testis: the role of laparoscopy. Arch Dis Child. Nov. 1998;79(5):419-22. X-4, X-5, X-6. [pmid: 10193255].
26 Bakr AA, Kotb M. Laparoscopic orchidopexy: the treatment of choice for the impalpable undescended testis. JSLS. Jul–Sep. 1998;2(3):259-62. X-2. [pmid: 9876750].
27 Banieghbal B, Davies M. Laparoscopic evaluation of testicular mobility as a guide to management of intra-abdominal testes. World J Urol. May. 2003;20(6):343-5. X-4, X-5, X-6. [pmid: 12811493].
28 Banwell PE, Hill AD, Menzies-Gow N, et al. Laparoscopic management of cryptorchidism and associated inguinal hernia. Br J Urol. Aug. 1994;74(2):245-6. X-4, X-5, X-6, X-7. [pmid: 7921945].
29 Bartone FF, Huseman CA, Maizels M, et al. Pitfalls in using human chorionic gonadotropin stimulation test to diagnose anorchia. Journal of Urology. 1984;132(3):563-567. X-5, X-6, X-7, X-8. [pmid: 6236305].
30 Batata MA, Chu FC, Hilaris BS, et al. Testicular cancer in cryptorchids. Cancer. Mar. 1. 1982;49(5):1023-30. X-5, X-6, X-7. [pmid: 6120755].
31 Batata MA, Whitmore WF Jr, Chu FC, et al. Cryptorchidism and testicular cancer. J Urol. Sep. 1980;124(3):382-7. X-5, X-6, X-7. [pmid: 6107388].
32 Beasley S. The undescended testis: Clinical assessment and management pathways. Middle East Paediatrics. Dec. 2006;11(4):104-107. X-1.
33 Beck RO, Nicholl P, Hickey NC, et al. Laparoscopic excision of an intra-abdominal testis. Br J Urol. Jul. 1992;70(1):105-6. X-1, X-4, X-5, X-6. [pmid: 1353395].
34 Beitler JC, Gomes SM, Coelho ACJ, et al. Complex inguinal hernia repairs. Hernia. 2009;13(1):61-66. X-5, X-6, X-7. [pmid: 18843525].
35 Belgorosky A, Rivarola MA. Sex hormone-binding globulin response to human chorionic gonadotropin stimulation in children with cryptorchidism, anorchia, male pseudohermaphroditism, and micropenis. Journal of Clinical Endocrinology and Metabolism. 1982;54(4):698-704. X-5, X-6, X-7. [pmid: 6120946].
36 Bellinger MF. Editorial Comment. Journal of Urology. Oct. 2007;178(4 SUPPLEMENT):1724-1725. X-1.
37 Bellinger MF. Editorial Comment. Journal of Urology. October. 2008;180(4 SUPPL):1808-1809. X-1.
38 Belman AB. Office pediatric urology. Urol Clin North Am. Feb. 1980;7(1):63-77. X-1. [pmid: 6103595].
39 Benson RC Jr, Beard CM, Kelalis PP, et al. Malignant potential of the cryptorchid testis. Mayo Clin Proc. Apr. 1991;66(4):372-8. X-5, X-6, X-7, X-8. [pmid: 1672910].
40 Beomonte Zobel B, Vicentini C, Masciocchi C, et al. Magnetic resonance imaging in the localization of undescended abdominal testes. Eur Urol. 1990;17(2):145-8. X-2. [pmid: 1968834].
41 Bianchi A. management of the impalpable testis. The role of microvascular orchidopexy. Pediatric Surgery International. 1990;5(1):48-57. X-4, X-5, X-6.
42 Bianchi A, Squire BR. Transscrotal orchidopexy: Orchidopexy revised. Pediatric Surgery International. [Journal]. 1989;4(3):189-192. X-4, X-5, X-6.
43 Bibbo M, Gill WB. Screening of adolescents exposed to diethylstilbestrol in utero. Pediatr Clin North Am. May. 1981;28(2):379-88. X-1. [pmid: 6113570].
44 Bilham S. Boy story. Nurs Times. Mar. 16–22. 2000;96(11):30-1. X-1. [pmid: 11310049].
45 Bittencourt DG, Miranda ML, Moreira APP, et al. The role of videolaparoscopy in the diagnostic and therapeutic approach of nonpalpable testis. International Braz J Urol. Jul. 2003;29(4):345-351. X-4, X-5, X-6, X-8. [pmid: 15745560].
46 Bjerklund Johansen TE, Larmo A. Ultrasound in the evaluation of retractile and truly undescended testes. Scand J Urol Nephrol. 1988;22(4):245-50. X-10. [pmid: 2907182].
47 Blanc T, Ayedi A, El-Ghoneimi A, et al. Testicular function and physical outcome in young adult males diagnosed with idiopathic 46 XY disorders of sex development during childhood. Eur J Endocrinol. Dec. 2011;165(6):907-15. X-5, X-6, X-7, X-8. [pmid: 21964959].
48 Blei L, Sihelnik S, Bloom D. Ultrasonographic analysis of chronic intratesticular pathology. Journal of Ultrasound in Medicine. [Journal]. 1983;2(1):17-23. X-5, X-6, X-7.
49 Bloom C, Hamilton P, Cassoff J, et al. Scrotal ultrasonography: a pictorial essay. Can Assoc Radiol J. Feb. 1998;49(1):12-20. X-1. [pmid: 9494459].
50 Boddy SA, Corkery JJ, Gornall P. The place of laparoscopy in the management of the impalpable testis. Br J Surg. Nov. 1985;72(11):918-9. X-4, X-5, X-6. [pmid: 2866013].
51 Boddy SA, Gordon AC, Thomas DF, et al. Experience with the Fowler Stephens and microvascular procedures in the management of intraabdominal testes. Br J Urol. Aug. 1991;68(2):199-202. X-4, X-5, X-6, X-8. [pmid: 1679364].
52 Boeckmann W, Brauers A, Mersdorf A, et al. Diagnostic and therapeutic laparoscopy of the nonpalpable testis. Scand J Urol Nephrol. Dec. 1996;30(6):479-84. X-4, X-5, X-6, X-8. [pmid: 9008029].
53 Bogaert GA, Kogan BA, Mevorach RA. Therapeutic laparoscopy for intra-abdominal testes. Urology. Aug. 1993;42(2):182-8. X-4, X-5, X-6, X-8. [pmid: 8103613].
54 Bollerslev J, Rohl H, Krag Sorensen E, et al. Gonadotropin and androgen levels in patients operated upon for cryptorchidism. Dan Med Bull. Dec. 1986;33(6):336-8. X-4, X-5, X-6, X-7. [pmid: 2878796].
55 Borkenstein M. Intranasal LH-RH for cryptorchidism: response to initial treatment and to treatment after relapse. Eur J Pediatr. Suppl 2. 1987;146:S42-3. X-4, X-5, X-6. [pmid: 2891521].
56 Brendler H. Cryptorchidism and cancer. Prog Clin Biol Res. 1985;203:189-96. X-1. [pmid: 2870507].
57 Brock IJW. Laparoscopic orchidopexy for the nonpalpable testis. Pediatric Endosurgery and Innovative Techniques. 2000;4(3):189-194. X-4, X-5, X-6, X-8.
58 Brock JW 3rd, Holcomb GW 3rd, Morgan WM 3rd. The use of laparoscopy in the management of the nonpalpable testis. J Laparoendosc Surg. Mar. 1996;6(Suppl 1):S35-9. X-4, X-5, X-6, X-8. [pmid: 8832925].
59 Brown RA, Millar AJ, Jee LD, et al. The value of laparoscopy for impalpable testes. S Afr J Surg. May. 1997;35(2):70-3. X-4. [pmid: 9267174].
60 Brown TR, Berkovitz GD, Gearhart JP. Androgen receptors in boys with isolated bilateral cryptorchidism. Am J Dis Child. Sep. 1988;142(9):933-6. X-4, X-5, X-6, X-7. [pmid: 2901218].
61 Bukowski TP, Sedberry S, Richardson B. Is human chorionic gonadotropin useful for identifying and treating nonpalpable testis?. J Urol. Jan. 2001;165(1):221-3. X-4, X-5, X-6, X-8. [pmid: 11125411].
62 Bundak R, Ermis B, Bas F, et al. Comparison of the effect of two modes of hCG stimulation on testicular descent and on plasma testosterone levels in children with true unilateral cryptorchidism. International Pediatrics. Mar. 2007;22(1):8-12. X-4, X-5, X-6, X-7.
63 Burger RA, Hohenfellner R. Are boys with the syndrome of agenesis of the anterior abdominal wall muscles always infertile when they grow up?. Pediatr Nephrol. Apr. 1989;3(2):185. X-1. [pmid: 2577145].
64 Cacciari E, Frejaville E, Becca A. Treatment of cryptorchidism by intranasal synthetic LH-RH and its analogue D-Ser(TBU)6-LHRH-EA10. Eur J Pediatr. Dec. 1982;139(4):280-4. X-10. [pmid: 6133756].
65 Cale AR, Farouk M, Prescott RJ, et al. Does vasectomy accelerate testicular tumour? Importance of testicular examinations before and after vasectomy. BMJ. Feb. 10. 1990;300(6721):370. X-5, X-6, X-7. [pmid: 2106990].
66 Campbell DM, Webb JA, Hargreave TB. Cryptorchidism in Scotland. Br Med J (Clin Res Ed). Nov. 14. 1987;295(6608):1235-6. X-5, X-6, X-7.
67 Canavese F, Cortese MG, Gennari F, et al. Non-palpable testes. Orchiopexy in single stage. Eur J Pediatr Surg. Apr. 1995;5(2):104-5. X-4, X-5, X-6. [pmid: 7612577].
68 Canavese F, Cortese MG, Magro P, et al. Cryptorchidism: medical and surgical treatment in the 1st year of life. Pediatr Surg Int. Nov. 1998;14(1–2):2-5. X-10. [pmid: 9880684].
69 Canavese F, Lalla R, Linari A, et al. Surgical treatment of cryptorchidism. Eur J Pediatr. Suppl 2. 1993;152:S43-4. X-4, X-5, X-6. [pmid: 8101814].
70 Canavese F, Mussa A, Manenti M, et al. Sperm count of young men surgically treated for cryptorchidism in the first and second year of life: fertility is better in children treated at a younger age. Eur J Pediatr Surg. Dec. 2009;19(6):388-91. X-4, X-5, X-6, X-7. [pmid: 19826983].
71 Canning DA. Early orchiopexy: prepubertal intratubular germ cell neoplasia and fertility outcome. J Urol. Jan. 2001;165(1):328-9. X-1. [pmid: 11203491].
72 Caroppo E, Niederberger C, Elhanbly S, et al. Effect of cryptorchidism and retractile testes on male factor infertility: a multicenter, retrospective, chart review. Fertil Steril. May. 2005;83(5):1581-4. X-5, X-6, X-7, X-8. [pmid: 15866613].
73 Carpi A, Fabris GF, Chiechi A, et al. Spermatogenesis in azoospermic, formerly cryptorchid men. Use of needle aspiration techniques. Acta Cytol. Sep–Oct. 2002;46(5):848-54. X-5, X-6, X-7, X-8. [pmid: 12365218].
74 Cartwright PC, Velagapudi S, Snyder HM 3rd, et al. A surgical approach to reoperative orchiopexy. J Urol. Apr. 1993;149(4):817-8. X-4, X-5, X-6. [pmid: 8095992].
75 Casale P, Canning DA. Laparoscopic orchiopexy. BJU Int. Nov. 2007;100(5):1197-206. X-1. [pmid: 17922797].
76 Castilho LN. Laparoscopy for the nonpalpable testis: how to interpret the endoscopic findings. J Urol. Nov. 1990;144(5):1215-8. X-4, X-5, X-6. [pmid: 1977929].
77 Castilho LN, Ferreira U. Laparoscopy in adults and children with nonpalpable testes. Andrologia. Sep–Oct. 1987;19(5):539-43. X-4, X-5, X-6. [pmid: 2892433].
78 Celani MF, Montanini V, Baraghini GF. Bioactive and immunoreactive luteinizing hormone in cryptorchid children. IRCS Medical Science. 1983;11(10):911-912. X-5, X-6, X-7, X-8.
79 Cendron M, Huff DS, Keating MA, et al. Anatomical, morphological and volumetric analysis: a review of 759 cases of testicular maldescent. J Urol. Mar. 1993;149(3):570-3. X-4, X-5, X-6. [pmid: 8094761].
80 Cendron M, Keating MA, Huff DS, et al. Cryptorchidism, orchiopexy and infertility: a critical long-term retrospective analysis. J Urol. Aug. 1989;142(2 Pt 2):559-62. discussion 572. X-4, X-5, X-6. [pmid: 2568506].
81 Chemes HE, Gottlieb SE, Pasqualini T, et al. Response to acute hCG stimulation and steroidogenic potential of Leydig cell fibroblastic precursors in humans. J Androl. Mar–Apr. 1985;6(2):102-12. X-4, X-5, X-6, X-7. [pmid: 3886616].
82 Chin TW, Yeh TJ, Wei CF. Intranasal luteinizing hormone releasing hormone in the treatment of cryptorchism. Journal of Surgical Association Republic of China. [Journal]. 1988;21(4):421-426. X-4, X-5, X-6, X-8.
83 Choi YJ, Reiner L. Autoimmune response following vasectomy. N Y State J Med. May. 1983;83(6):819-22. X-5, X-6, X-7. [pmid: 6575285].
84 Christiansen P, Andersson AM, Skakkebaek NE, et al. Serum inhibin B, FSH, LH and testosterone levels before and after human chorionic gonadotropin stimulation in prepubertal boys with cryptorchidism. Eur J Endocrinol. Jul. 2002;147(1):95-101. X-4, X-5, X-6, X-7. [pmid: 12088925].
85 Christiansen P, Muller J, Buhl S, et al. Hormonal treatment of cryptorchidism--hCG or GnRH--a multicentre study. Acta Paediatr. Aug. 1992;81(8):605-8. X-2. [pmid: 1356527].
86 Chui CH, Jacobsen AS. Laparoscopy in the evaluation of the non-palpable undescended testes. Singapore Med J. May. 2000;41(5):206-8. X-4, X-5, X-6. [pmid: 11063168].
87 Chung JM, Lee CY, Kang DG, et al. Parental perception of optimal surgical age for correction of cryptorchidism: a multicenter surveillance study. Urology. Nov. 2011;78(5):1162-6. X-4, X-5, X-6, X-7. [pmid: 21903244].
88 Cinti S, Barbatelli G, Pierleoni C, et al. The normal, cryptorchid and retractile prepuberal human testis: a comparative morphometric ultrastructural study of 101 cases. Scanning Microsc. Mar. 1993;7(1):351-8. discussion 358–62. X-5, X-6, X-7. [pmid: 8100363].
89 Cisek LJ, Peters CA, Atala A, et al. Current findings in diagnostic laparoscopic evaluation of the nonpalpable testis. J Urol. Sep. 1998;160(3 Pt 2):1145-9. discussion 1150. X-4, X-5, X-6. [pmid: 9719296].
90 Clark DA, Borzi PA. Laparoscopic orchidopexy for the intra-abdominal testis. Pediatr Surg Int. 1999;15(7):454-6. X-4, X-5, X-6. [pmid: 10525896].
91 Cloud DT. Major ambulatory surgery of the pediatric patient. Surg Clin North Am. Aug. 1987;67(4):805-17. X-4, X-5, X-6, X-7. [pmid: 2885930].
92 Cohen Z, Shinhar D, Kurzbart E, et al. Laproscopic and thoracoscopic surgery in children and adolescents: A 3-year experience. Pediatric Surgery International. Jul. 1997;12(5–6):356-359. X-5, X-6, X-7. [pmid: 9244098].
93 Cook B, Grubb DJ, Aldridge LA, et al. Comparison of the effects of adrenaline, clonidine and ketamine on the duration of caudal analgesia produced by bupivacaine in children. Br J Anaesth. Dec. 1995;75(6):698-701. X-4, X-5, X-6, X-7. [pmid: 8672316].
94 Cooper BJ, Little TM. Orchidopexy: theory and practice. Br Med J (Clin Res Ed). Sep. 14. 1985;291(6497):706-7. X-5, X-6, X-7.
95 Coppola CP, Leininger BE, Rasmussen TE, et al. Children treated at an expeditionary military hospital in Iraq. Archives of Pediatrics and Adolescent Medicine. 2006;160(9):972-976. X-4, X-5, X-6, X-7. [pmid: 16953022].
96 Corbally MT, Quinn FJ, Guiney EJ. The effect of two-stage orchiopexy on testicular growth. Br J Urol. Sep. 1993;72(3):376-8. X-4, X-5, X-6, X-8. [pmid: 8106112].
97 Cornud F, Amar E, Hamida K, et al. Ultrasound findings in male hypofertility and impotence. European Radiology. 2001;11(11):2126-2136. X-1. [pmid: 11702152].
98 Cortes D, Thorup J, Frisch M, et al. Examination for intratubular germ cell neoplasia at operation for undescended testis in boys. J Urol. Mar. 1994;151(3):722-5. X-4, X-5, X-6. [pmid: 7905932].
99 Cortes D, Thorup J, Petersen BL. Testicular neoplasia in undescended testes of cryptorchid boys-does surgical strategy have an impact on the risk of invasive testicular neoplasia?. Turk J Pediatr. Suppl. 2004;46:35-42. X-4, X-5, X-6, X-7. [pmid: 15499796].
100 Cortes D, Thorup J, Visfeldt J. Hormonal treatment may harm the germ cells in 1 to 3-year-old boys with cryptorchidism. J Urol. Apr. 2000;163(4):1290-2. X-5, X-6, X-7. [pmid: 10737531].
101 Cortes D, Thorup JM, Lenz K, et al. Laparoscopy in 100 consecutive patients with 128 impalpable testes. Br J Urol. Mar. 1995;75(3):281-7. X-4, X-5, X-6, X-8. [pmid: 7735794].
102 Cortes D, Thorup JM, Lindenberg S. Fertility potential after unilateral orchiopexy: an age independent risk of subsequent infertility when biopsies at surgery lack germ cells. J Urol. Jul. 1996;156(1):217-20. X-4, X-5, X-6, X-7. [pmid: 8648809].
103 Cortes D, Thorup JM, Visfeldt J. Cryptorchidism: aspects of fertility and neoplasms. A study including data of 1,335 consecutive boys who underwent testicular biopsy simultaneously with surgery for cryptorchidism. Horm Res. 2001;55(1):21-7. X-4, X-5, X-6, X-7. [pmid: 11423738].
104 Cortes D, Visfeldt J, Moller H, et al. Testicular neoplasia in cryptorchid boys at primary surgery: case series. BMJ. Oct. 2. 1999;319(7214):888-9. X-4, X-5, X-6, X-7. [pmid: 10506044].
105 Cortes D, Visfeldt J, Thorup JM. Erythropoietin may reduce the risk of germ cell loss in boys with cryptorchidism. Horm Res. 2001;55(1):41-5. X-4, X-5, X-6, X-7. [pmid: 11423742].
106 Coughlin MT, Bellinger MF, LaPorte RE, et al. Testicular suture: a significant risk factor for infertility among formerly cryptorchid men. J Pediatr Surg. Dec. 1998;33(12):1790-3. X-4, X-5, X-6. [pmid: 9869052].
107 Coughlin MT, O’Leary LA, Songer NJ, et al. Time to conception after orchidopexy: evidence for subfertility?. Fertil Steril. Apr. 1997;67(4):742-6. X-4, X-5, X-6. [pmid: 9093204].
108 Creasy DM. Monitoring spermatogenesis. Hum Exp Toxicol. Jan. 1995;14(1):70-1. X-1, X-5, X-6, X-7. [pmid: 7748620].
109 Cross GD, Barrett RF. Comparison of two regional techniques for postoperative analgesia in children following herniotomy and orchidopexy. Anaesthesia. Aug. 1987;42(8):845-9. X-4, X-5, X-6, X-7. [pmid: 2889389].
110 Cuda SP, Srinivasan AK, Kalisvaart J, et al. Evolution of single practice trends in the surgical approach to the undescended testicle. J Urol. Jun. 2011;185(6 Suppl):2451-4. X-4, X-5, X-6. [pmid: 21555009].
111 Czeizel AE, Kazy Z, Vargha P. Oral tinidazole treatment during pregnancy and teratogenesis. International Journal of Gynecology and Obstetrics. Dec. 2003;83(3):305-306. X-5, X-6, X-7. [pmid: 14643044].
112 Czeizel AE, Kazy Z, Vargha P. Vaginal treatment with povidone-iodine suppositories during pregnancy. International Journal of Gynecology and Obstetrics. Jan. 2004;84(1):83-85. X-5, X-6, X-7. [pmid: 14698837].
113 Daghighi MH, Fathi AH, Pourfathi H. Assessment of diagnostic value of sonography for cryptochidism. Journal of Diagnostic Medical Sonography 2006. Jan–Feb. 2006;22(1):42-47. X-10.
114 Dalela D, Sinha RJ, Goel A, et al. Balloon distension of scrotum: a step to facilitate creation of dartos pouch during orchiopexy. Pediatr Surg Int. Apr. 2008;24(4):437-8. X-1. [pmid: 18259763].
115 Danso AP, Nkrumah FK. The challenges of ambiguous genitalia. Cent Afr J Med. Sep. 1992;38(9):367-71. X-5, X-6, X-7. [pmid: 1298565].
116 Das S. Laparoscopic evaluation of nonpalpable testes. Urology. May. 1991;37(5):460-2. X-4, X-5, X-6. [pmid: 1673807].
117 Dave S, Manaboriboon N, Braga LH, et al. Open versus laparoscopic staged Fowler-Stephens orchiopexy: impact of long loop vas. J Urol. Nov. 2009;182(5):2435-9. X-4, X-5, X-6. [pmid: 19765743].
118 Davey RB. Orchidopexy: the relative importance of each step of mobilisation. Pediatr Surg Int. Feb. 1997;12(2–3):163-4. X-4, X-5, X-6.
119 Davis BE, Noble MJ, Weigel JW, et al. Analysis and management of chronic testicular pain. J Urol. May. 1990;143(5):936-9. X-5, X-6, X-7. [pmid: 2329609].
120 Dayanc M, Kibar Y, Irkilata HC, et al. Long-term outcome of scrotal incision orchiopexy for undescended testis. Urology. Oct. 2007;70(4):786-8. discussion 788–9. X-4, X-5, X-6. [pmid: 17991558].
121 Dayanc M, Kibar Y, Tahmaz L, et al. Scrotal incision orchiopexy for undescended testis. Urology. Dec. 2004;64(6):1216-8. discussion 1219. X-4, X-5, X-6. [pmid: 15596200].
122 De Boe V, De Backer A, Braeckman J. Laparoscopy: any indication in the work-up and treatment of undescended testis?. Acta Urol Belg. May. 1995;63(2):89-91. X-1. [pmid: 7785548].
123 de Gouveia Brazao CA, Pierik FH, Erenpreiss Y, et al. The effect of cryptorchidism on inhibin B in a subfertile population. Clin Endocrinol (Oxf). Jul. 2003;59(1):136-41. X-5, X-6, X-7. [pmid: 12807515].
124 de Kretser DM, Kerr JB. The effect of testicular damage on Sertoli and Leydig cell function. Monogr Endocrinol. 1983;25:133-54. X-1. [pmid: 6135153].
125 De la Hunt MN. Paediatric day care surgery: A hidden burden for primary care?. Annals of the Royal College of Surgeons of England. May. 1999;81(3):179-182. X-5, X-6, X-7. [pmid: 10364950].
126 De Luna AM, Ortenberg J, Craver RD. Exploration for testicular remnants: implications of residual seminiferous tubules and crossed testicular ectopia. J Urol. Apr. 2003;169(4):1486-9. X-5, X-6, X-7. [pmid: 12629397].
127 De Rosa G, Della Casa S, Corsello SM, et al. Treatment of undescended testes with hMG and hMG plus hCG: clinical, hormonal and sonographic evaluation. Ann Endocrinol (Paris). 1987;48(6):468-72. X-4, X-5, X-6, X-8. [pmid: 2895604].
128 Delemarre-Van de Waal HA. Induction of testicular growth and spermatogenesis by pulsatile, intravenous administration of gonadotrophin-releasing hormone in patients with hypogonadotrophic hypogonadism. Clin Endocrinol (Oxf). May. 1993;38(5):473-80. X-5, X-6, X-7. [pmid: 8330443].
129 Demirbilek S, Atayurt HF, Celik N, et al. Does treatment with human chorionic gonadotropin induce reversible changes in undescended testes in boys?. Pediatr Surg Int. 1997;12(8):591-4. X-4, X-5, X-6, X-8. [pmid: 9354732].
130 Demircan M, Akinci A, Mutus M. The effects of orchiopexy on serum anti-Mullerian hormone levels in unilateral cryptorchid infants. Pediatr Surg Int. Mar. 2006;22(3):271-3. X-4, X-5, X-6. [pmid: 16463168].
131 Denes FT, Arap MA, Giron AM, et al. Comprehensive surgical treatment of prune belly syndrome: 17 years’ experience with 32 patients. Urology. Oct. 2004;64(4):789-793. X-4, X-5, X-6, X-7. [pmid: 15491721].
132 Denes FT, Silva FAQ, Giron AM, et al. Laparoscopic evaluation and treatment of the impalpable testis. Brazilian Journal of Urology. 2001;27(4):380-385. X-9.
133 Denis L, Pacco J. The diagnostic work-up of the undescended testis. Prog Clin Biol Res. 1985;203:201-6. X-1. [pmid: 2870508].
134 Dickerman Z, Bauman B, Sandovsky U, et al. Human chorionic gonadotropin (hCG) treatment in cryptorchidism. Andrologia. 1983;15(Spec No):542-7. X-4, X-5, X-6. [pmid: 6141747].
135 Diez Pardo JA. Pediatric microsurgery. World Journal of Surgery. 1985;9(2):300-309. X-1. [pmid: 3887772].
136 DiGiacinto TM, Patten D, Willscher M, et al. Sonography of the scrotum. Medical Ultrasound. [Journal]. 1982;6(3):95-101. X-5, X-6, X-7, X-8.
137 Dixon J, Wallace AM, O’Toole S, et al. Prolonged human chorionic gonadotrophin stimulation as a tool for investigating and managing undescended testes. Clinical Endocrinology. Dec. 2007;67(6):816-821. X-5, X-8. [pmid: 17645564].
138 DuBois JJ, Pokorny WJ. A technique for fixation of the mobilized testis in neonatal herniorrhaphy. Pediatric Surgery International. 1993;8(1):94-95. X-1.
139 Dunn JCY, Kawaguchi AL, Fonkalsrud EW. Undescended testes/orchiopexy. Operative Techniques in General Surgery. Dec. 2004;6(4 SPEC. ISS):269-280. X-1.
140 Eiholzer U, l’Allemand D, Rousson V, et al. Hypothalamic and gonadal components of hypogonadism in boys with Prader-Labhart- Willi syndrome. J Clin Endocrinol Metab. Mar. 2006;91(3):892-8. X-5, X-6, X-7. [pmid: 16352691].
141 El Zoghbi CS, Favorito LA, Costa WS, et al. Structural analysis of gubernaculum testis in cryptorchid patients submitted to treatment with human chorionic gonadotrophin. Int Braz J Urol. Mar–Apr. 2007;33(2):223-9. discusson 230. X-4, X-5, X-6, X-8. [pmid: 17488543].
142 El-Anany F, Gad El-Moula M, Abdel Moneim A, et al. Laparoscopy for impalpable testis: Classification-based management. Surgical Endoscopy. Mar. 2007;21(3):449-454. X-4. [pmid: 17054004].
143 Elder JS. Measurements of serum Mullerian inhibiting substance in the evaluation of children with nonpalpable gonads. J Urol. Oct. 1997;158(4):1637. X-1. [pmid: 9302191].
144 Elder JS. Bilateral neonatal testicular torsion. J Urol. Apr. 1998;159(4):1413-4. X-1.
145 Elder JS. Ultrasonography is unnecessary in evaluating boys with a nonpalpable testis. Pediatrics. Oct. 2002;110(4):748-51. X-10. [pmid: 12359789].
146 Erez I, Schneider N, Glaser E, et al. Prompt diagnosis of ‘acute groin’ conditions in infants. Eur J Radiol. Oct. 1992;15(3):185-9. X-5, X-6, X-7. [pmid: 1362701].
147 Esposito C, Garipoli V. The value of 2-step laparoscopic Fowler-Stephens orchiopexy for intra-abdominal testes. J Urol. Nov. 1997;158(5):1952-4. discussion 1954–5. X-4, X-5, X-6, X-7. [pmid: 9334647].
148 Esposito C, Lima M, Mattioli G, et al. Complications of pediatric urological laparoscopy: mistakes and risks. J Urol. Apr. 2003;169(4):1490-2. discussion 1492. X-4, X-5, X-6, X-7. [pmid: 12629398].
149 Fait G, Yaron Y, Shenhar D, et al. Sonographic detection of undescended testes in the third trimester. J Ultrasound Med. Jan. 2002;21(1):15-8. quiz 20. X-5, X-6, X-7, X-8. [pmid: 11794397].
150 Fallon B, Kennedy TJ. Long-term follow-up of fertility in cryptorchid patients. Urology. May. 1985;25(5):502-4. X-4. [pmid: 2859682].
151 Farley SJ. Surveillance or biopsy for men with testicular microlithiasis?. Nature Reviews Urology. September. 2010;7(9):478. X-1.
152 Favorito LA, Costa WS, Sampaio FJ. Analysis of anomalies of the epididymis and processus vaginalis in human fetuses and in patients with cryptorchidism treated and untreated with human chorionic gonadotrophin. BJU Int. Oct. 2006;98(4):854-7. X-10. [pmid: 16978284].
153 Favorito LA, Toledo Fo JS. Study of testicular migration after treatment with human chorionic gonadotropin in patients with cryptorchidism. Brazilian Journal of Urology. 2001;27(3):270-274. X-9.
154 Fedder J, Boesen M. Effect of a combined GnRH/hCG therapy in boys with undescended testicles: evaluated in relation to testicular localization within the first week after birth. Arch Androl. May–Jun. 1998;40(3):181-6. X-4. [pmid: 9583356].
155 Fedder J, Hansen LG, Hjort T. Reduced level of sex-specific antigen (H-Y antigen) on lymphocytes in some patients with bilateral cryptorchidism. Arch Androl. 1989;22(1):67-75. X-5, X-6, X-7. [pmid: 2565709].
156 Fento EJM, Woodward AA, Hudson IL, et al. The ascending testis. Pediatric Surgery International. 1990;5(1):6-9. X-4, X-5, X-6.
157 Ferlin A, Zuccarello D, Zuccarello B, et al. Genetic alterations associated with cryptorchidism. JAMA. Nov. 19. 2008;300(19):2271-6. X-5, X-6, X-7. [pmid: 19017913].
158 Ferreira U, Cassiano Esteves S, Nogueira Castilho L, et al. Laparoscopy in the management of nonpalpable testes and intersex states. Arch Esp Urol. Sep. 1993;46(7):638-41. X-4, X-5, X-6, X-7. [pmid: 7902071].
159 Ferro F, Inon A, Caterino S, et al. Staged orchidopexy: simplifying the second stage. Pediatric Surgery International. 1990;5(1):10-12. X-4, X-5, X-6, X-8.
160 Ferro F, Lais A, Bagolan P, et al. Impact of primary surgical approach in the management of the impalpable testis. Eur Urol. 1992;22(2):142-6. X-4, X-5, X-6. [pmid: 1362154].
161 Ferro F, Lais A, Gonzalez-Serva L. Benefits and afterthoughts of laparoscopy for the nonpalpable testis. J Urol. Aug. 1996;156(2 Pt 2):795-8. discussion 798. X-10. [pmid: 8683786].
162 Findlow D, Aldridge LM, Doyle E. Comparison of caudal block using bupivacaine and ketamine with ilioinguinal nerve block for orchidopexy in children. Anaesthesia. Nov. 1997;52(11):1110-3. X-4, X-5, X-6. [pmid: 9404178].
163 Flett ME, Jones PF, Youngson GG. Emerging trends in the management of the impalpable testis. Br J Surg. Oct. 1999;86(10):1280-3. X-4, X-5, X-6, X-8. [pmid: 10540133].
164 Fonkalsrud EW. The role and timing of surgery for cryptorchidism. Aust N Z J Surg. Oct. 1984;54(5):431-4. X-1. [pmid: 6152391].
165 Fonkalsrud EW. Testicular undescent and torsion. Pediatr Clin North Am. Oct. 1987;34(5):1305-17. X-1. [pmid: 2889181].
166 Foresta C, Ferlin A, Garolla A, et al. Functional and cytologic features of the contralateral testis in cryptorchidism. Fertil Steril. Oct. 1996;66(4):624-9. X-10. [pmid: 8816628].
167 Forte F, Bitelli M, Sorrenti S, et al. Testicular fixation in adult retractile testis: technical notes. Chir Ital. Jan–Feb. 2003;55(1):145-7. X-4, X-5, X-6, X-7. [pmid: 12633055].
168 Fossa SD, Klepp O, Molne K, et al. Testicular function after unilateral orchiectomy for cancer and before further treatment. Int J Androl. Apr. 1982;5(2):179-84. X-5, X-6, X-7. [pmid: 7107033].
169 Fossa SD, Ous S. Primary unilateral retroperitoneal lymph node dissection (RLND) in non-seminomatous testicular cancer. Prog Clin Biol Res. 1985;203:319. X-5, X-6, X-7. [pmid: 3832089].
170 Frederick LR, Ballek NK, Esplin JA, et al. Primary carcinoid tumor presenting as a nonpalpable testicular mass. J Clin Oncol. Nov. 1. 2010;28(31):e637-9. X-1, X-5, X-6, X-7. [pmid: 20855827].
171 Freedman AL. Prenatal scrotal ultrasound: providing new clues in cryptorchidism. Ultrasound Obstet Gynecol. Apr. 1998;11(4):240. X-1. [pmid: 9618843].
172 Freud E, Zer M. Minimally invasive surgery in pediatric endocrinology. Journal of Pediatric Endocrinology and Metabolism. 2000;13(3):241-244. X-1. [pmid: 10714748].
173 Frick J. LHRH and cryptorchidism. Eur J Pediatr. Suppl 2. 1993;152:S28-30. X-4, X-5, X-6, X-8. [pmid: 8101808].
174 Frick J, Danner C, Kunit G, et al. The effect of chronic administration of a synthetic LH-RH analogue intranasally in cryptorchid boys. Int J Androl. Oct. 1980;3(5):469-78. X-4, X-5, X-6, X-8. [pmid: 6108293].
175 Friedland GW, Chang P. The role of imaging in the management of the impalpable undescended testis. AJR Am J Roentgenol. Dec. 1988;151(6):1107-11. X-1. [pmid: 2903643].
176 Fritzsche PJ. MRI of the scrotum. Urol Radiol. 1988;10(1):52-7. X-1. [pmid: 2900570].
177 Fritzsche PJ, Hricak H, Kogan BA, et al. Undescended testis: value of MR imaging. Radiology. Jul. 1987;164(1):169-73. X-2, X-8. [pmid: 2884693].
178 Froeling FM, Sorber MJ, de la Rosette JJ, et al. The nonpalpable testis and the changing role of laparoscopy. Urology. Feb. 1994;43(2):222-7. X-4, X-5, X-6, X-7. [pmid: 7906906].
179 Fryczkowski M, Paradysz A, Krauze-Balwinska Z. Late results of operative treatment of intersexuality in children with advanced hypospadias and simultaneous cryptorchidism. Int Urol Nephrol. 1996;28(2):241-5. X-4, X-5, X-6, X-7. [pmid: 8836797].
180 Fukuzaki A, Tanahashi Y, Orikasa S, et al. Laparoscopic examination for nonpalpable testes. Japanese Journal of Endourology and ESWL. 1990;3(1):66-69. X-4, X-5, X-6, X-8.
181 Gadiyar V, Gallagher TM, Crean PM, et al. The effect of a combination of rectal diclofenac and caudal bupivacaine on postoperative analgesia in children. Anaesthesia. Sep. 1995;50(9):820-2. X-5, X-6, X-7. [pmid: 7573879].
182 Gaines KK. Human chorionic gonadotropin use in undescended testicle and infertility. Urol Nurs. Jun. 2005;25(3):212-3. X-1. [pmid: 16050353].
183 Galli P, Bartolini E, Franchi F, et al. Treatment of cryptorchidism by intramuscular administration of LHRH. Reproduccion. Jul–Sep. 1980;4(3):247-54. X-4, X-5, X-6, X-8. [pmid: 6109680].
184 Garagorri JM, Job JC, Canlorbe P, et al. Results of early treatment of cryptorchidism with human chorionic gonadotropin. J Pediatr. Dec. 1982;101(6):923-7. X-4, X-5, X-6. [pmid: 6128381].
185 Garel L, Lucaya J, Piqueras J. Clinical quiz. Torsion of an intra-abdominal benign testicular teratoma. Pediatr Radiol. Feb. 2004;34(2):183-4. X-1. [pmid: 15046121].
186 Garg SK, Yopadhyay PK, Ram B. Gonadotrophin stimulation in children with abnormal sexual development. S Afr Med J. Sep. 2. 1989;76(5):199-201. X-4, X-5, X-6, X-7. [pmid: 2570464].
187 Gatti JM, Cooper CS, Kirsch AJ. Bimanual digital rectal examination for the evaluation of the nonpalpable testis. J Urol. Jul. 2003;170(1):207-10. X-5, X-6, X-7. [pmid: 12796691].
188 Gaur DD. Laparoscopic orchidopexy: a simple technique for establishing the abdominoscrotal port. Br J Urol. Dec. 1994;74(6):793-4. X-1. [pmid: 7827854].
189 Gesino A, Bachmann De, Santos ME. Spermatic cord torsion after testicular fixation. A different surgical approach and a revision of current techniques. Eur J Pediatr Surg. Dec. 2001;11(6):404-10. X-4, X-5, X-6. [pmid: 11807671].
190 Ghirri P, Ciulli C, Vuerich M, et al. Incidence at birth and natural history of cryptorchidism: a study of 10,730 consecutive male infants. J Endocrinol Invest. Sep. 2002;25(8):709-15. X-5, X-6, X-7. [pmid: 12240903].
191 Giannopoulos MF, Vlachakis IG, Charissis GC. 13 Years’ experience with the combined hormonal therapy of cryptorchidism. Horm Res. 2001;55(1):33-7. X-4, X-5, X-6. [pmid: 11423740].
192 Gibbs TD. Cryptorchidism and orchiopexy--part I. AUAAJ. Oct–Dec. 1983;4(2):4-9. X-1.
193 Gibbs TD. Cryptorchidism and orchiopexy--part II. AUAAJ. Jan–Mar. 1984;4(3):5-10. X-1.
194 Gill B, Kogan S, Starr S, et al. Significance of epididymal and ductal anomalies associated with testicular maldescent. J Urol. Aug. 1989;142(2 Pt 2):556-8. discussion 572. X-4, X-6, X-7. [pmid: 2568505].
195 Gill IS. Needlescopic urology: current status. Urol Clin North Am. Feb. 2001;28(1):71-83. X-4, X-5, X-6, X-7. [pmid: 11277071].
196 Girard J, Hadziselimovic F. Relevance of urinary gonadotrophins. Eur J Pediatr. Suppl 2. 1987;146:S18-20. X-5, X-6, X-7, X-8. [pmid: 2891512].
197 Giwercman A, Berthelsen JG, Muller J, et al. Carcinoma-in-situ of the cryptorchid testis. Prog Clin Biol Res. 1985;203:177-88. X-1, X-5, X-6, X-7. [pmid: 2870506].
198 Giwercman A, Bruun E, Frimodt-Moller C, et al. Prevalence of carcinoma in situ and other histopathological abnormalities in testes of men with a history of cryptorchidism. J Urol. Oct. 1989;142(4):998-1001. discussion 1001–2. X-4, X-5, X-6, X-7. [pmid: 2571738].
199 Giwercman A, Clausen OP, Bruun E, et al. The value of quantitative DNA flow cytometry of testicular fine-needle aspirates in assessment of spermatogenesis: a study of 137 previously maldescended human testes. Int J Androl. Feb. 1994;17(1):35-42. X-5, X-6, X-7. [pmid: 7911790].
200 Giwercman A, Grindsted J, Hansen B, et al. Testicular cancer risk in boys with maldescended testis: a cohort study. J Urol. Nov. 1987;138(5):1214-6. X-5, X-6, X-7. [pmid: 2889833].
201 Glassberg KI. Annual meeting of the section on pediatric urology. Pediatrics. [Journal]. 1987;80(1):111-117. X-1.
202 Goblyos P, Szule E Jr. Liquid crystal thermography in the localization of undescended testicles. Eur J Radiol. Nov. 1987;7(4):266-7. X-2. [pmid: 2891507].
203 Godbole PP, Morecroft JA, Mackinnon AE. Laparoscopy for the impalpable testis. Br J Surg. Oct. 1997;84(10):1430-2. X-5, X-6, X-7, X-8. [pmid: 9361605].
204 Godbole PP, Najmaldin AS. Laparoscopic orchidopexy in children. J Endourol. Apr. 2001;15(3):251-6. X-1. [pmid: 11339390].
205 Goede J, Hack WW, van der Voort-Doedens LM, et al. Testicular microlithiasis in boys and young men with congenital or acquired undescended (ascending) testis. J Urol. Apr. 2010;183(4):1539-43. X-5, X-6, X-7. [pmid: 20172540].
206 Goede J, Van Der Voort-Doedens LM, Sijstermans K, et al. The volume of retractile testes. Journal of Urology. November. 2011;186(5):2050-2054. X-5, X-6, X-7. [pmid: 21944090].
207 Goh DW, Hutson JM. The retractile testis: time for a reappraisal. J Paediatr Child Health. Dec. 1993;29(6):407-8. X-1. [pmid: 7904474].
208 Gokce MO, Burgu B, Aydogdu O, et al. Transverse testicular ectopia associated with persistent mulllerian duct syndrome: Another entity in which magnetic resonance imaging is unreliable. Urology. December. 2010;76(6):1457-1461. X-5, X-6, X-7, X-8. [pmid: 20970837].
209 Gokcora IH, Yagmurlu A. A longitudinal follow-up using the high trans-scrotal approach for inguinal and scrotal abnormalities in boys. Hernia. Dec. 2003;7(4):181-184. X-4, X-5, X-6, X-7. [pmid: 12802619].
210 Gokhale S. High resolution ultrasonography of the anterior abdominal wall. Indian Journal of Radiology and Imaging. 01. Nov. 2007;17(4):290-298. X-1.
211 Golabek T, Kiely E. Patterns of referral and treatment of undescended testis: a 12-year experience in a single centre. Ir J Med Sci. Dec. 2010;179(4):511-4. X-4, X-5, X-6, X-8. [pmid: 20721694].
212 Golan DT, Shmuel S, Bar-Maor JA. Autoimmune reaction in cryptorchidism?. Z Kinderchir. Jan. 1981;32(1):79-83. X-4, X-5, X-6, X-7. [pmid: 6116368].
213 Gomez Leon MN, Ferreiros J, Casanova R, et al. The value of computed tomography in the localization of undescended testes. Eur J Radiol. Nov. 1986;6(4):283-7. X-8. [pmid: 2878804].
214 Gomez-Perez R, Osuna JA, Arata-Bellabarba G. Surgical vs. untreated cryptorchidism: effects on fertility. Arch Androl. Jan–Feb. 2004;50(1):19-22. X-2, X-10. [pmid: 14660166].
215 Govan DE, Kessler R. Urologic problems in the adolescent male. Pediatr Clin North Am. Feb. 1980;27(1):109-24. X-1. [pmid: 6103528].
216 Govender D, Sing Y, Chetty R. Sertoli cell nodules in the undescended testis: a histochemical, immunohistochemical, and ultrastructural study of hyaline deposits. J Clin Pathol. Aug. 2004;57(8):802-6. X-5, X-6, X-7. [pmid: 15280399].
217 Gracia J, Gonzalez N, Gomez ME, et al. Clinical and anatomopathological study of 2000 cryptorchid testes. Br J Urol. Jun. 1995;75(6):697-701. X-5, X-6, X-7. [pmid: 7613821].
218 Gracia J, Navarro E, Guirado F, et al. Spontaneous ascent of the testis. Br J Urol. Jan. 1997;79(1):113-5. X-4, X-5, X-6, X-7. [pmid: 9043508].
219 Gracia J, Sanchez J, Garcia C, et al. What is the relationship between spermatozoa per milliliter at adulthood and the tubular fertility index at surgical age for patients with cryptorchidism?. J Pediatr Surg. Apr. 1998;33(4):594-6. X-4, X-5, X-6, X-7. [pmid: 9574758].
220 Gracia J, Sanchez Zalabardo J, Sanchez Garcia J, et al. Clinical, physical, sperm and hormonal data in 251 adults operated on for cryptorchidism in childhood. BJU Int. Jun. 2000;85(9):1100-3. X-4, X-5, X-6, X-7. [pmid: 10848704].
221 Graif M, Czerniak A, Avigad I, et al. High-resolution sonography of the undescended testis in childhood: an analysis of 45 cases. Isr J Med Sci. Jul. 1990;26(7):382-5. X-2. [pmid: 1974893].
222 Grasso M, Buonaguidi A, Lania C, et al. Postpubertal cryptorchidism: review and evaluation of the fertility. Eur Urol. 1991;20(2):126-8. X-4, X-5, X-6, X-8. [pmid: 1684324].
223 Gray J. Undescended testes. N Z Nurs J. Jan. 1981;74(1):6. X-1. [pmid: 6111775].
224 Guar DD, Agarwal DK, Purohit KC, et al. Laparoscopic orchiopexy for the intra-abdominal testis. J Urol. Feb. 1995;153(2):479-81. X-4, X-5, X-6. [pmid: 7815627].
225 Gueugniaud PY, Abisseror M, Moussa M, et al. The hemodynamic effects of pneumoperitoneum during laparoscopic surgery in healthy infants: assessment by continuous esophageal aortic blood flow echo-Doppler. Anesth Analg. Feb. 1998;86(2):290-3. X-4, X-5, X-6, X-7. [pmid: 9459234].
226 Guiney EJ, Corbally M, Malone PS. Laparoscopy and the management of the impalpable testis. Br J Urol. Mar. 1989;63(3):313-6. X-4, X-5, X-6. [pmid: 2564795].
227 Gulanikar AC, Anderson PA, Schwarz R, et al. Impact of diagnostic laparoscopy in the management of the unilateral impalpable testis. Br J Urol. Mar. 1996;77(3):455-7. X-4, X-5, X-6. [pmid: 8814857].
228 Guminska A, Slowikowska-Hilczer J, Kuzanski W, et al. Features of impaired seminiferous tubule differentiation are associated with germ cell neoplasia in adult men surgically treated in childhood because of cryptorchidism. Folia Histochem Cytobiol. Suppl 1. 2007;45:S163-8. X-4, X-5, X-6, X-7. [pmid: 18292827].
229 Gutierrez CS. Cryptorchidism. West J Med. Jul. 1995;163(1):67-8. X-1. [pmid: 7667988].
230 Guven A, Kogan BA. Undescended testis in older boys: further evidence that ascending testes are common. J Pediatr Surg. Sep. 2008;43(9):1700-4. X-4, X-5, X-6, X-7. [pmid: 18779010].
231 Gyawali B, Bhattacharyya S, Reid JA. Medical audit of community screening for undescended testes in Halton District. Public Health. Sep. 1993;107(5):343-7. X-4, X-5, X-6, X-7. [pmid: 7902589].
232 Hack WW, Meijer RW, Van Der Voort-Doedens LM, et al. Previous testicular position in boys referred for an undescended testis: further explanation of the late orchidopexy enigma?. BJU Int. Aug. 2003;92(3):293-6. X-5, X-6, X-7. [pmid: 12887487].
233 Hack WW, Meijer RW, van der Voort-Doedens LM, et al. Natural course of acquired undescended testis in boys. Br J Surg. Jun. 2003;90(6):728-31. X-4, X-5, X-6, X-8. [pmid: 12808623].
234 Hack WW, Sijstermans K, van der Voort-Doedens LM, et al. The high scrotal (“gliding”) testis revised. Eur J Pediatr. Jan. 2007;166(1):57-61. X-4, X-5, X-6, X-7. [pmid: 16896645].
235 Hack WW, Sijstermans K, van Dijk J, et al. Prevalence of acquired undescended testis in 6-year, 9-year and 13-year-old Dutch schoolboys. Arch Dis Child. Jan. 2007;92(1):17-20. X-5, X-6, X-7. [pmid: 16905567].
236 Hack WW, van der Voort-Doedens LM, Goede J, et al. Natural history and long-term testicular growth of acquired undescended testis after spontaneous descent or pubertal orchidopexy. BJU Int. Oct. 2010;106(7):1052-9. X-5, X-6, X-7, X-8. [pmid: 20151964].
237 Hack WW, van der Voort-Doedens LM, Sijstermans K, et al. Reduction in the number of orchidopexies for cryptorchidism after recognition of acquired undescended testis and implementation of expectative policy. Acta Paediatr. Jun. 2007;96(6):915-8. X-4, X-5, X-6, X-7. [pmid: 17537024].
238 Hadziselimovic F. Pathogenesis and treatment of undescended testes. Eur J Pediatr. Dec. 1982;139(4):255-65. X-1, X-5, X-8. [pmid: 6133752].
239 Hadziselimovic F. Treatment of cryptorchidism with GnRH. Urol Clin North Am. Oct. 1982;9(3):413-20. X-10. [pmid: 6128825].
240 Hadziselimovic F. Hormonal regulation of testicular descent and maldescent. Prog Clin Biol Res. 1985;203:167-76. X-1. [pmid: 2870505].
241 Hadziselimovic F. Hormonal treatment of the undescended testes. Journal of Pediatric Endocrinology. [Journal]. 1986;2(1):1-5. X-1.
242 Hadziselimovic F. Testicular and vascular changes in patients with varicocele. Acta Urol Belg. May. 1995;63(2):51-4. X-5, X-6, X-7. [pmid: 7785541].
243 Hadziselimovic F. Early successful orchidopexy does not prevent from developing azoospermia. Int Braz J Urol. Sep–Oct. 2006;32(5):570-3. X-4, X-5, X-6, X-7. [pmid: 17081328].
244 Hadziselimovic F, Girard J, Herzog B, et al. Hormonal treatment of cryptorchidism. Horm Res. 1982;16(3):188-92. X-4. [pmid: 6125464].
245 Hadziselimovic F, Girard J, Hocht B, et al. Effect of LH-RH treatment on hypothalamo-pituitary-gonadal axis and Leydig cell ultrastructure in cryptorchid boys. Horm Res. 1980;13(6):358-66. X-10. [pmid: 6115808].
246 Hadziselimovic F, Hecker E, Herzog B. The value of testicular biopsy in cryptorchidism. Urol Res. 1984;12(3):171-4. X-5, X-6, X-7. [pmid: 6148798].
247 Hadziselimovic F, Herzog B. Cryptorchidism. Pediatric Surgery International. [Journal]. 1987;2(3):132-141. X-1.
248 Hadziselimovic F, Herzog B. Long-term effect of a luteinizing-hormone-releasing hormone analogue (buserelin) on cryptorchid testes (extended summary). Horm Res. 1988;30(4–5):210. discussion 211. X-1. [pmid: 2907900].
249 Hadziselimovic F, Herzog B. Importance of early postnatal germ cell maturation for fertility of cryptorchid males. Horm Res. 2001;55(1):6-10. X-4, X-5, X-6, X-7. [pmid: 11423735].
250 Hadziselimovic F, Herzog B, Buser M. Development of cryptorchid testes. Eur J Pediatr. Suppl 2. 1987;146:S8-12. X-4, X-5, X-6, X-7. [pmid: 2891529].
251 Hadziselimovic F, Herzog B, Emmons LR. The incidence of seminoma and expression of cell adhesion molecule CD44 in cryptorchid boys and infertile men. J Urol. May. 1997;157(5):1895-7. X-4, X-5, X-6, X-7. [pmid: 9112558].
252 Hadziselimovic F, Herzog B, Hocht B, et al. Screening for cryptorchid boys risking sterility and results of long-term buserelin treatment after successful orchiopexy. Eur J Pediatr. Suppl 2. 1987;146:S59-62. X-5, X-6, X-7, X-8. [pmid: 2891527].
253 Hadziselimovic F, Herzog B, Huff DS, et al. The morphometric histopathology of undescended testes and testes associated with incarcerated inguinal hernia: a comparative study. J Urol. Aug. 1991;146(2 ( Pt 2)):627-9. X-4, X-5, X-6, X-7. [pmid: 1677688].
254 Hadziselimovic F, Hocht B, Herzog B, et al. Infertility in cryptorchidism is linked to the stage of germ cell development at orchidopexy. Horm Res. 2007;68(1):46-52. X-4, X-5, X-6, X-8. [pmid: 17356291].
255 Hadziselimovic F, Hoecht B. Testicular histology related to fertility outcome and postpubertal hormone status in cryptorchidism. Klin Padiatr. Sep–Oct. 2008;220(5):302-7. X-4, X-5, X-6, X-7. [pmid: 18401814].
256 Hadziselimovic F, Huff D, Duckett J, et al. Long-term effect of luteinizing hormone-releasing hormone analogue (buserelin) on cryptorchid testes. J Urol. Oct. 1987;138(4 Pt 2):1043-5. X-4, X-5, X-6, X-8. [pmid: 2888905].
257 Hadziselimovic F, Huff D, Duckett J, et al. Treatment of cryptorchidism with low doses of buserelin over a 6-months period. Eur J Pediatr. Suppl 2. 1987;146:S56-8. X-4, X-5, X-6, X-7. [pmid: 2891526].
258 Hadziselimovic F, Snyder HM, Huff DS. An unusual subset of cryptorchidism: possible end organ failure. J Urol. Sep. 1999;162(3 Pt 2):983-5. X-4, X-5, X-6, X-7. [pmid: 10458416].
259 Hadziselimovic F, Zivkovic D, Bica DT, et al. The importance of mini-puberty for fertility in cryptorchidism. J Urol. Oct. 2005;174(4 Pt 2):1536-9. discussion 1538–9. X-10. [pmid: 16148647].
260 Haertig A, Leo JP, de Fourmestraux N, et al. Clinical features of testicular tumours. Prog Clin Biol Res. 1985;203:221-5. X-5, X-6, X-7. [pmid: 2870511].
261 Hafez ESE, Ghaly IM, Ibrahim II. Endocrine profiles in pediatric andrology. III. Human chorionic gonadotropin stimulation test in cryptorchid boys. Archives of Andrology. 1983;11(1):53-58. X-5, X-6, X-7. [pmid: 6138004].
262 Hagberg S, Westphal O. Results of combined hormonal and surgical treatment for undescended testis in boys under 3 years of age. A randomized study. Eur J Pediatr. Suppl 2. 1987;146:S38-9. X-10. [pmid: 2891519].
263 Haimov-Kochman R, Prus D, Farchat M, et al. Reproductive outcome of men with azoospermia due to cryptorchidism using assisted techniques. Int J Androl. Feb. 2010;33(1):e139-43. X-4, X-5, X-6, X-7. [pmid: 19622071].
264 Hallak J, Cocuzza M, Sarkis AS, et al. Organ-sparing microsurgical resection of incidental testicular tumors plus microdissection for sperm extraction and cryopreservation in azoospermic patients: surgical aspects and technical refinements. Urology. Apr. 2009;73(4):887-91. discussion 891–2. X-4, X-5, X-6, X-7. [pmid: 19201456].
265 Hammar M, Berg AA, Mathson K, et al. Influence of hCG treatment on the metabolism of progesterone and pregnenolone in vitro by the human undescended prepubertal testis. Int J Androl. Oct. 1987;10(5):647-52. X-5, X-6, X-7, X-8. [pmid: 2891621].
266 Hamza AF, Elrahim M, Elnagar, et al. Testicular descent: when to interfere?. Eur J Pediatr Surg. Jun. 2001;11(3):173-6. X-5, X-6, X-7. [pmid: 11475113].
267 Han SW, Lee T, Kim JH, et al. Pathological difference between retractile and cryptorchid testes. J Urol. Sep. 1999;162(3 Pt 1):878-80. X-4, X-5, X-6, X-7. [pmid: 10458400].
268 Han WK, Kim JH, Hong CH, et al. Structural evidence against hormonal therapy for cryptorchid testis: abnormal gubernacular attachment. J Urol. Jun. 2004;171(6 Pt 1):2427-9. X-4, X-5, X-6, X-7. [pmid: 15126868].
269 Handa R, Kale R, Harjai M, et al. Single scrotal incision orchiopexy for palpable undescended testis. Asian J Surg. Jan. 2006;29(1):25-7. X-4, X-5, X-6, X-7. [pmid: 16428094].
270 Handa R, Kale R, Harjai MM. Laparoscopic orchiopexy: is closure of the internal ring necessary?. J Postgrad Med. Oct–Dec. 2005;51(4):266-7. discussion 268. X-5, X-6, X-7, X-8. [pmid: 16388167].
271 Hannallah RS, Broadman LM, Belman AB, et al. Comparison of caudal and ilioinguinal/iliohypogastric nerve blocks for control of post-orchiopexy pain in pediatric ambulatory surgery. Anesthesiology. Jun. 1987;66(6):832-4. X-4, X-5, X-6, X-7. [pmid: 2884900].
272 Harland SJ, Rapley EA, Nicholson PW. Do all patients with bilateral testis cancer have a hereditary predisposition?. Int J Androl. Aug. 2007;30(4):251-5. discussion 255. X-1, X-5, X-6, X-7. [pmid: 17705806].
273 Harrison CB, Kaplan GW, Scherz HC, et al. Microvascular autotransplantation of the intra-abdominal testis. J Urol. Aug. 1990;144(2 Pt 2):506-7. discussion 512–3. X-4, X-5, X-6. [pmid: 1973739].
274 Hassan ME, Mustafawi A. Laparoscopic management of impalpable testis in children, new classification, lessons learned, and rare anomalies. J Laparoendosc Adv Surg Tech A. Apr. 2010;20(3):265-9. X-4, X-5, X-6. [pmid: 20059389].
275 Hauffa BP. Why early surgery may not be enough: the search for new therapeutic strategies in cryptorchidism. Klin Padiatr. Sep–Oct. 2008;220(5):279-80. X-1. [pmid: 18716980].
276 Hauser R, Lessing JB, Samuel D, et al. Management of bilateral nonpalpable testes: laparoscopic diagnosis and orchidectomy. Int J Androl. Apr. 1994;17(2):74-7. X-4, X-5, X-6. [pmid: 7913082].
277 Hay SA. Collateral circulation after spermatic vessel ligation for abdominal testis and its impact on staged laparoscopically assisted orchiopexy. J Laparoendosc Adv Surg Tech A. Feb. 2007;17(1):124-7. X-4, X-5, X-6. [pmid: 17362189].
278 Hay SA, Soliman HA, Abdel Rahman AH, et al. Laparoscopic classification and treatment of the impalpable testis. Pediatr Surg Int. 1999;15(8):570-2. X-4, X-5, X-6, X-8. [pmid: 10631737].
279 Hayashi Y, Mogami T, Sasaki S, et al. Transinguinal laparoscopy for nonpalpable testis. Int J Urol. Jul. 1996;3(4):274-7. X-4, X-5, X-6. [pmid: 8844282].
280 Hazebroek FW, Molenaar JC. The management of the impalpable testis by surgery alone. J Urol. Aug. 1992;148(2 Pt 2):629-31. X-5, X-6, X-8. [pmid: 1353544].
281 He D, Lin T, Wei G, et al. Laparoscopic orchiopexy for treating inguinal canalicular palpable undescended testis. J Endourol. Aug. 2008;22(8):1745-9. X-4, X-5, X-6. [pmid: 18620497].
282 Heath AL, Man DW, Eckstein HB. Epididymal abnormalities associated with maldescent of the testis. J Pediatr Surg. Feb. 1984;19(1):47-9. X-4, X-5, X-6, X-7. [pmid: 6142101].
283 Hederstrom E, Forsberg L, Kullendorff CM. Ultrasonography of the undescended testis. Acta Radiol Diagn (Stockh). Jul–Aug. 1985;26(4):453-6. X-10. [pmid: 3901679].
284 Hedinger E. Histopathology of undescended testes. Eur J Pediatr. Dec. 1982;139(4):266-71. X-1, X-5, X-6, X-7. [pmid: 6133753].
285 Heiskanen P, Billig H, Toppari J, et al. Apoptotic cell death in the normal and cryptorchid human testis: the effect of human chorionic gonadotropin on testicular cell survival. Pediatr Res. Aug. 1996;40(2):351-6. X-5, X-6, X-7. [pmid: 8827789].
286 Heiss KF, Shandling B. Laparoscopy for the impalpable testes: experience with 53 testes. J Pediatr Surg. Feb. 1992;27(2):175-8. discussion 179. X-4, X-5, X-6. [pmid: 1348786].
287 Hemingway AP, Williams G, Allison DJ. Testicular venography in the localization of undescended testes. An analysis of seventeen patients. Ann Radiol (Paris). 1986;29(2):223-5. X-2. [pmid: 2874763].
288 Herrinton LJ, Zhao W, Husson G. Management of cryptorchism and risk of testicular cancer. Am J Epidemiol. Apr. 1. 2003;157(7):602-5. X-5, X-6, X-8. [pmid: 12672679].
289 Herzog B, Hadziselimovic F, Strebel C. Primary and secondary testicular atrophy. Eur J Pediatr. Suppl 2. 1987;146:S53-5. X-1, X-4, X-5, X-6. [pmid: 2891525].
290 Herzog B, Rosslein R, Hadziselimovic F. The role of the processus vaginalis in cryptorchidism. Does a patent processus vaginalis have a prognostic importance for predicting subsequent fertility?. Eur J Pediatr. Suppl 2. 1993;152:S15-6. X-5, X-6, X-7. [pmid: 8101803].
291 Herzog B, Steigert M, Hadziselimovic F. Is a testis located at the superficial inguinal pouch (Denis Browne pouch) comparable to a true cryptorchid testis?. J Urol. Aug. 1992;148(2 Pt 2):622-3. X-4, X-5, X-6, X-7. [pmid: 1353541].
292 Heyns CF. The gubernaculum during testicular descent in the human fetus. J Anat. Aug. 1987;153:93-112. X-5, X-6, X-7. [pmid: 2892824].
293 Hezmall HP, Lipshultz LI. Cryptorchidism and infertility. Urol Clin North Am. Oct. 1982;9(3):361-9. X-1. [pmid: 6128819].
294 Hinman F Jr. Alternatives to orchiopexy. J Urol. Apr. 1980;123(4):548-51. X-1. [pmid: 6102609].
295 Hinman F Jr. Management of the intra-abdominal testis. Eur J Pediatr. Suppl 2. 1987;146:S49-50. X-1. [pmid: 2891523].
296 Hirsch HJ, Eldar-Geva T, Benarroch F, et al. Primary testicular dysfunction is a major contributor to abnormal pubertal development in males with Prader-Willi syndrome. J Clin Endocrinol Metab. Jul. 2009;94(7):2262-8. X-5, X-6, X-7. [pmid: 19401370].
297 Hjertkvist M, Damber JE, Bergh A. Cryptorchidism: a registry based study in Sweden on some factors of possible aetiological importance. J Epidemiol Community Health. Dec. 1989;43(4):324-9. X-5, X-6, X-7. [pmid: 2575645].
298 Hjertkvist M, Lackgren G, Ploen L, et al. Does HCG treatment induce inflammation-like changes in undescended testes in boys?. J Pediatr Surg. Feb. 1993;28(2):254-8. X-5, X-6, X-7, X-8. [pmid: 8094747].
299 Hocht B. LH-RH treatment for cryptorchidism. Randomized study and 10-year follow-up results. Eur J Pediatr. Suppl 2. 1987;146:S44-6. X-10. [pmid: 2891522].
300 Hoekstra HJ, Wobbes T, Sleyfer DT, et al. Bilateral primary germ cell tumors of testis. Urology. Feb. 1982;19(2):152-4. X-5, X-6, X-7. [pmid: 7058607].
301 Holcomb GW 3rd. Laparoscopic evaluation for a contralateral inguinal hernia or a nonpalpable testis. Pediatr Ann. Nov. 1993;22(11):678-84. X-5, X-6, X-7, X-8. [pmid: 7904746].
302 Holcomb GW 3rd, Brock JW 3rd, Neblett WW 3rd, et al. Laparoscopy for the nonpalpable testis. Am Surg. Feb. 1994;60(2):143-7. X-5, X-6, X-7, X-8. [pmid: 7905721].
303 Hoorweg-Nijman JJ, Havers HM, Delemarre-van de Waal HA. Effect of human chorionic gonadotrophin (hCG)/follicle-stimulating hormone treatment versus hCG treatment alone on testicular descent: a double-blind placebo-controlled study. Eur J Endocrinol. Jan. 1994;130(1):60-4. X-8. [pmid: 7907261].
304 Horasanli K, Miroglu C, Tanriverdi O, et al. Single stage Fowler-Stephens orchidopexy: a preferred alternative in the treatment of nonpalpable testes. Pediatr Surg Int. Sep. 2006;22(9):759-61. X-4, X-5, X-6. [pmid: 16896813].
305 Hornak M, Pauer M, Bardos A Jr, et al. The incidence of carcinoma in situ in postpubertal undescended testis. Int Urol Nephrol. 1987;19(3):321-5. X-4, X-5, X-6, X-7. [pmid: 2889693].
306 Hosie S, Loff S, Witt K, et al. Is there a correlation between organochlorine compounds and undescended testes?. Eur J Pediatr Surg. Oct. 2000;10(5):304-9. X-5, X-6, X-7. [pmid: 11194541].
307 Hosie S, Wessel L, Waag KL. Could testicular descent in humans be promoted by direct androgen stimulation of the gubernaculum testis?. Eur J Pediatr Surg. Feb. 1999;9(1):37-41. X-5, X-6, X-7, X-8. [pmid: 10207702].
308 Howard ER, Hedges AR. Diagnosis and surgical treatment of the maldescended testis. Br J Hosp Med. Apr. 1986;35(4):260-2. X-1, X-4, X-5, X-6. [pmid: 2872931].
309 Hrebinko RL, Bellinger MF. The limited role of imaging techniques in managing children with undescended testes. J Urol. Aug. 1993;150(2 Pt 1):458-60. X-8. [pmid: 8100860].
310 Hsieh JT, Huang TS. A study on cryptorchidism. Taiwan Yi Xue Hui Za Zhi. Aug. 1985;84(8):953-9. X-5, X-6, X-7. [pmid: 2867121].
311 Hsieh MH, Bayne A, Cisek LJ, et al. Bladder injuries during laparoscopic orchiopexy: incidence and lessons learned. J Urol. Jul. 2009;182(1):280-4. discussion 284–5. X-4, X-5, X-6, X-7. [pmid: 19450839].
312 Hsieh MH, Roth DR, Meng MV. Economic analysis of infant vs postpubertal orchiopexy to prevent testicular cancer. Urology. Apr. 2009;73(4):776-81. X-5, X-6, X-7, X-8. [pmid: 19193413].
313 Huff DS, Fenig DM, Canning DA, et al. Abnormal germ cell development in cryptorchidism. Horm Res. 2001;55(1):11-7. X-5, X-6, X-7. [pmid: 11423736].
314 Huff DS, Hadziselimovic F, Duckett JW, et al. Germ cell counts in semithin sections of biopsies of 115 unilaterally cryptorchid testes. The experience from the Children’s Hospital of Philadelphia. Eur J Pediatr. Suppl 2. 1987;146:S25-7. X-5, X-6, X-7. [pmid: 2891515].
315 Huff DS, Snyder HM 3rd, Hadziselimovic F, et al. An absent testis is associated with contralateral testicular hypertrophy. J Urol. Aug. 1992;148(2 Pt 2):627-8. X-4, X-5, X-6, X-7. [pmid: 1353543].
316 Huff DS, Snyder HM 3rd, Rusnack SL, et al. Hormonal therapy for the subfertility of cryptorchidism. Horm Res. 2001;55(1):38-40. X-4, X-5, X-6. [pmid: 11423741].
317 Humke U, Siemer S, Bonnet L, et al. Pediatric laparoscopy for nonpalpable testes with new miniaturized instruments. J Endourol. Oct. 1998;12(5):445-50. X-4, X-5, X-6. [pmid: 9847068].
318 Hunt JB, Witherington R, Smith AM. The midline preperitoneal approach to orchiopexy. Am Surg. Apr. 1981;47(4):184-9. X-4, X-5, X-6. [pmid: 6111967].
319 Hurwitz RS, Kaptein JS. How well does contralateral testis hypertrophy predict the absence of the nonpalpable testis?. J Urol. Feb. 2001;165(2):588-92. X-5, X-6, X-7. [pmid: 11176443].
320 Hussain Taqvi SR, Akhtar J, Batool T, et al. Correlation of the size of undescended testis with its locations in vatrious age groups. J Coll Physicians Surg Pak. Sep. 2006;16(9):594-7. X-4, X-5, X-6, X-7. [pmid: 16945233].
321 Hutcheson JC, Cooper CS, Snyder HM 3rd. The anatomical approach to inguinal orchiopexy. J Urol. Nov. 2000;164(5):1702-4. X-1. [pmid: 11025753].
322 Hvistendahl GM, Poulsen EU. Laparoscopy for the impalpable testes: experience with 80 intra-abdominal testes. J Pediatr Urol. Oct. 2009;5(5):389-92. X-5, X-6, X-8. [pmid: 19457721].
323 Hwang AH, Hwang MM, Xie HW, et al. Access to urologic care for children in California: Medicaid versus private insurance. Urology. Jul. 2005;66(1):170-3. X-5, X-6, X-7. [pmid: 15993479].
324 Illig R, Bucher H, Prader A. Success, relapse and failure after intranasal LHRH treatment of cryptorchidism in 55 prepubertal boys. Eur J Pediatr. Mar. 1980;133(2):147-50. X-4, X-5, X-6. [pmid: 6102517].
325 Illig R, Torresani T, Bucher H, et al. Effect of intranasal LHRH therapy on plasma LH, FSH and testosterone, and relation to clinical results in prepubertal boys with cryptorchidism. Clin Endocrinol (Oxf). Jan. 1980;12(1):91-7. X-10. [pmid: 6103766].
326 Inan M, Aydiner CY, Tokuc B, et al. Prevalence of cryptorchidism, retractile testis and orchiopexy in school children. Urol Int. 2008;80(2):166-71. X-5, X-6, X-7. [pmid: 18362487].
327 Irkilata HC, Dayanc M, Kibar Y, et al. Effect of scrotal incision orchiopexy on serum inhibin B levels and comparison with classic inguinal orchiopexy. Urology. Sep. 2008;72(3):525-9. X-4, X-5, X-6. [pmid: 18571703].
328 Irkilata HC, Dayanc M, Yildirim I, et al. Low sperm recovery from the undescended testis with testicular sperm extraction in postpubertal cryptorchids: preliminary report. Andrologia. Jun. 2005;37(2–3):65-8. X-4, X-5, X-6, X-7. [pmid: 16026426].
329 Irkilata HC, Yildirim I, Onguru O, et al. The influence of orchiopexy on serum inhibin B level: relationship with histology. J Urol. Dec. 2004;172(6 Pt 1):2402-5. discussion 2405. X-4, X-5, X-6. [pmid: 15538279].
330 Ismail K, Ashour M, El-Afifi M, et al. Laparoscopy in the management of impalpable testis: series of 64 cases. World J Surg. Jul. 2009;33(7):1514-9. X-10. [pmid: 19363581].
331 Ito H, Kataumi Z, Yanagi S, et al. Changes in the volume and histology of retractile testes in prepubertal boys. Int J Androl. Jun. 1986;9(3):161-9. X-5, X-6, X-7. [pmid: 2879799].
332 Iyer KR, Kumar V, Huddart SN, et al. The scrotal approach. Pediatric Surgery International. 1995;10(1):58-60. X-4, X-5, X-6, X-7.
333 Jackson MB. The epidemiology of cryptorchidism. John Radcliffe Hospital Cryptorchidism Research Group. Horm Res. 1988;30(4–5):153-6. X-5, X-6, X-7. [pmid: 2907891].
334 Jackson MB, Gough MH, Dudley NE. Anatomical findings at orchiopexy. Br J Urol. Jun. 1987;59(6):568-71. X-4, X-5, X-6. [pmid: 2891395].
335 Jackson MB, Swerdlow AJ. Seasonal variations in cryptorchidism. J Epidemiol Community Health. Sep. 1986;40(3):210-3. X-5, X-6, X-7. [pmid: 2877045].
336 Jallouli M, Rebai T, Abid N, et al. Neoadjuvant gonadotropin-releasing hormone therapy before surgery and effect on fertility index in unilateral undescended testes: a prospective randomized trial. Urology. Jun. 2009;73(6):1251-4. X-10. [pmid: 19371931].
337 Janus C, Martin A. MRI of the male pelvis: Current applications. Applied Radiology. 1989;18(10):36-39. X-1. [pmid: 10304415].
338 Jarow JP, Berkovitz GD, Migeon CJ, et al. Elevation of serum gonadotropins establishes the diagnosis of anorchism in prepubertal boys with bilateral cryptorchidism. J Urol. Jul. 1986;136(1 Pt 2):277-9. X-4, X-5, X-6, X-8. [pmid: 2873261].
339 Jawad AJ. High scrotal orchidopexy for palpable maldescended testes. Br J Urol. Aug. 1997;80(2):331-3. X-4, X-5, X-6, X-8. [pmid: 9284211].
340 Jawad AJ. Scroto-peritoneal port for laparoscopic orchidopexy. Pediatr Surg Int. Jul. 1998;13(5–6):460-1. X-4, X-5, X-6. [pmid: 9639650].
341 Job JC, Canlorbe P, Garagorri JM, et al. Hormonal therapy of cryptorchidism with human chorionic gonadotropin(HCG). Urol Clin North Am. Oct. 1982;9(3):405-11. X-1, X-4, X-5, X-6. [pmid: 6128824].
342 Job JC, Toublanc JE, Chaussain JL, et al. Endocrine and immunological findings in cryptorchid infants. Horm Res. 1988;30(4–5):167-72. X-1, X-5, X-6, X-7. [pmid: 2907894].
343 Job JC, Toublanc JE, Chaussain JL, et al. The pituitary-gonadal axis in cryptorchid infants and children. Eur J Pediatr. Suppl 2. 1987;146:S2-5. X-1. [pmid: 2891513].
344 Johansen TE. Anatomy of the testis and epididymis in cryptorchidism. Andrologia. Sep–Oct. 1987;19(5):565-9. X-4, X-5, X-6, X-7. [pmid: 2892434].
345 Johansen TE. The anatomy of gubernaculum testis and processus vaginalis in cryptorchidism. Scand J Urol Nephrol. 1988;22(2):101-5. X-5, X-6, X-7. [pmid: 2905073].
346 Johansen TE. Therapeutic basis in cryptorchidism. A clinical and experimental study. J Oslo City Hosp. Mar–Apr. 1988;38(3–4):27-43. X-2. [pmid: 2898518].
347 Johansen TE, Larmo A. Ultrasonography in undescended testes. Acta Radiol. Mar–Apr. 1988;29(2):159-63. X-8. [pmid: 2896011].
348 Jones BJ, Thornhill JA, O’Donnell B, et al. Influence of prior orchiopexy on stage and prognosis of testicular cancer. Eur Urol. 1991;19(3):201-3. X-4, X-5, X-6, X-8. [pmid: 1677333].
349 Jones C, Kern I. Laparoscopy for the non-palpable testis: a review of twenty-eight patients (1988–90). Aust N Z J Surg. Jun. 1993;63(6):451-3. X-4, X-5, X-6. [pmid: 8098936].
350 Jordan GH, Winslow BH. Laparoscopic single stage and staged orchiopexy. J Urol. Oct. 1994;152(4):1249-52. X-4, X-5, X-6, X-8. [pmid: 7915336].
351 Jose B, Perkins PL, Kays H. Seminoma in undescended testes. J Surg Oncol. Apr. 1984;25(4):252-4. X-5, X-6, X-7. [pmid: 6143856].
352 Josso N, Fekete C, Cachin O, et al. Persistence of Mullerian ducts in male pseudohermaphroditism, and its relationship to cryptorchidism. Clin Endocrinol (Oxf). Aug. 1983;19(2):247-58. X-4, X-5, X-6, X-7. [pmid: 6136350].
353 Josso N, Legeai L, Forest MG, et al. An enzyme linked immunoassay for anti-mullerian hormone: a new tool for the evaluation of testicular function in infants and children. J Clin Endocrinol Metab. Jan. 1990;70(1):23-7. X-5, X-6, X-7. [pmid: 1688440].
354 Jozsa T, Csizy I, Kutasy B, et al. Decreased incidence of appendix testis in cryptorchidism with intraoperative survey. Urol Int. 2008;80(3):317-20. X-5, X-6, X-7. [pmid: 18480639].
355 Jozsa T, Dienes B, Telek A, et al. Differential expression of androgen and estrogen receptor of appendix testis in patients with descended and undescended testes. Int J Urol. Feb. 2008;15(2):171-4. X-5, X-6, X-7. [pmid: 18269458].
356 Kaefer M, Diamond D, Hendren WH, et al. The incidence of intersexuality in children with cryptorchidism and hypospadias: stratification based on gonadal palpability and meatal position. J Urol. Sep. 1999;162(3 Pt 2):1003-6. discussion 1006–7. X-5, X-6, X-7. [pmid: 10458421].
357 Kaleva M, Arsalo A, Louhimo I, et al. Treatment with human chorionic gonadotrophin for cryptorchidism: clinical and histological effects. Int J Androl. Oct. 1996;19(5):293-8. X-4. [pmid: 8985778].
358 Kamisawa H, Kojima Y, Hayashi Y, et al. Evaluation of preoperative testicular volume in Japanese children with unilateral cryptorchidism. Int Urol Nephrol. 2008;40(4):977-81. X-5, X-6, X-7. [pmid: 18459063].
359 Kanemoto K, Hayashi Y, Kojima Y, et al. The management of nonpalpable testis with combined groin exploration and subsequent transinguinal laparoscopy. J Urol. Feb. 2002;167(2 Pt 1):674-6. X-4, X-5, X-6, X-8. [pmid: 11792951].
360 Karaman I, Karaman A, Erdogan D, et al. The transscrotal approach for recurrent and iatrogenic undescended testes. Eur J Pediatr Surg. Jul. 2010;20(4):267-9. X-4, X-5, X-6. [pmid: 20225179].
361 Karpe B. Prognosis of hormonal treatment of undescended testis related to testicular position at birth. Pediatric Surgery International. 1991;6(3):221-222. X-4, X-5, X-6, X-8.
362 Karplus G, Kleiner O, Newman N, et al. Twelve years of minimally invasive surgery in children and adolescents: a single center experience. J Laparoendosc Adv Surg Tech A. Aug. 2005;15(4):419-23. X-4, X-5, X-6, X-7. [pmid: 16108750].
363 Kaye JD, Palmer LS. Single setting bilateral laparoscopic orchiopexy for bilateral intra-abdominal testicles. J Urol. Oct. 2008;180(4 Suppl):1795-9. discussion 1799. X-4, X-5, X-6, X-8. [pmid: 18721983].
364 Kelley BP, Higuera S, Cisek LJ, et al. Combined laparoscopic and microsurgical techniques for testicular autotransplantation: is this still an evolving technique?. J Reconstr Microsurg. Oct. 2010;26(8):555-8. X-4, X-5, X-6. [pmid: 20640978].
365 Kennedy WAn, Snyder HMr. Paediatric andrology: the impact of environmental pollutants. BJU Int. Jan. 1999;83(2):195-200. X-1. [pmid: 10233480].
366 Khademi M, Seebode JJ, Falla A. Selective spermatic arteriography for localization of an impalpable undescended testis. Radiology. Sep. 1980;136(3):627-34. X-2. [pmid: 6105698].
367 Khairi A, Shehata S, Al-Azim MA, et al. Hypoplastic gonadal vessels exiting the deep ring during laparoscopy for impalpable testes: when is inguinal exploration necessary?. J Laparoendosc Adv Surg Tech A. Feb. 2009;19(1):103-6. X-4, X-5, X-6. [pmid: 19021464].
368 Khan AR. Open laparoscopic access for primary trocar using modified Hasson’s technique. Saudi Med J. May. 2003;24(Suppl):S21-4. X-4, X-5, X-6. [pmid: 12778236].
369 Khan O, Krausz T, Williams G. Testicular venography in impalpable testis. Eur Urol. 1983;9(6):341-2. X-1. [pmid: 6140166].
370 Khan O, Williams G, Boley NB, et al. Testicular venography for the localization of the impalpable undescended testis. Br J Surg. Nov. 1982;69(11):660. X-8. [pmid: 6127135].
371 Khattak ID, Zafar A, Khan IA, et al. Re-do orchidopexy in a general surgical unit-reliability of clinical diagnosis and the outcome of surgery. J Ayub Med Coll Abbottabad. Jul–Sep. 2008;20(3):97-9. X-4, X-5, X-6. [pmid: 19610529].
372 Khazanchi RK, Saraf R, Shankar G. The hockey stick incision in microvascular autotransplantation of intra-abdominal testis. Indian Journal of Urology. 1994;11(1):40-41. X-1, X-4, X-5, X-6.
373 Kidney DD, Cohen AJ, Seville P. Retractile testis: an incidental CT finding in trauma patients. AJR Am J Roentgenol. May. 1997;168(5):1233-4. X-5, X-6, X-7, X-8. [pmid: 9129418].
374 Kim GH, Dy LC, Caldemeyer KS, et al. Buschke-Ollendorff syndrome. Journal of the American Academy of Dermatology. 01. Apr. 2003;48(4):600-601. X-1. [pmid: 12664025].
375 Kim KK. High scrotal incision for scrotal pouch orchiopexy. Urology. Jul. 1996;48(1):131-2. X-1, X-4, X-5, X-6. [pmid: 8693635].
376 Kim SO, Hwang EC, Hwang IS, et al. Testicular catch up growth: The impact of orchiopexy age. Urology. October. 2011;78(4):886-889. X-4, X-5, X-6. [pmid: 21762966].
377 King LR. Undescended testis. JAMA. Sep. 18. 1996;276(11):856. X-1, X-4, X-5, X-6. [pmid: 8782621].
378 Kirk JM, Savage MO, Grant DB, et al. Gonadal function and response to human chorionic and menopausal gonadotrophin therapy in male patients with idiopathic hypogonadotrophic hypogonadism. Clin Endocrinol (Oxf). Jul. 1994;41(1):57-63. X-5, X-6, X-7, X-8. [pmid: 7914153].
379 Kirsch AJ, Escala J, Duckett JW, et al. Surgical management of the nonpalpable testis: the Children’s Hospital of Philadelphia experience. J Urol. Apr. 1998;159(4):1340-3. X-4, X-5, X-6, X-8. [pmid: 9507881].
380 Klein EA, Herr HW. Suprapubic approach for bilateral orchiectomy and placement of testicular prostheses. J Urol. Apr. 1990;143(4):765-6. X-1. [pmid: 2313802].
381 Kleinteich B, Popp W, Daniel P, et al. Excretory urography as a screening method for abnormalities of the upper urinary tract in asymptomatic boys with undescended testicles. Int Urol Nephrol. 1981;13(1):77-80. X-5, X-6, X-7. [pmid: 6115827].
382 Klidjian AM, Swift PG, Johnstone JM. Luteinising hormone releasing hormone for incomplete descent of the testis. Arch Dis Child. Jun. 1985;60(6):568-71. X-8. [pmid: 2861791].
383 Koff WJ, Scaletscky R. Malformations of the epididymis in undescended testis. J Urol. Feb. 1990;143(2):340-3. X-4, X-5, X-6, X-7. [pmid: 1967660].
384 Kogan BA, Hricak H, Tanagho EA. Magnetic resonance imaging in genital anomalies. J Urol. Oct. 1987;138(4 Pt 2):1028-30. X-8. [pmid: 2888904].
385 Kogan SJ, Gill B, Bennett B, et al. Human monorchism: a clinicopathological study of unilateral absent testes in 65 boys. J Urol. Apr. 1986;135(4):758-61. X-5, X-6, X-7. [pmid: 2870199].
386 Kogan SJ, Tennenbaum S, Gill B, et al. Efficacy of orchiopexy by patient age 1 year for cryptorchidism. J Urol. Aug. 1990;144(2 Pt 2):508-9. discussion 512–3. X-4, X-5, X-6. [pmid: 1973740].
387 Kojima Y, Hayashi Y, Mizuno K, et al. Assessment of serum follicle-stimulating hormone level and testicular volume for prediction of paternity potential in pubertal boys who underwent bilateral orchiopexy in childhood. J Urol. Jun. 2006;175(6):2290-4. X-4, X-5, X-6. [pmid: 16697861].
388 Kokorowski PJ, Routh JC, Graham DA, et al. Variations in timing of surgery among boys who underwent orchidopexy for cryptorchidism. Pediatrics. Sep. 2010;126(3):e576-82. X-5, X-6, X-7. [pmid: 20732947].
389 Kollin C, Hesser U, Ritzen EM, et al. Testicular growth from birth to two years of age, and the effect of orchidopexy at age nine months: a randomized, controlled study. Acta Paediatr. Mar. 2006;95(3):318-24. X-10. [pmid: 16497643].
390 Kollin C, Karpe B, Hesser U, et al. Surgical treatment of unilaterally undescended testes: testicular growth after randomization to orchiopexy at age 9 months or 3 years. J Urol. Oct. 2007;178(4 Pt 2):1589-93. discussion 1593. X-10. [pmid: 17707045].
391 Kolon TF, Miller OF. Comparison of single versus multiple dose regimens for the human chorionic gonadotropin stimulatory test. J Urol. Oct. 2001;166(4):1451-4. X-5, X-8. [pmid: 11547110].
392 Koskimies AI, Hovatta O. Hypothalamo--pituitary--gonadal axis and sperm-agglutinating antibodies in infertile men treated for cryptorchidism. Arch Androl. May. 1982;8(3):181-3. X-4, X-5, X-6. [pmid: 6125129].
393 Kostakopoulos A, Sofras F, Kyriakidis A, et al. Preoperative ultrasonography of the undescended testis. Acta Urol Belg. 1987;55(1):89-92. X-8. [pmid: 2882669].
394 Koyama T, Nonomura K, Ameda K, et al. Laparoscopic evaluation and the management of the nonpalpable testis. Diagnostic and Therapeutic Endoscopy. 1997;4(2):69-74. X-5, X-6, X-7, X-8. [pmid: 18493455].
395 Kropp KA, Voeller KK. Cryptorchidism in meningomyelocele. J Pediatr. Jul. 1981;99(1):110-3. X-5, X-6, X-7. [pmid: 6114140].
396 Ku JH, Kim ME, Lee NK, et al. Testicular volume and masculine identity in men with unilateral cryptorchidism: results of a community-based survey in Korea. Urol Res. Oct. 2003;31(5):312-6. X-5, X-6, X-7. [pmid: 14574535].
397 Kubini K, Zachmann M, Albers N, et al. Basal inhibin B and the testosterone response to human chorionic gonadotropin correlate in prepubertal boys. J Clin Endocrinol Metab. Jan. 2000;85(1):134-8. X-5, X-8. [pmid: 10634376].
398 Kucheria R, Sahai A, Sami TA, et al. Laparoscopic management of cryptorchidism in adults. Eur Urol. Sep. 2005;48(3):453-7. discussion 457. X-4, X-5, X-6, X-8. [pmid: 15994002].
399 Kyriacou V, Mavridou C, Bintoudi A, et al. Pituitary stalk interruption syndrome: The role of MRI and review of the literature. Neuroradiology Journal. October. 2010;23(5):607-612. X-5, X-6, X-7.
400 Labady F, Lepies P, Cinovsky K. On the psychopathology of patients with disorders in the descent of the testis. Int Urol Nephrol. 1988;20(6):647-55. X-5, X-6, X-7. [pmid: 2906635].
401 Lackgren G. Undescended testis--diagnosis, treatment and fertility. Scand J Urol Nephrol Suppl. 1988;110:47-50. X-1. [pmid: 2903547].
402 Lackgren G, Berg AA. The effect of hCG-treatment on in vitro metabolism of progesterone by the human undescended pre-pubertal testis. Int J Androl. Oct. 1983;6(5):414-22. X-4, X-5, X-6. [pmid: 6140226].
403 Lackgren G, Berg AA. In vitro metabolism of progesterone by the human undescended testis. Int J Androl. Oct. 1983;6(5):423-32. X-5, X-6, X-7. [pmid: 6140227].
404 Lackgren G, Gordeladze JO, Ploen L, et al. Germ cell adenylyl cyclase activity in the human undescended testis and the effect of HCG-treatment. Arch Androl. 1984;12(1):97-102. X-5, X-6, X-8. [pmid: 6148043].
405 Lackgren G, Ploen L. The influence of human chorionic gonadotrophin (hCG) on the morphology of the prepubertal human undescended testis. Int J Androl. Feb. 1984;7(1):39-52. X-4, X-5, X-6, X-8. [pmid: 6143733].
406 Lackgren G, Ploen L, Berg AA, et al. Receptors for luteinizing hormone (LH) and follicle stimulating hormone (FSH) in the human undescended testis and the effect of hCG-treatment. Int J Androl. Dec. 1983;6(6):520-32. X-4. [pmid: 6142003].
407 Lahdes-Vasama TT, Koskimaki JE, Streng TK, et al. Urodynamic findings in men operated on for an undescended testicle. BJU Int. Dec. 2003;92(9):972-6. X-4, X-5, X-6, X-7. [pmid: 14632858].
408 Lai HS, Duh YC, Tsai WS, et al. Role of thermography in the diagnosis of undescended testes. Eur Urol. 1998;33(2):209-13. X-10. [pmid: 9519367].
409 Lais A, Caterino S, Talamo M, et al. The gliding testis: minor degree of true undescended testis?. Eur J Pediatr. Suppl 2. 1993;152:S20-2. X-4, X-5, X-6, X-7. [pmid: 8101805].
410 Lakhoo K, Thomas DF, Najmaldin AS. Is inguinal exploration for the impalpable testis an outdated operation?. Br J Urol. Mar. 1996;77(3):452-4. X-4, X-5, X-6, X-7. [pmid: 8814856].
411 Lakshiminarayan G, Jitendra N, Deepak Singh C, et al. A clinical study and management of inguinoscrotal swelling in children. JMS - Journal of Medical Society. Sep. 2007;21(3):143-146. X-1, X-5, X-6, X-7.
412 Lala R, Canavese F, Andreo R, et al. Testicular function of young men treated in childhood for cryptorchidism. Horm Res. 2001;55(1):53. X-4. [pmid: 11423746].
413 Lala R, De Sanctis C, Canavese F, et al. Early medical and surgical treatment of cryptorchidism: Clincal, anatomic, and histologic findings. Pediatric Surgery International. 1992;7(5):368-371. X-4, X-5, X-6.
414 Lala R, Matarazzo P, Chiabotto P, et al. Combined therapy with LHRH and HCG in cryptorchid infants. Eur J Pediatr. Suppl 2. 1993;152:S31-3. X-4. [pmid: 8101810].
415 Lala R, Matarazzo P, Chiabotto P, et al. Early hormonal and surgical treatment of cryptorchidism. J Urol. May. 1997;157(5):1898-901. X-4. [pmid: 9112559].
416 Lamah M, McCaughey ES, Finlay FO, et al. The ascending testis: is late orchidopexy due to failure of screening or late ascent?. Pediatr Surg Int. Jul. 2001;17(5–6):421-3. X-5, X-6, X-7. [pmid: 11527181].
417 Landa HM, Gylys-Morin V, Mattrey RF, et al. Magnetic resonance imaging of the cryptorchid testis. Eur J Pediatr. Suppl 2. 1987;146:S16-7. X-8. [pmid: 2891511].
418 Lanson Y. Epidemiology of testicular cancers. Prog Clin Biol Res. 1985;203:155-9. X-1. [pmid: 2870504].
419 Lawson A, Gornall P, Buick RG, et al. Impalpable testis: testicular vessel division in treatment. Br J Surg. Sep. 1991;78(9):1111-2. X-4. [pmid: 1681977].
420 Lee BW. Hormonal treatment of cryptorchidism. J Singapore Paediatr Soc. 1990;32(1–2):23-6. X-1, X-4, X-5, X-6. [pmid: 1979644].
421 Lee BW, Tan SH, Goh HH. Gonadotrophin therapy in children with cryptorchidism. Asian Medical Journal. [Journal]. 1984;27(10):661-665. X-4, X-5, X-6, X-8.
422 Lee JK, Glazer HS. Computed tomography in the localization of the nonpalpable testis. Urol Clin North Am. Oct. 1982;9(3):397-404. X-2. [pmid: 6128823].
423 Lee MM, Donahoe PK, Silverman BL, et al. Measurements of serum mullerian inhibiting substance in the evaluation of children with nonpalpable gonads. N Engl J Med. May. 22. 1997;336(21):1480-6. X-5, X-6, X-7. [pmid: 9154766].
424 Lee PA. Consequence of cryptorchidism: relationship to etiology and treatment. Curr Probl Pediatr. Aug. 1995;25(7):232-6. X-1. [pmid: 8521719].
425 Lee PA. Fertility after cryptorchidism: epidemiology and other outcome studies. Urology. Aug. 2005;66(2):427-31. X-1, X-4, X-5, X-6. [pmid: 16098371].
426 Lee PA, Bellinger MF, Coughlin MT. Correlations among hormone levels, sperm parameters and paternity in formerly unilaterally cryptorchid men. J Urol. Sep. 1998;160(3 Pt 2):1155-7. discussion 1178. X-5, X-6, X-7. [pmid: 9719298].
427 Lee PA, Bellinger MF, Songer NJ, et al. An epidemiologic study of paternity after cryptorchidism: initial results. Eur J Pediatr. Suppl 2. 1993;152:S25-7. X-4, X-5, X-6, X-7. [pmid: 8101807].
428 Lee PA, Coughlin MT. Fertility after bilateral cryptorchidism. Evaluation by paternity, hormone, and semen data. Horm Res. 2001;55(1):28-32. X-4, X-5, X-6. [pmid: 11423739].
429 Lee PA, Coughlin MT. Leydig cell function after cryptorchidism: evidence of the beneficial result of early surgery. J Urol. Apr. 2002;167(4):1824-7. X-4, X-5, X-6. [pmid: 11912442].
430 Lee PA, Coughlin MT. The single testis: paternity after presentation as unilateral cryptorchidism. J Urol. Oct. 2002;168(4 Pt 2):1680-2. discussion 1682–3. X-4, X-5, X-6. [pmid: 12352333].
431 Lee PA, Coughlin MT, Bellinger MF. Paternity and hormone levels after unilateral cryptorchidism: association with pretreatment testicular location. J Urol. Nov. 2000;164(5):1697-701. X-4, X-5, X-6. [pmid: 11025752].
432 Lee PA, Coughlin MT, Bellinger MF. Inhibin B: comparison with indexes of fertility among formerly cryptorchid and control men. J Clin Endocrinol Metab. Jun. 2001;86(6):2576-84. X-4, X-5, X-6, X-8. [pmid: 11397857].
433 Lee PA, Coughlin MT, Bellinger MF. No relationship of testicular size at orchiopexy with fertility in men who previously had unilateral cryptorchidism. J Urol. Jul. 2001;166(1):236-9. X-4, X-5, X-6, X-8. [pmid: 11435877].
434 Lee PA, O’Leary LA, Songer NJ, et al. Paternity after cryptorchidism: lack of correlation with age at orchidopexy. Br J Urol. Jun. 1995;75(6):704-7. X-4, X-5, X-6. [pmid: 7613823].
435 Lee PA, O’Leary LA, Songer NJ, et al. Paternity after unilateral cryptorchidism: a controlled study. Pediatrics. Oct. 1996;98(4 Pt 1):676-9. X-4, X-5, X-6. [pmid: 8885945].
436 Lee PA, O’Leary LA, Songer NJ, et al. Paternity after bilateral cryptorchidism. A controlled study. Arch Pediatr Adolesc Med. Mar. 1997;151(3):260-3. X-4, X-5, X-6. [pmid: 9080933].
437 Lenz S, Giwercman A, Skakkebaek NE, et al. Ultrasound in detection of early neoplasia of the testis. Int J Androl. Feb. 1987;10(1):187-90. X-5, X-6, X-7. [pmid: 2884185].
438 Lenzi A, Gandini L, Lombardo F, et al. Unilateral cryptorchidism corrected in prepubertal age: evaluation of sperm parameters, hormones, and antisperm antibodies in adult age. Fertil Steril. May. 1997;67(5):943-8. X-4, X-5, X-6. [pmid: 9130905].
439 Leung AKC, Wong AL. A photoessay on pediatric genital lesions. Consultant. 1999;39(7):2021-2030. X-1, X-5, X-6, X-7.
440 Leung MW, Chao NS, Wong BP, et al. Laparoscopic mobilization of testicular vessels: an adjunctive step in orchidopexy for impalpable and redo undescended testis in children. Pediatr Surg Int. Sep. 2005;21(9):767-9. X-4, X-5, X-6, X-8. [pmid: 16096794].
441 Li JH, Huang TH, Jiang XW, et al. 46, XX male sex reversal syndrome. Asian J Androl. Jun. 2004;6(2):165-7. X-1, X-5, X-6, X-7. [pmid: 15154093].
442 Lim KT, Casey RG, Lennon F, et al. Cryptorchidism: a general surgical perspective. Ir J Med Sci. Jul–Sep. 2003;172(3):139-40. X-5, X-6, X-8. [pmid: 14700118].
443 Lima M, Bertozzi M, Ruggeri G, et al. The nonpalpable testis: an experience of 132 consecutive videolaparoscopic explorations in 6 years. Pediatr Med Chir. Jan–Feb. 2002;24(1):37-40. X-4, X-5, X-6, X-7. [pmid: 11938680].
444 Lindgren BW, Darby EC, Faiella L, et al. Laparoscopic orchiopexy: procedure of choice for the nonpalpable testis?. J Urol. Jun. 1998;159(6):2132-5. X-5, X-6, X-8. [pmid: 9598558].
445 Lindgren BW, Franco I, Blick S, et al. Laparoscopic Fowler-Stephens orchiopexy for the high abdominal testis. J Urol. Sep. 1999;162(3 Pt 2):990-3. discussion 994. X-5, X-6, X-8. [pmid: 10458418].
446 Liu CS, Chin TW, Wei CF. Impalpable cryptorchidism--a review of 170 testes. Zhonghua Yi Xue Za Zhi (Taipei). Feb. 2002;65(2):63-8. X-10. [pmid: 12014360].
447 Lobe TE. The applications of laparoscopy and lasers in pediatric surgery. Surg Annu. 1993;25(Pt 1):175-91. X-1. [pmid: 8093212].
448 Lojanapiwat B, Soonthornpun S, Wudhikarn S. Preoperative laparoscopy in the management of the nonpalpable testis. J Med Assoc Thai. Nov. 1999;82(11):1106-10. X-4, X-5, X-6, X-7. [pmid: 10659545].
449 London NJ, Joseph HT, Johnstone JM. Orchidopexy: the effect of changing patterns of referral and treatment on outcome. Br J Surg. Jul. 1987;74(7):636-8. X-4, X-5, X-6, X-8. [pmid: 2887229].
450 Longui CA, Arnhold IJ, Mendonca BB, et al. Serum inhibin levels before and after gonadotropin stimulation in cryptorchid boys under age 4 years. J Pediatr Endocrinol Metab. Nov–Dec. 1998;11(6):687-92. X-5, X-6, X-8. [pmid: 9829221].
451 Lorenzo AJ, Samuelson ML, Docimo SG, et al. Cost analysis of laparoscopic versus open orchiopexy in the management of unilateral nonpalpable testicles. J Urol. Aug. 2004;172(2):712-6. X-1. [pmid: 15247768].
452 Lotan G, Klin B, Efrati Y, et al. Laparoscopic evaluation and management of nonpalpable testis in children. World J Surg. Dec. 2001;25(12):1542-5. X-4, X-5, X-6, X-8. [pmid: 11775188].
453 Lotan G, Klin B, Vinograd I. Laparoscopic-guided second-stage Fowler-Stephens procedure for nonpalpable testis in children. Pediatric Endosurgery and Innovative Techniques. 1997;1(1):43-46. X-4, X-5, X-6, X-8.
454 Lou CC, Lin JN, Tung TC, et al. Anatomical findings of the vanishing testis. Changgeng Yi Xue Za Zhi. Jun. 1994;17(2):121-4. X-5, X-6, X-7. [pmid: 7915188].
455 Lovegrove C. Hypogonadotropic hypogonadism and abnormal olfactory-bulb development in CHARGE syndrome. Nature Clinical Practice Endocrinology and Metabolism. 20. Jan. 2006;2(1):4. X-1, X-5, X-6, X-7.
456 Lowe DH, Brock WA, Kaplan GW. Laparoscopy for localization of nonpalpable testes. J Urol. Apr. 1984;131(4):728-9. X-4, X-5, X-6, X-8. [pmid: 6142965].
457 Lustig RH, Conte FA, Kogan BA, et al. Ontogeny of gonadotropin secretion in congenital anorchism: sexual dimorphism versus syndrome of gonadal dysgenesis and diagnostic considerations. J Urol. Sep. 1987;138(3):587-91. X-5, X-6, X-7, X-8. [pmid: 3114503].
458 Lynch DF, Brock WA, Kaplan GW. Orchiopexy: experiences at two centers. Urology. May. 1982;19(5):507-9. X-4, X-5, X-6, X-8. [pmid: 6123173].
459 Mabogunje OA. Surgery for undescended testes. East Afr Med J. Apr. 1986;63(4):251-7. X-4, X-5, X-6, X-8. [pmid: 2874010].
460 MacKellar A. Undescended testis: how history and examination may influence treatment. Aust N Z J Surg. Aug. 1988;58(8):643-5. X-4, X-5, X-6, X-8. [pmid: 2902837].
461 MacMahon RA, O’Brien BM, Aberdeen J, et al. Results of the use of autotransplantation of the intraabdominal testis using microsurgical vascular anastomosis. J Pediatr Surg. Feb. 1980;15(1):92-6. X-4, X-5, X-6. [pmid: 6102597].
462 Maggio MC, Corsello M, Piccione M, et al. Neonatal presentation of Prader Willi syndrome. Personal records. [Italian, English]. Minerva Pediatrica. Dec. 2007;59(6):817-823. X-5, X-6, X-7. [pmid: 17978792].
463 Maghnie M, Valtorta A, Moretta A, et al. Effect of short-term administration of human chorionic gonadotropin on immune functions in cryptorchid children. European Journal of Pediatrics. 1991;150(4):238-241. X-4, X-5, X-6, X-7. [pmid: 1674245].
464 Maghnie M, Valtorta A, Moretta A, et al. Effects of short-term administration of human chorionic gonadotropin on immune functions in cryptorchid children. Eur J Pediatr. Feb. 1991;150(4):238-41. X-4, X-5, X-6, X-8. [pmid: 1674245].
465 Mahmoud AM, Comhaire FH, Abdel-Rahim DE, et al. Conception rates and assisted reproduction in subfertility due to unilateral cryptorchidism. Andrologia. May–Jun. 1996;28(3):141-4. X-5, X-6, X-7. [pmid: 8738076].
466 Mahmoud AM, Comhaire FH, Vereecken A, et al. Inhibin and steroid response to testicular stimulation with pure FSH (Metrodin) in infertile men with unilateral cryptorchidism. Andrologia. Mar–Apr. 1996;28(2):103-8. X-4, X-5, X-6, X-7. [pmid: 8849044].
467 Main KM, Toppari J, Suomi AM, et al. Larger testes and higher inhibin B levels in Finnish than in Danish newborn boys. J Clin Endocrinol Metab. Jul. 2006;91(7):2732-7. X-5, X-6, X-7. [pmid: 16595596].
468 Maizels M, Gomez F, Firlit CF. Surgical correction of the failed orchiopexy. J Urol. Nov. 1983;130(5):955-7. X-4, X-5, X-6, X-7. [pmid: 6138441].
469 Maizels M, Yerkes EB, Macejko A, et al. A New Computer Enhanced Visual Learning Method to Train Urology Residents in Pediatric Orchiopexy: A Prototype for Accreditation Council for Graduate Medical Education Documentation. Journal of Urology. October. 2008;180(4 SUPPL):1814-1818. X-5, X-6, X-7. [pmid: 18721933].
470 Makedonsky IA. The use of human chorionic gonadotropin (HCG) for penile reconstruction in bladder exstrophy and total epispadias patients. Eur J Pediatr Surg. Dec. 2006;16(6):428-31. X-5, X-6, X-7. [pmid: 17211793].
471 Malone PS, Guiney EJ. The value of laparoscopy in localising the impalpable undescended testis. Br J Urol. Aug. 1984;56(4):429-31. X-5, X-6, X-7, X-8. [pmid: 6152544].
472 Mandat KM, Wieczorkiewicz B, Gubala-Kacala M, et al. Semen analysis of patients who had orchidopexy in childhood. Eur J Pediatr Surg. Apr. 1994;4(2):94-7. X-4, X-5, X-6. [pmid: 7912956].
473 Manson AL, Terhune D, Jordan G, et al. Preoperative laparoscopic localization of the nonpalpable testis. J Urol. Nov. 1985;134(5):919-20. X-4, X-5, X-6, X-8. [pmid: 2865378].
474 Marcus KA, Sweep CG, van der Burgt I, et al. Impaired Sertoli cell function in males diagnosed with Noonan syndrome. J Pediatr Endocrinol Metab. Nov. 2008;21(11):1079-84. X-5, X-6, X-7. [pmid: 19189703].
475 Mark SD, Davidson PJ. The role of laparoscopy in evaluation of the impalpable undescended testis. Aust N Z J Surg. Jun. 1997;67(6):332-4. X-4, X-5, X-6, X-8. [pmid: 9193266].
476 Martin DC. Guest editorial: testis. J Urol. Sep. 1980;124(3):388. X-1, X-5, X-6, X-7. [pmid: 6107389].
477 Martin DC. Malignancy in the cryptorchid testis. Urol Clin North Am. Oct. 1982;9(3):371-6. X-1. [pmid: 6128820].
478 Martin JM, Gorayski P, Zwahlen D, et al. Is radiotherapy a good adjuvant strategy for men with a history of cryptorchism and stage I seminoma?. Int J Radiat Oncol Biol Phys. Jan. 1. 2010;76(1):65-70. X-4, X-5, X-6, X-7. [pmid: 19362785].
479 Martinetti M, Maghnie M, Salvaneschi L, et al. Immunogenetic and hormonal study of cryptorchidism. J Clin Endocrinol Metab. Jan. 1992;74(1):39-42. X-4. [pmid: 1345784].
480 Martinova Y, Tzvetkov D, Nikolovsky M. Effect of orchiopexy on human testicular ultrastructure. Acta Chir Hung. 1991;32(2):153-7. X-4, X-5, X-6, X-7. [pmid: 1687906].
481 Marulaiah M, Gilhotra A, Moore L, et al. Testicular and paratesticular pathology in children: a 12-year histopathological review. World J Surg. May. 2010;34(5):969-74. X-5, X-6, X-7. [pmid: 20151127].
482 Mayr J, Rune G, Spendel S, et al. Course of pubic tubercle--centre of testicle distance in children with and without testicular maldescent. Eur J Pediatr Surg. Feb. 1993;3(1):33-6. X-5, X-6, X-7. [pmid: 8096765].
483 Mayr J, Rune GM, Holas A, et al. Ascent of the testis in children. Eur J Pediatr. Nov. 1995;154(11):893-5. X-4, X-5, X-6, X-7. [pmid: 8582401].
484 Mayr JM, Lawrenz K, Berghold A. Undescended testicles: an epidemiological review. Acta Paediatr. Oct. 1999;88(10):1089-93. X-4, X-5, X-6. [pmid: 10565455].
485 McAleer IM, Kaplan GW. Is routine karyotyping necessary in the evaluation of hypospadias and cryptorchidism?. J Urol. Jun. 2001;165(6 Pt 1):2029-31. discussion 2031–2. X-5, X-6, X-7. [pmid: 11371923].
486 McAleer IM, Packer MG, Kaplan GW, et al. Fertility index analysis in cryptorchidism. J Urol. Apr. 1995;153(4):1255-8. X-4, X-5, X-6, X-8. [pmid: 7869523].
487 McBride ML, Van den Steen N, Lamb CW, et al. Maternal and gestational factors in cryptorchidism. Int J Epidemiol. Dec. 1991;20(4):964-70. X-4, X-5, X-6, X-7. [pmid: 1686874].
488 McCabe JE, Kenny SE. Orchidopexy for undescended testis in England: is it evidence based?. J Pediatr Surg. Feb. 2008;43(2):353-7. X-4, X-5, X-6. [pmid: 18280289].
489 McGlynn KA, Graubard BI, Klebanoff MA, et al. Risk factors for cryptorchism among populations at differing risks of testicular cancer. Int J Epidemiol. Jun. 2006;35(3):787-95. X-5, X-6, X-7. [pmid: 16492711].
490 McKiernan MV, Murphy PD, Johnston JG. Ten-year review of treatment of the undescended testis in the west of Ireland. Br J Urol. Jul. 1992;70(1):84-9. X-4, X-5, X-6, X-7. [pmid: 1353396].
491 McLachlan RI, Finkel DM, Bremner WJ, et al. Serum inhibin concentrations before and during gonadotropin treatment in men with hypogonadotropic hypogonadism: physiological and clinical implications. J Clin Endocrinol Metab. May. 1990;70(5):1414-9. X-5, X-6, X-7. [pmid: 2110576].
492 Meakin JL, Keogh EJ, Martin CE. Human anti-luteinizing hormone-releasing hormone antibodies in patients treated with synthetic luteinizing hormone-releasing hormone. Fertil Steril. May. 1985;43(5):811-3. X-4, X-5, X-6, X-7. [pmid: 2860022].
493 Mehendale VG, Kamdar MS, Shenoy SN, et al. Laparoscopic management of impalpable testes. Indian Journal of Urology. 1999;15(2):137-141. X-4, X-5, X-6, X-8.
494 Meijer RW, Hack WWM, Haasnoot K. Successful treatment of acquired undescended testes with human chorionic gonadotropin. European Journal of Pediatrics. 2001;160(1):66-67. X-4, X-5, X-6, X-8. [pmid: 11195026].
495 Merguerian PA, Mevorach RA, Shortliffe LD, et al. Laparoscopy for the evaluation and management of the nonpalpable testicle. Urology. May. 1998;51(5A Suppl):3-6. X-5, X-6, X-8. [pmid: 9610548].
496 Merksz M, Toth J. Testicular-epididymal fusion abnormality in undescended testis. Int Urol Nephrol. 1987;19(2):179-87. X-4, X-5, X-6, X-8. [pmid: 2889692].
497 Merry C, Sweeney B, Puri P. The vanishing testis: anatomical and histological findings. Eur Urol. 1997;31(1):65-7. X-5, X-6, X-7. [pmid: 9032537].
498 Metin A, Kayigil O, Ahmed SI. The efficacy of human chorionic gonadotropin in retractile testis. Neuro Endocrinol Lett. Feb. 2005;26(1):39-42. X-4. [pmid: 15726018].
499 Michikawa T, Matsufuji H, Araki Y, et al. Does early orchidopexy prevent morphological changes in undescended testes? A perioperative assessment using ultrasonography. Urol Int. 2008;81(2):210-4. X-4, X-5, X-6. [pmid: 18758222].
500 Mieusset R, Bujan L, Massat G, et al. Clinical and biological characteristics of infertile men with a history of cryptorchidism. Hum Reprod. Mar. 1995;10(3):613-9. X-4. [pmid: 7782441].
501 Milad MF, Haddad MJ, Zein TA, et al. Laparoscopy for the impalpable testes. Initial experience of one center. Int Surg. Apr–Jun. 1994;79(2):163-5. X-4, X-5, X-6. [pmid: 7928153].
502 Miller OF, Stock JA, Cilento BG, et al. Prospective evaluation of human chorionic gonadotropin in the differentiation of undescended testes from retractile testes. J Urol. Jun. 2003;169(6):2328-31. X-4, X-5, X-6, X-8. [pmid: 12771792].
503 Mininberg DT. The epididymis and testicular descent. Eur J Pediatr. Suppl 2. 1987;146:S28-30. X-4, X-5, X-6, X-7. [pmid: 2891516].
504 Mininberg DT, Chen ME, Witkin SS. Antisperm antibodies in cryptorchid boys. Eur J Pediatr. Suppl 2. 1993;152:S23-4. X-4, X-5, X-6, X-7. [pmid: 8101806].
505 Mininberg DT, Poppas DP. Cryptorchidism. Curr Ther Endocrinol Metab. 1994;5:318-23. X-1. [pmid: 7704745].
506 Mirilas P, Mamoulakis C, De Almeida M. Puberty does not induce serum antisperm surface antibodies in patients with previously operated cryptorchidism. J Urol. Dec. 2003;170(6 Pt 1):2432-5. X-10. [pmid: 14634446].
507 Misra D, Dias R, Kapila L. Scrotal fixation: a different surgical approach in the management of the low undescended testes. Urology. May. 1997;49(5):762-5. X-4, X-5, X-6, X-7. [pmid: 9145985].
508 Misra M, MacLaughlin DT, Donahoe PK, et al. Measurement of Mullerian inhibiting substance facilitates management of boys with microphallus and cryptorchidism. J Clin Endocrinol Metab. Aug. 2002;87(8):3598-602. X-5, X-6, X-7. [pmid: 12161481].
509 Miyamoto J, Asanuma H, Nakai H, et al. Mutational analysis of androgen receptor (AR) gene in 46,XY patients with ambiguous genitalia and normal testosterone secretion: Endocrinological characteristics of three patients with AR gene mutations. Clinical Pediatric Endocrinology. 2006;15(4):151-162. X-5, X-6, X-7.
510 Mlay SM, Sayi EN. Undescended testis in paediatric patients at Muhimbili Medical Centre, Dar es Salaam. East Afr Med J. Feb. 1994;71(2):135-7. X-5, X-6, X-7. [pmid: 7925044].
511 Mohta A. Cryptorchidism: what’s new?. Indian Pediatr. Oct. 2004;41(10):1019-23. X-1. [pmid: 15523127].
512 Molenaar JC. Surgical treatment of undescended testes. Eur J Pediatr. Dec. 1982;139(4):289-91. X-1. [pmid: 6133758].
513 Mollaeian M, Mehrabi V, Elahi B. Significance of epididymal and ductal anomalies associated with undescended testis: study in 652 cases. Urology. Jun. 1994;43(6):857-60. X-4, X-5, X-6, X-7. [pmid: 7910991].
514 Moller H, Cortes D, Engholm G, et al. Risk of testicular cancer with cryptorchidism and with testicular biopsy: cohort study. BMJ. Sep. 12. 1998;317(7160):729. X-5, X-6, X-7. [pmid: 9732342].
515 Moller H, Prener A, Skakkebaek NE. Testicular cancer, cryptorchidism, inguinal hernia, testicular atrophy, and genital malformations: case-control studies in Denmark. Cancer Causes Control. Mar. 1996;7(2):264-74. X-10. [pmid: 8740739].
516 Moore RG, Peters CA, Bauer SB, et al. Laparoscopic evaluation of the nonpalpable tests: a prospective assessment of accuracy. J Urol. Mar. 1994;151(3):728-31. X-4, X-5, X-6, X-7. [pmid: 7905933].
517 Moorhead D, Barnes R. Technique for bilateral orchiectomy leaving epididymis. Urology. Sep. 1981;18(3):294. X-1. [pmid: 7281398].
518 Mortazavi F, Aslanabadi S, Mahnama ST. Urogenital anomalies associated with anorectal malformations. Pakistan Journal of Medical Sciences. Apr. 2007;23(2):172-175. X-5, X-6, X-7.
519 Moul JW, Belman AB. A review of surgical treatment of undescended testes with emphasis on anatomical position. J Urol. Jul. 1988;140(1):125-8. X-4, X-5, X-6, X-7. [pmid: 2898022].
520 Mouriquand PD. Undescended testes in children: the paediatric urologist’s point of view. Eur J Endocrinol. Dec. 2008;159(Suppl 1):S83-6. X-1. [pmid: 18628346].
521 Muglia V, Tucci S Jr, Elias J Jr, et al. Magnetic resonance imaging of scrotal diseases: when it makes the difference. Urology. Mar. 2002;59(3):419-23. X-8. [pmid: 11880084].
522 Muller J, Skakkebaek NE. Abnormal germ cells in maldescended testes: a study of cell density, nuclear size and deoxyribonucleic acid content in testicular biopsies from 50 boys. J Urol. Apr. 1984;131(4):730-3. X-5, X-6, X-7. [pmid: 6142966].
523 Munch LC, Wood DP, Lucas BA, et al. Laparoscopy in urologic surgery: modern applications of the cystoscope. J Ky Med Assoc. Mar. 1993;91(3):92-8. X-1. [pmid: 8096538].
524 Myles LM, Holmes SJ. Human chorionic gonadotrophin and laparoscopy in the treatment of impalpable testes. J Pediatr Surg. Apr. 1994;29(4):551-2. X-4, X-5, X-6, X-8. [pmid: 7912269].
525 Nagler HM, Hensle TW. Furlow cylinder passer for orchiopexies. Urology. Mar. 1981;17(3):277. X-1. [pmid: 6111150].
526 Nagler HM, Hensle TW. Furlow cylinder passer for orchiopexies. Urology. [Journal]. 1986;28(5):31. X-1. [pmid: 3727226].
527 Nah SA, Giacomello L, Eaton S, et al. Surgical repair of incarcerated inguinal hernia in children: Laparoscopic or open?. European Journal of Pediatric Surgery. 2011;21(1):8-11. X-5, X-6, X-7. [pmid: 20938898].
528 Najmaldin A. Minimal access surgery in paediatrics. Arch Dis Child. Feb. 1995;72(2):107-9. X-1. [pmid: 7702369].
529 Nane I, Ziylan O, Esen T, et al. Primary gonadotropin releasing hormone and adjunctive human chorionic gonadotropin treatment in cryptorchidism: a clinical trial. Urology. Jan. 1997;49(1):108-11. X-4, X-5, X-6. [pmid: 9000196].
530 Naslund MJ, Gearhart JP, Jeffs RD. Laparoscopy: its selected use in patients with unilateral nonpalpable testis after human chorionic gonadotropin stimulation. J Urol. Jul. 1989;142(1):108-10. X-4, X-5, X-6, X-7. [pmid: 2567357].
531 Nassar AH. Laparoscopic-assisted orchidopexy: a new approach to the impalpable testis. J Pediatr Surg. Jan. 1995;30(1):39-41. X-4, X-5, X-6, X-7. [pmid: 7722826].
532 Navarro MA, Rodriguez-Tolra J, Arranz B, et al. Salivary testosterone in cryptorchid pubertal boys: a parameter to assess the gonadal function. Fertil Steril. Jul. 1989;52(1):128-31. X-5, X-6, X-7. [pmid: 2568277].
533 Navarro MA, Villabona CM, Aguilo F, et al. Salivary testosterone: its application in the follow-up of hypo- and hyper-androgenic states. J Clin Chem Clin Biochem. Oct. 1987;25(10):751-2. X-1. [pmid: 2891782].
534 Nawaz A, Matta H, Jacobsz A, et al. Unresectable hepatoblastoma: The role of preoperative chemotherapy. Annals of Saudi Medicine. 1999;19(6):553-556. X-5, X-6, X-7. [pmid: 17277482].
535 Neilson AG, Walker GM. Screening of testicular descent in older boys is worthwhile: an observational study. Br J Gen Pract. Mar. 2011;61(584):173-7. X-4, X-5, X-6, X-7. [pmid: 21375901].
536 Nguyen MT, Delaney DP, Kolon TF. Gene expression alterations in cryptorchid males using spermatozoal microarray analysis. Fertil Steril. Jul. 2009;92(1):182-7. X-4, X-5, X-6, X-7. [pmid: 18687424].
537 Nicotina PA, Romeo C, Arena S, et al. Immunohistology of aquaporin-1 and stem cell factor-receptor in human undescended testes. Pediatr Surg Int. Apr. 2004;20(4):271-5. X-5, X-6, X-7. [pmid: 15133700].
538 Niederberger C. Cryptorchidism, fertility, and cancer. J Androl. Jan–Feb. 2003;24(1):19-20. X-1. [pmid: 12514074].
539 Niedzielski J, Pisarska K, Przewratil P. The usefulness of testicular atrophy index in the assessment of undescended testicle--preliminary report. Rocz Akad Med Bialymst. 2003;48:112-4. X-5, X-6, X-7, X-8. [pmid: 14737954].
540 Nikkanen V, Punnonen R. Serum prolactin, FSH, LH and testosterone before and after vasectomy in normal men. Arch Androl. Jun. 1982;8(4):311-3. X-5, X-6, X-7. [pmid: 6810776].
541 Nistal M, Jimenez-Heffernan JA. Rete testis dysgenesis. A characteristic lesion of undescended testes. Arch Pathol Lab Med. Dec. 1997;121(12):1259-64. X-4, X-5, X-6, X-7. [pmid: 9431315].
542 Nistal M, Paniagua R, Abaurrea MA. Multi-vacuolated leydig cells in human adult cryptorchid testes. Andrologia. Sep–Oct. 1981;13(5):436-9. X-5, X-6, X-7. [pmid: 6119047].
543 Nistal M, Paniagua R, Riestra ML, et al. Bilateral prepubertal testicular biopsies predict significance of cryptorchidism-associated mixed testicular atrophy, and allow assessment of fertility. Am J Surg Pathol. Aug. 2007;31(8):1269-76. X-5, X-6, X-7. [pmid: 17667553].
544 Noble MJ, Wacksman J. Screening excretory urography in patients with cryptorchidism or hypospadias: a survey and review of the literature. J Urol. Jul. 1980;124(1):98-100. X-5, X-6, X-7. [pmid: 6106072].
545 Noh PH, Cooper CS, Snyder HM 3rd, et al. Testicular volume does not predict germ cell count in patients with cryptorchidism. J Urol. Feb. 2000;163(2):593-6. X-5, X-6, X-7. [pmid: 10647693].
546 Nutman A, Freud E, Itzhaky D, et al. High maternal estriol level in pregnancy as a predictor of surgical intervention for undescended testis. Fertil Steril. Jul. 2005;84(1):249-52. X-5, X-6, X-7. [pmid: 16009196].
547 Oates RD. Strategies for clinicians: Unraveling the genetic basis of severe male factor infertility. Sexuality, Reproduction and Menopause. February. 2011;9(1):25-30. X-1, X-5, X-6, X-7.
548 O’Brien BM. Second Runme Shaw lecture. State of the art of reconstructive microvascular surgery. Ann Acad Med Singapore. Oct. 1984;13(4):693-707. X-1. [pmid: 6152140].
549 O’Brien BM, Rao VK, MacLeod AM, et al. Microvascular testicular transfer. Plast Reconstr Surg. Jan. 1983;71(1):87-91. X-4, X-5, X-6. [pmid: 6129669].
550 O’Brien MF, Hegarty PK, Healy C, et al. One-stage Fowler-Stephens orchidopexy for impalpable undescended testis. Ir J Med Sci. Jan–Mar. 2004;173(1):18-9. X-4, X-5, X-6, X-7. [pmid: 15732230].
551 Odiase V, Whitaker RH. Analysis of cord length obtained during steps of orchiopexy. Br J Urol. Jun. 1982;54(3):308-10. X-4, X-5, X-6, X-7. [pmid: 6125228].
552 Oesch I, Ransley PG. Unilaterally impalpable testis. Eur Urol. 1987;13(5):324-6. X-4, X-5, X-6, X-7. [pmid: 2890526].
553 Ofordeme KG, Aslan AR, Nazir TM, et al. Apoptosis and proliferation in human undescended testes. BJU Int. Sep. 2005;96(4):634-8. X-4, X-5, X-6, X-8. [pmid: 16104924].
554 Oguzkurt P, Oz S, Kayaselcuk F. Ectopic adrenal tissue: An incidental finding during inguinoscrotal operations in children. Hernia. 2002;6(2):62-63. X-5, X-6, X-7. [pmid: 12152640].
555 Oh J, Landman J, Evers A, et al. Management of the postpubertal patient with cryptorchidism: an updated analysis. J Urol. Mar. 2002;167(3):1329-33. X-1, X-5, X-6, X-7. [pmid: 11832725].
556 O’Hali W, Anderson P, Giacomantonio M. Management of impalpable testes: indications for abdominal exploration. J Pediatr Surg. Jun. 1997;32(6):918-20. X-5, X-6, X-7, X-8. [pmid: 9200101].
557 Okuyama A, Namiki M, Aono T, et al. Improvement of spermatogenesis by hCG and hMG treatment in pubertal boys with history of orchiopexy at early childhood. Arch Androl. Suppl. 1984;12:29-33. X-2. [pmid: 6152576].
558 Okuyama A, Nishimoto N, Yoshioka T, et al. Gonadal findings in cryptorchid boys with Noonan’s phenotype. Eur Urol. 1981;7(5):274-7. X-4, X-5, X-6, X-7. [pmid: 6113962].
559 Onal B, Kogan BA. Additional benefit of laparoscopy for nonpalpable testes: finding a contralateral patent processus. Urology. Jun. 2008;71(6):1059-63. X-4, X-5, X-6, X-7. [pmid: 18342920].
560 Osifo DO, Osaigbovo EO. The prevalence, postnatal descent, and complications of undescended testes among children who underwent neonatal circumcision in Benin City, Nigeria. J Pediatr Surg. Apr. 2009;44(4):791-6. X-4, X-5, X-6, X-7. [pmid: 19361642].
561 Osuna JA, Arata de Bellabarba G, Temponi AF, et al. Cryptorchidism: treatment with human chorionic gonadotropin--a Venezuelan experience. Arch Androl. Nov–Dec. 1997;39(3):229-35. X-4. [pmid: 9352035].
562 O’Toole S. A potpourri of pediatric urology. Journal of Pediatric Urology. Aug. 2007;3(4):321-322. X-1.
563 Otto F. Male breast cancer - Neglected tumour. European Journal of Cancer. September. 2011;47(SUPPL 3):S340-341. X-1. [pmid: 21944007].
564 Paasch U, Thieme C, Grunewald S, et al. Electronic data base systems support the evaluation of male infertility factors, example cryptorchidism. Urol Int. 2004;72(2):154-61. X-4, X-5, X-6, X-7. [pmid: 14963358].
565 Palacio MM, Sferco A, Garcia Fernanndez AE, et al. Inguinal cordopexy: a simple and effective new technique for securing the testes in reoperative orchiopexy. J Pediatr Surg. Mar. 1999;34(3):424-5. X-4, X-5, X-6, X-7. [pmid: 10211646].
566 Palmer LS, Gill B, Kogan SJ. Endocrine analysis of childhood monorchism. J Urol. Aug. 1997;158(2):594-6. X-5, X-6, X-7. [pmid: 9224372].
567 Palmer LS, Rastinehad A. Incidence and concurrent laparoscopic repair of intra-abdominal testis and contralateral patent processus vaginalis. Urology. Aug. 2008;72(2):297-9. discussion 299. X-4, X-5, X-6. [pmid: 18579186].
568 Papp G, Hoznek A. Clinical effect of cryptocur by undescended testicles. Andrologia. Jul–Aug. 1989;21(4):391-5. X-5, X-8. [pmid: 2571314].
569 Papparella A, Parmeggiani P, Cobellis G, et al. Laparoscopic management of nonpalpable testes: a multicenter study of the Italian Society of Video Surgery in Infancy. J Pediatr Surg. Apr. 2005;40(4):696-700. X-4. [pmid: 15852282].
570 Papparella A, Romano M, Noviello C, et al. The value of laparoscopy in the management of non-palpable testis. J Pediatr Urol. Dec. 2010;6(6):550-4. X-4, X-5, X-6. [pmid: 20106723].
571 Papparella A, Zamparelli M, Cobellis G, et al. Laparoscopy for nonpalpable testis: Is inguinal exploration always necessary when the cord structures enter the inguinal ring?. Pediatric Endosurgery and Innovative Techniques. 1999;3(1):29-33. X-4, X-5, X-6.
572 Pappis CH, Argianas SA, Bousgas D, et al. Unsuspected urological anomalies in asymptomatic cryptorchid boys. Pediatr Radiol. 1988;18(1):51-3. X-4, X-5, X-6, X-7. [pmid: 2893330].
573 Parigi GB, Bardoni B, Avoltini V, et al. Is bilateral congenital anorchia genetically determined?. Eur J Pediatr Surg. Oct. 1999;9(5):312-5. X-5, X-6, X-7. [pmid: 10584191].
574 Park JH, Park YH, Park K, et al. Diagnostic laparoscopy for the management of impalpable testes. Korean Journal of Urology. May. 2011;52(5):355-358. X-4. [pmid: 21687397].
575 Parkash S, Ramakrishnan K, Bagdi RK. Orchiopexy: trans-septal ipsilateral positioning. Br J Urol. Feb. 1983;55(1):79-80. X-4, X-5, X-6. [pmid: 6130813].
576 Parker L. Causes of testicular cancer. Lancet. Sep. 20. 1997;350(9081):827-8. X-1. [pmid: 9310598].
577 Parkinson MC, Swerdlow AJ, Pike MC. Carcinoma in situ in boys with cryptorchidism: when can it be detected?. Br J Urol. Apr. 1994;73(4):431-5. X-4, X-5, X-6, X-7. [pmid: 7911060].
578 Parsons JK, Ferrer F, Docimo SG. The low scrotal approach to the ectopic or ascended testicle: prevalence of a patent processus vaginalis. J Urol. May. 2003;169(5):1832-3. discussion 1833. X-4, X-5, X-6. [pmid: 12686856].
579 Partsch CJ, von Buren E, Brand M, et al. Efficacy of the subcutaneous reformulated triptorelin depot in children with central precocious puberty. Acta Paediatr. Dec. 1998;87(12):1240-4. X-5, X-6, X-7. [pmid: 9894822].
580 Pasqualini T, Chemes H, Rivarla MA. Testicular testosterone levels during puberty in cryptorchidism. Clin Endocrinol (Oxf). Dec. 1981;15(6):545-54. X-4, X-5, X-6, X-7. [pmid: 6120056].
581 Passerotti C, Peters CA. Robotic-assisted laparoscopy applied to reconstructive surgeries in children. World J Urol. Jun. 2006;24(2):193-7. X-1. [pmid: 16758249].
582 Patel RP, Kolon TF, Huff DS, et al. Testicular microlithiasis and antisperm antibodies following testicular biopsy in boys with cryptorchidism. J Urol. Nov. 2005;174(5):2008-10. discussion 2010. X-4, X-5, X-6. [pmid: 16217379].
583 Patel RP, Kolon TF, Huff DS, et al. Cryptorchid testis histopathology in myelomeningocele patients. J Pediatr Urol. Dec. 2008;4(6):434-7. X-4, X-5, X-6, X-7. [pmid: 18644747].
584 Patil KK, Duffy PG, Woodhouse CR, et al. Long-term outcome of Fowler-Stephens orchiopexy in boys with prune-belly syndrome. J Urol. Apr. 2004;171(4):1666-9. X-2. [pmid: 15017263].
585 Peddle JF. Removal of an intra-abdominal testis in the dog. Mod Vet Pract. Mar. 1981;62(3):231-3. X-5, X-6, X-7. [pmid: 6111021].
586 Pekkafali MZ, Sahin C, Ilbey YO, et al. Comparison of ultrasonographic and laparoscopic findings in adult nonpalpable testes cases. Eur Urol. Jul. 2003;44(1):124-7. X-2. [pmid: 12814687].
587 Pellerin D. Cryptorchidism and surgery. Prog Clin Biol Res. 1985;203:215-20. X-5, X-6, X-7. [pmid: 2870510].
588 Peloquin F, Kiruluta G, Quiros E. Management of an impalpable testis: the role of laparoscopy. Can J Surg. Dec. 1991;34(6):587-90. X-10. [pmid: 1684136].
589 Penna FJ, Nguyen HT, Passerotti CC, et al. The concordance of testicular anatomic location in bilateral cryptorchidism. J Pediatr Urol. Feb. 2011;7(1):52-6. X-4, X-5, X-6. [pmid: 20392672].
590 Perovic S, Janic N. Laparoscopy in the diagnosis of non-palpable testes. Br J Urol. Mar. 1994;73(3):310-3. X-4, X-5, X-6. [pmid: 7909273].
591 Perovic S, Janic N. A short vas deferens limiting successful laparoscopic testicular descent. Br J Urol. Jan. 1997;79(1):120-1. X-4, X-5, X-6. [pmid: 9043510].
592 Pesce C, d’Agostino S, Costa L, et al. Reoperative orchiopexy: surgical aspects and functional outcome. Pediatr Surg Int. 2001;17(1):62-4. X-4, X-5, X-6. [pmid: 11294272].
593 Pettersson A, Richiardi L, Nordenskjold A, et al. Age at surgery for undescended testis and risk of testicular cancer. N Engl J Med. May. 3. 2007;356(18):1835-41. X-4, X-5, X-6. [pmid: 17476009].
594 Pike MC, Chilvers C, Peckham MJ. Effect of age at orchidopexy on risk of testicular cancer. Lancet. May. 31. 1986;1(8492):1246-8. X-4, X-5, X-6, X-7. [pmid: 2872394].
595 Pinczowski D, McLaughlin JK, Lackgren G, et al. Occurrence of testicular cancer in patients operated on for cryptorchidism and inguinal hernia. J Urol. Nov. 1991;146(5):1291-4. X-4, X-5, X-6, X-7. [pmid: 1682512].
596 Pintus C, Coppola R, Talamo M, et al. Laparoscopic approach for nonpalpable abdominal testis. Surg Laparosc Endosc. Apr. 1997;7(2):156-8. X-4, X-5, X-6. [pmid: 9109249].
597 Pirgon O, Atabek ME, Oran B, et al. Treatment with human chorionic gonadotropin induces left ventricular mass in cryptorchid boys. J Pediatr Endocrinol Metab. May. 2009;22(5):449-54. X-5, X-6, X-7, X-8. [pmid: 19618664].
598 Pisani E, Austoni E, Trinchieri A, et al. Urological laparoscopy: our preliminary results. Arch Ital Urol Androl. Dec. 1993;65(6):687-94. X-4, X-5, X-6, X-7. [pmid: 8312953].
599 Piscitelli B, Martone A, Tarallo L. Feasibility of tele-thermography in localizing undescended testes. Acta Thermographica. [Journal]. 1982;7(2):50-52. X-8.
600 Pitteloud N, Hayes FJ, Dwyer A, et al. Predictors of outcome of long-term GnRH therapy in men with idiopathic hypogonadotropic hypogonadism. J Clin Endocrinol Metab. Sep. 2002;87(9):4128-36. X-5, X-6, X-7. [pmid: 12213860].
601 Plotzker ED, Rushton HG, Belman AB, et al. Laparoscopy for nonpalpable testes in childhood: is inguinal exploration also necessary when vas and vessels exit the inguinal ring?. J Urol. Aug. 1992;148(2 Pt 2):635-7. discussion 638. X-4, X-5, X-6. [pmid: 1353546].
602 Poenaru D, Homsy YL, Peloquin F, et al. Laparoscopic management of the impalpable abdominal testis. Urology. Nov. 1993;42(5):574-8. discussion 578–9. X-4, X-5, X-6. [pmid: 7901932].
603 Pohl HG, Joyce GF, Wise M, et al. Cryptorchidism and hypospadias. J Urol. May. 2007;177(5):1646-51. X-5, X-6, X-7. [pmid: 17437777].
604 Polascik TJ, Chan-Tack KM, Jeffs RD, et al. Reappraisal of the role of human chorionic gonadotropin in the diagnosis and treatment of the nonpalpable testis: a 10-year experience. J Urol. Aug. 1996;156(2 Pt 2):804-6. X-8. [pmid: 8683788].
605 Pommerville P, Futter NG, McKay DE, et al. The role of gonadal venography in the management of the adult with non-palpable undescended testis. Br J Urol. Aug. 1982;54(4):408-10. X-4, X-5, X-6. [pmid: 6126241].
606 Ponchietti R, Grechi G. Fertility in unilateral cryptorchidism: review of 104 cases. Acta Eur Fertil. Jul–Aug. 1986;17(4):277-8. X-4, X-5, X-6. [pmid: 2883799].
607 Poomthavorn P, Stargatt R, Zacharin M. Psychosexual and psychosocial functions of anorchid young adults. J Clin Endocrinol Metab. Jul. 2009;94(7):2502-5. X-5, X-6, X-7. [pmid: 19366856].
608 Poppas DP, Lemack GE, Mininberg DT. Laparoscopic orchiopexy: clinical experience and description of technique. J Urol. Feb. 1996;155(2):708-11. X-4, X-5, X-6. [pmid: 8558711].
609 Poppas DP, Wei JT, Mingin GC. The concealed laparoscopic orchidopexy. BJU Int. Jul. 2000;86(1):138-9. X-4, X-5, X-6. [pmid: 10886098].
610 Rabinowitz R, Hulbert WC Jr. Cryptorchidism. Pediatr Rev. Jul. 1994;15(7):272-4. X-1. [pmid: 7916154].
611 Rabinowitz R, Hulbert WC Jr. Late presentation of cryptorchidism: the etiology of testicular re-ascent. J Urol. May. 1997;157(5):1892-4. X-4, X-5, X-6, X-8. [pmid: 9112557].
612 Radmayr C, Corvin S, Studen M, et al. Cryptorchidism, open processus vaginalis, and associated hernia: laparoscopic approach to the internal inguinal ring. Eur Urol. Dec. 1999;36(6):631-4. X-4, X-5, X-6, X-8. [pmid: 10559618].
613 Raivio T, Dunkel L. Inverse relationship between serum inhibin B and FSH levels in prepubertal boys with cryptorchidism. Pediatr Res. Nov. 1999;46(5):496-500. X-4, X-5, X-6, X-7. [pmid: 10541309].
614 Raivio T, Palvimo JJ, Dunkel L, et al. Novel assay for determination of androgen bioactivity in human serum. J Clin Endocrinol Metab. Apr. 2001;86(4):1539-44. X-5, X-6, X-7. [pmid: 11297580].
615 Rajendran R, Sathyanji EK, Pai R. Age of treatment of undescended testis--a study. J Indian Med Assoc. Nov. 2002;100(11):662-3. 670. X-4, X-5, X-6. [pmid: 12797638].
616 Rajfer J. Technique of orchiopexy. Urol Clin North Am. Oct. 1982;9(3):421-7. X-1. [pmid: 6128826].
617 Rajfer J, Tauber A, Zinner N, et al. The use of computerized tomography scanning to localize the impalpable testis. J Urol. May. 1983;129(5):972-4. X-8. [pmid: 6133961].
618 Rangarajan M, Jayakar SM. Laparoscopic orchiectomy for the adult impalpable testis--experiences in a rural teaching hospital. Surg Endosc. Jan. 2007;21(1):66-9. X-4, X-5, X-6, X-7. [pmid: 17063294].
619 Rao M, Wilkinson J, Benton DC. Screening for undescended testes. Arch Dis Child. Aug. 1991;66(8):934-7. X-5, X-6, X-7, X-8. [pmid: 1681788].
620 Redman JF. Impalpable testes: observations based on 208 consecutive operations for undescended testes. J Urol. Sep. 1980;124(3):379-81. X-4, X-5, X-6, X-7. [pmid: 6107387].
621 Redman JF. The ascending (acquired undescended) testis: a phenomenon?. BJU Int. Jun. 2005;95(9):1165-7. X-1. [pmid: 15892793].
622 Reece-Smith H, Moisey CU. The undescended testicle: a continuing failure. Br Med J (Clin Res Ed). Jun. 2. 1984;288(6431):1653. X-4, X-5, X-6, X-7.
623 Reid S, Renwick A, Seal S, et al. Biallelic BRCA2 mutations are associated with multiple malignancies in childhood including familial Wilms tumour. Journal of Medical Genetics. Feb. 2005;42(2):147-151. X-5, X-6, X-7. [pmid: 15689453].
624 Reinberg Y, Gonzalez R. Laparoscopic urological surgery in children. Semin Urol. Aug. 1992;10(3):161-3. X-1. [pmid: 1355926].
625 Rich MA, Siegel JF, Brock WA. Laparoscopy in children with cryptorchidism. Children’s Hospital Quarterly. 1993;3(4):283-285. X-4, X-5, X-6, X-8.
626 Riebel T, Herrmann C, Wit J, et al. Ultrasonographic late results after surgically treated cryptorchidism. Pediatr Radiol. Mar. 2000;30(3):151-5. X-4, X-5, X-6. [pmid: 10755751].
627 Rijwani A. Picture quiz. Perinatology. Sep. 2003;5(5):239-240. X-1.
628 Ritchey ML, Bloom D. Summary of the urology section. American Academy of Pediatrics. Pediatrics. Jul. 1995;96(1 Pt 1):138-43. X-1. [pmid: 7596702].
629 Ritchey ML, Bloom DA. Modified dartos pouch orchiopexy. Urology. Jan. 1995;45(1):136-8. X-1, X-4, X-5, X-6. [pmid: 7817467].
630 Robertson JF, Azmy AF, Cochran W. Assent to ascent of the testis. Br J Urol. Feb. 1988;61(2):146-7. X-4, X-5, X-6, X-7. [pmid: 2894881].
631 Robertson SA, Munro FD, Mackinlay GA. Two-stage Fowler-Stephens orchidopexy preserving the gubernacular vessels and a purely laparoscopic second stage. J Laparoendosc Adv Surg Tech A. Feb. 2007;17(1):101-7. X-4, X-5, X-6. [pmid: 17362185].
632 Rockey KE, Cusack TJ. Ultrasound imaging of the scrotum. A pictorial guide to its varied capabilities. Postgrad Med. Jul. 1987;82(1):219-27. X-1, X-5, X-6, X-7. [pmid: 2885819].
633 Rohatgi M, Gupta DK, Menon PS, et al. Hormonal therapy in undescended testes. Indian J Pediatr. Jan–Feb. 1991;58(1):79-83. X-4, X-5, X-6. [pmid: 1682249].
634 Romano AA, Dana K, Bakker B, et al. Growth response, near-adult height, and patterns of growth and puberty in patients with Noonan syndrome treated with growth hormone. Journal of Clinical Endocrinology and Metabolism. July. 2009;94(7):2338-2344. X-5, X-6, X-7. [pmid: 19401366].
635 Rosello PJ, Novoa R, Milazzo C. Hormonal and testicular volume studies in cryptorchidism. Bol Asoc Med P R. Mar. 1982;74(3):66-9. X-4, X-5, X-6. [pmid: 6127088].
636 Ross JH, Gill IS, Kay R. Needlescopic approach to the nonpalpable testis. Pediatric Endosurgery and Innovative Techniques. 2000;4(3):195-200. X-1.
637 Rubin SZ, Gershater R. Testicular venography as an accurate indicator of true cryptorchism. Can J Surg. Jul. 1981;24(4):360-2. X-8. [pmid: 6115709].
638 Rubin SZ, Mueller DL, Amundson GM, et al. Ultrasonography and the impalpable testis. Aust N Z J Surg. Aug. 1986;56(8):609-11. X-2. [pmid: 2875709].
639 Rushton HG Jr. This Month in Pediatric Urology. Journal of Urology. November. 2009;182(5):2094-2095. X-1.
640 Rushton HG Jr. This Month in Pediatric Urology. Journal of Urology. May. 2010;183(5):1661-1662. X-1.
641 Rusnack SL, Wu HY, Huff DS, et al. The ascending testis and the testis undescended since birth share the same histopathology. J Urol. Dec. 2002;168(6):2590-1. X-4, X-5, X-6, X-7. [pmid: 12441991].
642 Ryhanen P, Adamski J, Puhakka K, et al. Postoperative pain relief in children. A comparison between caudal bupivacaine and intramuscular diclofenac sodium. Anaesthesia. Jan. 1994;49(1):57-61. X-4, X-5, X-6, X-7. [pmid: 7906104].
643 Saeed A, Nawaz M, Griffin S. An audit of undescended testis treated at DHQ Hospital Abbottabad. Medical Forum Monthly. July. 2011;22(7):7-10. X-11.
644 Saggese G, Ghirri P, Gabrielli S, et al. Hormonal therapy for cryptorchidism with a combination of human chorionic gonadotropin and follicle-stimulating hormone. Success and relapse rate. Am J Dis Child. Aug. 1989;143(8):980-2. X-4. [pmid: 2569267].
645 Saha SK. Cordopexy: a new approach to the undescended testis. A review of 2 to 5-year followup. J Urol. Mar. 1983;129(3):561-4. X-4, X-5, X-6. [pmid: 6132014].
646 Saha SK. Cordopexy. A new approach to the treatment of undescended testis. J R Coll Surg Edinb. Mar. 1984;29(2):105-6. X-4, X-5, X-6. [pmid: 6145797].
647 Sahai A, Kucheria R, Challacombe B, et al. Video consent: a pilot study of informed consent in laparoscopic urology and its impact on patient satisfaction. JSLS. Jan–Mar. 2006;10(1):21-5. X-5, X-6, X-7. [pmid: 16709351].
648 Samadi AA, Palmer LS, Franco I. Laparoscopic orchiopexy: report of 203 cases with review of diagnosis, operative technique, and lessons learned. J Endourol. Aug. 2003;17(6):365-8. X-4, X-5, X-6. [pmid: 12965060].
649 Sangrasi AK, Laghari AA, Abbasi MR, et al. Laparoscopic-assisted management of impalpable testis in patients older than 10 years. JSLS. Apr–Jun. 2010;14(2):251-5. X-2. [pmid: 20932378].
650 Sarihan H, Sari A, Abes M, et al. Nonpalpable undescending testis. Value of magnetic resonance imaging. Minerva Urol Nefrol. Dec. 1998;50(4):233-6. X-2. [pmid: 9973808].
651 Sarmah A. Late diagnosis of cryptorchidism: a failure of medical screening?. Arch Dis Child. Jun. 1992;67(6):728-30. X-4, X-5, X-6, X-7. [pmid: 1352673].
652 Sasagawa I, Nakada T, Kubota Y, et al. Gonadal function and testicular histology in Noonan’s syndrome with bilateral cryptorchidism. Arch Androl. Mar–Apr. 1994;32(2):135-40. X-5, X-6, X-7. [pmid: 7909426].
653 Satar N, Bayazit Y, Doran S. Laparoscopy in the management of impalpable testicle. Acta Chir Belg. Nov–Dec. 2005;105(6):662-6. X-4, X-5, X-6, X-7. [pmid: 16438083].
654 Sathyanarayana S. Phthalates and Children’s Health. Current Problems in Pediatric and Adolescent Health Care. Feb. 2008;38(2):34-49. X-1. [pmid: 18237855].
655 Saw KC, Eardley I, Dennis MJ, et al. Surgical outcome of orchiopexy. I. Previously unoperated testes. Br J Urol. Jul. 1992;70(1):90-4. X-4, X-5, X-6. [pmid: 1353397].
656 Scharli AF. The undescended testicle: Viewpoint of the endocrinologist. Editorial comment. Pediatric Surgery International. [Journal]. 1987;2(3):131. X-1.
657 Schindler AM, Diaz P, Cuendet A, et al. Follicle-stimulating hormone. IV. Study of the histology of pubertal cryptorchid and scrotal testes in relation to the secretion of gonadotropins. Fertil Steril. Jun. 1982;37(6):828-36. X-5, X-6, X-7. [pmid: 6123450].
658 Schleef J, von Bismarck S, Burmucic K, et al. Groin exploration for nonpalpable testes: laparoscopic approach. J Pediatr Surg. Nov. 2002;37(11):1552-5. X-4, X-5, X-6, X-7. [pmid: 12407538].
659 Schoorl M. Classification and diagnosis of undescended testes. Eur J Pediatr. Dec. 1982;139(4):253-4. X-1, X-4, X-5, X-6. [pmid: 6133751].
660 Schwarz HP, Aebi S, Perisic M. Success and relapse rate after treatment of cryptorchidism with intranasal LHRH. Acta Paediatr Scand. Mar. 1985;74(2):274-80. X-4, X-5, X-6, X-7. [pmid: 2859731].
661 Schwentner C, Oswald J, Kreczy A, et al. Neoadjuvant gonadotropin-releasing hormone therapy before surgery may improve the fertility index in undescended testes: a prospective randomized trial. J Urol. Mar. 2005;173(3):974-7. X-10. [pmid: 15711353].
662 Selice R, Ferlin A, Garolla A, et al. Effects of endogenous FSH on normal human spermatogenesis in adults. International Journal of Andrology. December. 2011;34(6 PART 2):e511-e517. X-5, X-6, X-7. [pmid: 21790654].
663 Semple D, Findlow D, Aldridge LM, et al. The optimal dose of ketamine for caudal epidural blockade in children. Anaesthesia. Dec. 1996;51(12):1170-2. X-4, X-5, X-6, X-7. [pmid: 9038462].
664 Shafik A. Extraperitoneal inguinal pelviscopy: diagnostic tool for nonpalpable testes. J Endourol. Feb. 1994;8(1):53-5. X-4, X-5, X-6. [pmid: 7910505].
665 Shafik A, El-Sibal O, Shafik I. Electro-orchidogram: a non-invasive diagnostic tool in testicular pathologies. Med Sci Monit. Aug. 2006;12(8):MT51-5. X-5, X-6, X-7. [pmid: 16865074].
666 Shah A. Impalpable testes--is imaging really helpful?. Indian Pediatr. Aug. 2006;43(8):720-3. X-2. [pmid: 16951436].
667 Shalaby MM, Shoma AM, Elanany FG, et al. Management of the looping vas deferens during laparoscopic orchiopexy. J Urol. Jun. 2011;185(6 Suppl):2455-7. X-4, X-5, X-6. [pmid: 21555012].
668 Shames DA. Practical approach to the undescended testicle. J S C Med Assoc. Dec. 1982;78(12):664-6. X-1. [pmid: 6130185].
669 Shanberg AM. Laparoscopic orchiopexy for intraperitoneal testicles. West J Med. Apr. 1996;164(4):343. X-1. [pmid: 8732737].
670 Sharifiaghdas F, Beigi FM. Impalpable testis: laparoscopy or inguinal canal exploration?. Scand J Urol Nephrol. 2008;42(2):154-7. X-4, X-5, X-6. [pmid: 17853013].
671 Shenfeld O, Eldar I, Lotan G, et al. Intraoperative irrigation with bupivacaine for analgesia after orchiopexy and herniorrhaphy in children. J Urol. Jan. 1995;153(1):185-7. X-4, X-5, X-6, X-7. [pmid: 7966769].
672 Shera AH, Baba AA, Gupta SK, et al. Undescended testis: how extensive should the work up be?. Afr J Paediatr Surg. May–Aug. 2010;7(2):92-5. X-10. [pmid: 20431218].
673 Shibata Y, Kojima Y, Mizuno K, et al. Optimal cutoff value of contralateral testicular size for prediction of absent testis in Japanese boys with nonpalpable testis. Urology. Jul. 2010;76(1):78-81. X-4, X-5, X-6, X-7. [pmid: 20472272].
674 Shima H, Okamoto E, Terakawa T, et al. Is hormonal therapy necessary in prepubertal boys with cryptorchidism?. Int Urol Nephrol. 1991;23(6):605-9. X-4, X-5, X-6, X-7. [pmid: 1685151].
675 Shun a, Puri P. Inguinal hernia in the newborn. A 15-year review. Pediatric Surgery International. [Journal]. 1988;3(2–3):156-157. X-4, X-5, X-6, X-7.
676 Singh A, Singh R. Current status of cryptorchism. Indian J Pediatr. Jan–Feb. 1983;50(402):73-7. X-1. [pmid: 6137455].
677 Singh RR, Rajimwale A, Nour S. Laparoscopic management of impalpable testes: Comparison of different techniques. Pediatric Surgery International. December. 2011;27(12):1327-30. X-10. [pmid: 21882045].
678 Sinisi AA, D’Apuzzo A, Pasquali D, et al. Antisperm antibodies in prepubertal boys treated with chemotherapy for malignant or non-malignant diseases and in boys with genital tract abnormalities. Int J Androl. Feb. 1997;20(1):23-8. X-5, X-6, X-7. [pmid: 9202987].
679 Sinisi AA, Pasquali D, Papparella A, et al. Antisperm antibodies in cryptorchidism before and after surgery. J Urol. Nov. 1998;160(5):1834-7. X-4, X-5, X-6, X-7. [pmid: 9783970].
680 Skakkebaek NE, Berthelsen JG, Muller J. Carcinoma-in-situ of the undescended testis. Urol Clin North Am. Oct. 1982;9(3):377-85. X-1. [pmid: 6128821].
681 Skandhan KP, Khan PS, Sumangala B. DDT and male reproductive system. Research Journal of Environmental Toxicology. 2011;5(2):76-80. X-1.
682 Smith PH. Review of the treatment of testicular cancer. Turkish Journal of Pediatrics. 1984;26(1–4):285-289. X-1. [pmid: 6537081].
683 Smolko MJ, Kaplan GW, Brock WA. Location and fate of the nonpalpable testis in children. J Urol. Jun. 1983;129(6):1204-6. X-5, X-6, X-7, X-8. [pmid: 6133965].
684 Snodgrass W, Bush N, Holzer M, et al. Current referral patterns and means to improve accuracy in diagnosis of undescended testis. Pediatrics. Feb. 2011;127(2):e382-8. X-10. [pmid: 21262892].
685 Somri M, Gaitini LA, Vaida SJ, et al. Effect of ilioinguinal nerve block on the catecholamine plasma levels in orchidopexy: comparison with caudal epidural block. Paediatr Anaesth. Nov. 2002;12(9):791-7. X-4, X-5, X-6, X-7. [pmid: 12519139].
686 Stec AA, Thomas JC, DeMarco RT, et al. Incidence of testicular ascent in boys with retractile testes. J Urol. Oct. 2007;178(4 Pt 2):1722-4. discussion 1724–5. X-5, X-6, X-7. [pmid: 17707014].
687 Steckler RE, Zaontz MR, Skoog SJ, et al. Cryptorchidism, pediatricians, and family practitioners: patterns of practice and referral. J Pediatr. Dec. 1995;127(6):948-51. X-5, X-6, X-7. [pmid: 8523194].
688 Steinhardt GF, Kroovand RL, Perlmutter AD. Orchiopexy: planned 2-stage technique. J Urol. Mar. 1985;133(3):434-5. X-4, X-5, X-6. [pmid: 2857793].
689 Stephens FD. Fowler-Stephens orchiopexy. Semin Urol. May. 1988;6(2):103-6. X-1. [pmid: 2903522].
690 Strittmatter T. Testicular autotransplantation - the Monchengladbach experience. Horm Res. 2001;55(1):51. X-10. [pmid: 11423744].
691 Studnik S, Lewis H, John A. Effectiveness of child health surveillance in lowering age of referral and surgery for undescended testis. Ambulatory Child Health. 2001;7(3/4):269-273. X-4, X-5, X-6, X-7.
692 Sudrania OP. Orchiopexy: neo-gubernaculum technique. Br J Urol. May. 1992;69(5):550-1. X-1. [pmid: 1352476].
693 Swerdlow AJ, Higgins CD, Pike MC. Risk of testicular cancer in cohort of boys with cryptorchidism. BMJ. May. 24. 1997;314(7093):1507-11. X-5, X-6, X-7. [pmid: 9169396].
694 Taha SA, Abdulkader A, Kamal BA, et al. Management of an unusually high postpubertal presentation of cryptorchidism. Int Surg. Apr–Jun. 1990;75(2):105-8. X-4, X-5, X-6, X-7. [pmid: 1974246].
695 Tak MS, Patnaik R, Zargar AH, et al. Hormonal and surgical management of cryptorchidism. JK Practitioner. 1999;6(2):118-120. X-5, X-6, X-8.
696 Tanaka YO, Mesaki N, Kurosaki Y, et al. Testicular feminization: role of MRI in diagnosing this rare male pseudohermaphroditism. J Comput Assist Tomogr. Nov–Dec. 1998;22(6):884-8. X-5, X-6, X-7. [pmid: 9843226].
697 Tang PMY, Leung MWY, Chao NSY, et al. Use of laparoscopy in the management of impalpable testis in children. Hong Kong Journal of Paediatrics. 2009;14(3):172-176. X-4, X-5, X-6, X-8.
698 Tapanainen J, Koivisto M, Huhtaniemi I, et al. Effect of gonadotropin-releasing hormone on pituitary-gonadal function of male infants during the first year of life. Journal of Clinical Endocrinology and Metabolism. 1982;55(4):689-692. X-5, X-6, X-7, X-8. [pmid: 6125525].
699 Tapanainen J, Martikainen H, Dunkel L. Steroidogenic response to a single injection of hCG in pre- and early pubertal cryptorchid boys. Clinical Endocrinology. 1983;18(4):355-362. X-5, X-6, X-7, X-8. [pmid: 6135519].
700 Tasian GE, Copp HL, Baskin LS. Diagnostic imaging in cryptorchidism: Utility, indications, and effectiveness. Journal of Pediatric Surgery. December. 2011;46(12):2406-2413. X-1. [pmid: 22152893].
701 Taskinen S, Hovatta O, Wikstrom S. Early treatment of cryptorchidism, semen quality and testicular endocrinology. J Urol. Jul. 1996;156(1):82-4. X-4, X-5, X-6, X-7. [pmid: 8648845].
702 Taskinen S, Hovatta O, Wikstrom S. Sexual development in patients treated for cryptorchidism. Scand J Urol Nephrol. Aug. 1997;31(4):361-4. X-4. [pmid: 9290166].
703 Taskinen S, Lehtinen A, Hovatta O. Prostatic volume in young adults after treatment of cryptorchidism in childhood. Scand J Urol Nephrol. 2006;40(5):376-9. X-4, X-5, X-6, X-7. [pmid: 17060083].
704 Taskinen S, Wikstrom S. Effect of age at operation, location of testis and preoperative hormonal treatment on testicular growth after cryptorchidism. J Urol. Aug. 1997;158(2):471-3. X-10. [pmid: 9224326].
705 Tekant G, Emir H, Froglu E, et al. Experience with laparoscopy in nonpalpable testis. Horm Res. 2001;55(1):52. X-4, X-5, X-6, X-8. [pmid: 11423745].
706 Tellaloglu S, Kadioglu A, Kilicaslan I, et al. Cryptorchidism: is orchidopexy always preventive treatment for infertility?. Acta Chir Hung. 1994;34(1–2):195-201. X-4. [pmid: 7604624].
707 Tennenbaum SY, Lerner SE, McAleer IM, et al. Preoperative laparoscopic localization of the nonpalpable testis: a critical analysis of a 10-year experience. J Urol. Mar. 1994;151(3):732-4. X-4, X-5, X-6. [pmid: 7905934].
708 Thinyu S, Muttarak M. Role of ultrasonography in diagnosis of scrotal disorders: A review of 110 cases. Biomedical Imaging and Intervention Journal. 2009;5((1)(e2)). X-5, X-6, X-7, X-8.
709 Thorup J, Cortes D, Nielsen OH. Clinical and histopathologic evaluation of operated maldescended testes after luteinizing hormone-releasing hormone treatment. Pediatric Surgery International. 1993;8(5):419-422. X-4, X-5, X-6, X-7.
710 Thorup J, Cortes D, Nielsen OH. Clinical and histopathological evaluation of operated maldescended testes after LH-RH treatment. Eur J Pediatr. Suppl 2. 1993;152:S37. X-1. [pmid: 8101812].
711 Thorup J, Corties D. The incidence of maldescended testes in Denmark. Pediatric Surgery International. 1990;5(1):2-5. X-5, X-6, X-7.
712 Thorup J, Kvist N, Larsen P, et al. Clinical results of early and late operative correction of undescended testes. Br J Urol. Jun. 1984;56(3):322-5. X-4, X-5, X-6. [pmid: 6152715].
713 Thorup J, Petersen BL, Kvist K, et al. Bilateral vanished testes diagnosed with a single blood sample showing very high gonadotropins (follicle-stimulating hormone and luteinizing hormone) and very low inhibin B. Scandinavian Journal of Urology and Nephrology. December. 2011;45(6):425-431. X-5, X-6, X-7. [pmid: 21854100].
714 Tong Q, Zheng L, Tang S, et al. Laparoscopy-assisted orchiopexy for recurrent undescended testes in children. J Pediatr Surg. Apr. 2009;44(4):806-10. X-4, X-5, X-6, X-7. [pmid: 19361645].
715 Topuzlu Tekant G, Emir H, Eroglu E, et al. Experience with laparoscopy in nonpalpable testis. Eur J Pediatr Surg. Jun. 2001;11(3):177-81. X-5, X-6, X-8. [pmid: 11475114].
716 Toublanc JE. Hormonal treatment of undescended testis. Prog Clin Biol Res. 1985;203:207-11. X-4. [pmid: 2870509].
717 Traub A. Induction of ovulation. Gonadotrophin therapy. Ir J Med Sci. Dec. 1986;155(12 Suppl):30-6. X-1. [pmid: 2884196].
718 Tripathi RP, Jena AN, Gulati P, et al. Undescended testis: evaluation by magnetic resonance imaging. Indian Pediatr. Apr. 1992;29(4):433-8. X-10. [pmid: 1354655].
719 Tsujihata M, Miyake O, Yoshimura K, et al. Laparoscopic diagnosis and treatment of nonpalpable testis. Int J Urol. Dec. 2001;8(12):692-6. X-5, X-6, X-8. [pmid: 11851770].
720 Tzvetkova P, Tzvetkov D. Diagnosis of abdominal bilateral cryptorchidism: HCG stimulation test. Urol Int. 2001;67(1):46-8. X-5, X-6, X-7, X-8. [pmid: 11464115].
721 Tzvetkova P, Tzvetkov D, Kanchev L, et al. hCG stimulation test for diagnosis of androgen deficiency. Arch Androl. Sep–Oct. 1997;39(2):163-71. X-10. [pmid: 9272233].
722 Uehling D. Cryptorchidism in the Prader-Willi syndrome. J Urol. Jul. 1980;124(1):103-4. X-5, X-6, X-7, X-8. [pmid: 6106070].
723 Uehling DT, Alter AJ. Current diagnostic modalities for undescended testes. Wis Med J. Mar. 1984;83(3):20-2. X-1. [pmid: 6145255].
724 Urban MD, Lee PA, Lanes R, et al. HCG stimulation in children with cryptorchidism. Clin Pediatr (Phila). Oct. 1987;26(10):512-4. X-4. [pmid: 2888559].
725 Van Brakel J, Dohle GR, De Muinck Keizer-Schrama SMPF, et al. Surgical findings in acquired undescended testis: An explanation for pubertal descent or non-descent?. European Journal of Pediatric Surgery. 2011;21(6):351-355. X-4, X-5, X-6, X-7. [pmid: 21879460].
726 Van Rijn RR, Merks JH. Cryptorchid testicular tumour presenting as an acute abdomen in an infant. Pediatr Radiol. Jan. 2011;41(1):130. X-5, X-6, X-7. [pmid: 20431879].
727 Varela Cives R, Bautista Casasnovas A, Alonso Martin A, et al. The influence of patency of the vaginal process on the efficacy of hormonal treatment of cryptorchidism. Eur J Pediatr. Nov. 1996;155(11):932-6. X-4, X-5, X-6. [pmid: 8911891].
728 Varela-Cives R, Bautista-Casasnovas A, Gude F, et al. The predictive value of inguinal herniography for the diagnosis and treatment of cryptorchidism. J Urol. Mar. 2000;163(3):964-7. X-4, X-5, X-6. [pmid: 10688033].
729 Vegh A. Experiences with Kryptocur in the treatment of cryptorchism. Acta Chir Hung. 1987;28(4):257-61. X-4, X-5, X-6. [pmid: 2893501].
730 Vigueras RM, Reyes G, Osvaldo Cuevas J, et al. The histological effect of the human chorionic gonadotropin and luteinizing hormone-releasing hormone on experimental cryptorchidism in rats. Proc West Pharmacol Soc. 1999;42:71-3. X-1, X-5, X-6, X-7. [pmid: 10697694].
731 Vijayaraghavan SB. Sonographic localization of nonpalpable testis: Tracking the cord technique. Indian Journal of Radiology and Imaging. 01. May. 2011;21(2):134-141. X-2. [pmid: 21799597].
732 von Eyben F, Krabbe S, Skakkebaek NE. Alpha-foetoprotein and human chorionic gonadotropin in men with maldescended testes. Br J Cancer. Jul. 1980;42(1):156-7. X-5, X-6, X-7. [pmid: 6158970].
733 Vutyavanich T, Piromlertamorn W, Sirirungsi W, et al. Frequency of Y chromosome microdeletions and chromosomal abnormalities in infertile Thai men with oligozoospermia and azoospermia. Asian J Androl. Jan. 2007;9(1):68-75. X-5, X-6, X-7. [pmid: 17187159].
734 Waldschmidt J, Doede T, Vygen I. The results of 9 years of experience with a combined treatment with LH-RH and HCG for cryptorchidism. Eur J Pediatr. Suppl 2. 1993;152:S34-6. X-4, X-10. [pmid: 8101811].
735 Waldschmidt J, el-Dessouky M, Priefer A. Therapeutic results in cryptorchidism after combination therapy with LH-RH nasal spray and hCG. Eur J Pediatr. Suppl 2. 1987;146:S31-4. X-4, X-5, X-6, X-8. [pmid: 2891517].
736 Wechsler RJ, Kurtz AB, Needleman L, et al. Cross-sectional imaging of abdominal wall hernias. American Journal of Roentgenology. 1989;153(3):517-521. X-1, X-5, X-6, X-7. [pmid: 2763948].
737 Weiss RM, Carter AR, Rosenfield AT. High resolution real-time ultrasonography in the localization of the undescended testis. J Urol. May. 1986;135(5):936-8. X-2. [pmid: 2870201].
738 Weiss RM, Glickman MG. Localization and management of nonpalpable undescended testes. Surg Clin North Am. Oct. 1980;60(5):1253-63. X-2. [pmid: 6107996].
739 Weiss RM, Glickman MG. Venography of the undescended testis. Urol Clin North Am. Oct. 1982;9(3):387-95. X-2. [pmid: 6128822].
740 Whitaker P, De Kock MLS. Laparoscopy for the non-palpable testis - Look before you cut!. South African Journal of Surgery. 1992;30(1):26-28. X-5, X-6, X-7. [pmid: 1348878].
741 Whitaker RH. The undescended testis - the risk of malignant degeneration. Monogr Paediatr. 1981;12:104-8. X-1. [pmid: 6111749].
742 Whitaker RH. Neoplasia in cryptorchid men. Semin Urol. May. 1988;6(2):107-9. X-1. [pmid: 2903523].
743 Williams G, Dharmaraj P. Dissent of the testis. BMJ. Dec. 22. 2007;335(7633):1287. X-1. [pmid: 18156230].
744 Williams HA. Screening for testicular cancer. Pediatr Nurs. Sep–Oct. 1981;7(5):38-40. X-1. [pmid: 6117050].
745 Wilson-Storey D, MacKinnon AE. The laparoscope and the undescended testis. J Pediatr Surg. Jan. 1992;27(1):89-92. X-4, X-5, X-6, X-8. [pmid: 1348088].
746 Wilson-Storey D, McGenity K, Dickson JA. Orchidopexy: the younger the better?. J R Coll Surg Edinb. Dec. 1990;35(6):362-4. X-4, X-5, X-6. [pmid: 1982318].
747 Wit JM, Delemarre-van der Waal HA, Faber JA, et al. Intra- and inter-observer variability in the assessment of testicular descent. Andrologia. Sep–Oct. 1987;19(5):585-90. X-5, X-6, X-7, X-8. [pmid: 2892435].
748 Witherington R. Cryptorchism and approaches to its surgical management. Surg Clin North Am. Apr. 1984;64(2):367-84. X-1. [pmid: 6145222].
749 Witjes JA, de Vries JD, Lock MT, et al. Use of luteinizing-hormone-releasing hormone nasal spray in the treatment of cryptorchidism: is there still an indication? A clinical study in 78 boys with 103 undescended testicles. Eur Urol. 1990;17(3):226-8. X-4. [pmid: 1972065].
750 Wolf CK, Maizels M, Furness IPD. The undescended testicle. Comprehensive Therapy. 2001;27(1):11-17. X-1. [pmid: 11280851].
751 Wolloch Y, Yahel J, Schachter A, et al. Fertility and sexual development after unilateral orchipodexy for cryptorchidism. Panminerva Med. Apr–Jun. 1983;25(2):121-5. X-4, X-5, X-6. [pmid: 6139780].
752 Wolverson MK, Houttuin E, Heiberg E, et al. Comparison of computed tomography with high-resolution real-time ultrasound in the localization of the impalpable undescended testis. Radiology. Jan. 1983;146(1):133-6. X-2. [pmid: 6129677].
753 Wolverson MK, Jagannadharao B, Sundaram M, et al. CT in localization of impalpable cryptorchid testes. AJR Am J Roentgenol. Apr. 1980;134(4):725-9. X-8. [pmid: 6102432].
754 Woodard JR, Trulock TS. Complications of orchiopexy. Urol Clin North Am. Aug. 1983;10(3):537-41. X-1. [pmid: 6137894].
755 Wright JE. Impalpable testes: a review of 100 boys. J Pediatr Surg. Feb. 1986;21(2):151-3. X-4, X-5, X-6, X-8. [pmid: 2869117].
756 Yasumoto R, Nishisaka N, Maekawa T, et al. Subcapsular orchiectomy using ultrasonic surgical aspirator for testicular androgen ablation: A new alternative technique and long-term follow-up. Minimally Invasive Therapy and Allied Technologies. Sep. 1998;7(4):385-387. X-5, X-6, X-7.
757 Yonkov AS, Chatalbashev ND. A 25-year experience with standard orchidopexy in cryptorchism. Folia Med (Plovdiv). 2004;46(4):27-31. X-4, X-5, X-6. [pmid: 15962812].
758 Youngson GG, Jones PF. Management of the impalpable testis: long-term results of the preperitoneal approach. J Pediatr Surg. May. 1991;26(5):618-20. X-4, X-5, X-6. [pmid: 1676416].
759 Yucel S, Ziada A, Harrison C, et al. Decision making during laparoscopic orchiopexy for intra-abdominal testes near the internal ring. J Urol. Oct. 2007;178(4 Pt 1):1447-50. discussion 1450. X-4, X-5, X-6, X-8. [pmid: 17706708].
760 Zabar KJ, Durazi MH, Samiei MR. Cryptorchidism in adolescents and adults: orchiopexy or orchidectomy?. Journal of the Bahrain Medical Society. 1990;2(2):65-66. X-2.
761 Zaccara A, Spagnoli A, Capitanucci ML, et al. Impalpable testis and laparoscopy: when the gonad is not visualized. JSLS. Jan–Mar. 2004;8(1):39-42. X-4, X-5, X-6. [pmid: 14974661].
762 Zadik Z, Blachar Y, Abramovitch D. Growth effect of human chorionic gonadotrophin in 2–8-year-old boys with undescended testes. Helv Paediatr Acta. Aug. 1984;39(3):249-54. X-5, X-6, X-7, X-8. [pmid: 6152695].
763 Zincke H. Bilateral pelvic lymphadenectomy and radical retropubic prostatectomy for stage C or D1 adenocarcinoma of the prostate: Possible beneficial effect of adjuvant treatment. NCI Monographs. 1988;(7):109-115. X-1, X-5, X-6, X-7. [pmid: 3173496].
764 Zivkovic D, Bica DG, Hadziselimovic F. Effects of hormonal treatment on the contralateral descended testis in unilateral cryptorchidism. Journal of Pediatric Urology. Oct. 2006;2(5):468-472. X-10. [pmid: 18947658].
765 Zivkovic D, Bica DT, Hadziselimovic F. Relationship between adult dark spermatogonia and secretory capacity of Leydig cells in cryptorchidism. BJU Int. Nov. 2007;100(5):1147-9. discussion 1149. X-10. [pmid: 17662083].
766 Ziylan O, Oktar T, Korgali E, et al. Failed orchiopexy. Urol Int. 2004;73(4):313-5. X-4, X-5, X-6. [pmid: 15604574].