# Sample Abstract and Full-Text Review Forms

Abstract Review Form 1

Abstract Review Form 2

Full Text Review Form