# Exact Search Strings and Results

Table A-1 PubMed search strategies

Search terms | | Preliminary search results
#1 | cryptorchidism[mh] OR cryptorchidism[tiab] OR cryptorchid[tiab] OR ((testis[mh] OR testis[tiab] OR testes[tiab] OR testicle[tiab] OR testicles[tiab] OR testicular[tiab]) AND (undescended[tiab] OR ascended[tiab] OR retractile[tiab] OR retracted[tiab] OR nonpalpable[tiab] OR non-palpable[tiab] OR palpable[tiab] OR unilateral[tiab] OR bilateral[tiab])) | 12,879
#2 | therapeutics[mh] OR diagnosis[mh] OR surgical procedures, operative[mh] OR laparoscopy[mh] OR diagnostic imaging[mh] OR therapy[sh] OR diagnosis[sh] OR therapeutic[tiab] OR therapeutics[tiab] OR therapy[tiab] OR therapies[tiab] OR treatment[tiab] OR treatments[tiab] OR manage[tiab] OR management[tiab] OR evaluate[tiab] OR evaluation[tiab] OR diagnose[tiab] OR diagnosis[tiab] OR diagnostic[tiab] OR surgery[tiab] OR surgeries[tiab] OR surgical[tiab] OR reoperation[tiab] OR reoperate[tiab] OR orchiopexy[tiab] OR orchiopexies[tiab]OR orchidopexy[tiab] OR orchidopexies[tiab] OR orchiectomy[tiab] OR orchiectomies[tiab] OR orchidectomy[tiab] OR orchidectomies[tiab] OR laparoscopy[tiab] OR laparoscopic[tiab] OR imaging[tiab] OR image study[tiab] OR image studies[tiab] | 12,124,573
#3 | #1 AND #2 AND english[la] AND humans[mh] | 5,937
#4 | #3 AND editorial[pt] | 41
#5 | #3 AND letter[pt] | 186
#6 | #3 AND comment[pt] | 115
#7 | #3 AND case reports[pt] | 1,955
#8 | #3 AND review[pt] | 668
#9 | #3 AND news[pt] | 1
#10 | #3 AND guideline[pt] | 4
#11 | #3 AND practice guideline[pt] | 3
#12 | #3 AND meta-analysis[pt] | 13
#13 | #3 AND historical article[pt] | 10
#14 | #3 AND jsubsetk | 0
#15 | #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 | 2,668^*^
#16 | #3 NOT #15 | 3,269
#17 | #16 AND 1980:2012[dp] | 2,755

Key: [mh] medical subject heading; [sh] subheading; [tiab] keyword in title or abstract; [la] language; [pt] publication type; jsubsetk consumer health subset; [dp] publication date.

* numbers may not add up as some records are indexed in multiple publication types.

Table A-2 EMBASE search strategies

Search terms | | Search results
#1 | cryptorchism/OR (cryptorchidism OR cryptorchid).mp OR ((testis/OR (testis OR testes OR testicle OR testicles OR testicular).mp) AND ((undescended OR ascended OR retractile OR retracted OR nonpalpable OR non-palpable OR palpable OR unilateral OR bilateral).mp)) | 14,529
#2 | exp therapy/OR exp diagnosis/OR exp surgery/OR orchidopexy/OR orchiectomy/OR diagnostic imaging/OR laparoscopy/OR (therapeutic OR therapeutics OR therapy OR therapies OR treatment OR treatments OR manage OR management OR evaluate OR evaluation OR diagnose OR diagnosis OR diagnostic OR surgery OR surgeries OR surgical OR reoperation OR reoperate OR orchiopexy OR orchiopexies OR orchidopexy OR orchidopexies OR orchiectomy OR orchiectomies OR orchidectomy OR orchidectomies OR laparoscopy OR laparoscopic OR imaging OR image study OR image studies).mp | 11,565,532
#3 | 1 AND 2 | 10,630
#4 | limit 3 to human AND English language | 6,001
#5 | Limit 4 to MEDLINE records | 799
#6 | 4 AND review.pt | 665
#7 | 4 AND conference paper.pt | 233
#8 | 4 AND editorial.pt | 56
#9 | 4 AND letter.pt | 177
#10 | 4 AND note.pt | 113
#11 | 4 AND short survey.pt | 53
#12 | 4 AND case report/ | 2,065
#13 | 4 AND practice guideline/ | 54
#14 | 4 AND systematic review/ | 29
#15 | 4 AND meta analysis/ | 22
#16 | 5 OR 6 OR 7 OR 8 OR 9 OR 10 OR 11 OR 12 OR 13 OR 14 OR 15 | 3,634^*^
#17 | 4 NOT 16 | 2,367
| 16 limited 1980–2012 | 2,367

Key:/all fields; exp explode term; .mp map term as keyword; .pt publication type.

* numbers may not add up as some records are indexed in multiple publication types.

Table A-3 CINAHL search strategies

Search terms | | Search results
#1 | (MH “Cryptorchidism”) OR cryptorchidism OR cryptorchid OR (((MH “Testis”) OR testis OR testes OR testicle OR testicles OR testicular) AND (undescended OR ascended OR retractile OR retracted OR nonpalpable OR non-palpable OR palpable OR unilateral OR bilateral)) | 203
#2 | (MH “Therapeutics+”) OR (MH “Diagnosis+”) OR (MH “Surgery, Operative+”) OR (MH “Orchiectomy”) OR (MH “Laparoscopy”) OR (MH “Diagnostic Imaging+”) OR therapeutic OR therapeutics OR therapy OR therapies OR treatment OR treatments OR management OR evaluate OR evaluation OR diagnose OR diagnosis OR diagnostic OR surgery OR surgical OR reoperation OR reoperate OR orchiopexy OR orchiopexies OR orchidopexy OR orchidopexies OR orchiectomy OR orchiectomies OR orchidectomy OR orchidectomies OR laparoscopy OR laparoscopic OR imaging OR image study OR image studies | 1,488,221
#3 | #1 AND #2 | 163
#4 | #3 AND limiters: English language; Human | 51
#5 | #3 AND limiters: English language; Human; Exclude MEDLINE records | 4