# Acronyms/Abbreviations/Symbols

ARHQ: Agency for Healthcare Research and Quality
CER: Comparative Effectiveness Review
CINAHL: Cumulative Index to Nursing and Allied Health Literature
CT: Computed Tomography
DWI: Diffusion-weighted Imaging
FS: Fowler-Stephens
GnRH: Gonadotropin-releasing Hormone
hCG: Human Chorionic Gonadotropin
hMG: Human Menopausal Gonadotropin
IM: Intramuscular
IU: International Unit
kg: Kilogram
KQ: Key Question
LHRH: Luteinizing Hormone-releasing Hormone
MeSH: Medical Subject Heading
mmol: Millimolar
MRA: Magnetic Resonance Angiogram
MRAr/V: Magnetic Resonance Imaging in combination with arteriography/venography
MRI: Magnetic Resonance Imaging
MRV: Magnetic Resonance Venogram/Venography
N: Number
NPT: Non-Palpable Testicles
NPV: Negative Predictive Value
OAC: Overall Accuracy Rate
PICOTS: Population, Interventions, Comparators, Outcomes, Timing, Settings
PPV: Positive Predictive Value
QUADAS: Quality Assessment of Diagnostic Accuracy Studies Revised
RCT: Randomized Controlled Trials
Se: Sensitivity
Sp: Specificity
TEP: Technical Expert Panel
UDT: Undescended Testicle
μg: Microgram
US: Ultrasonography