# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project. Ms. Sharana Jones served as project coordinator, shepherding, planning, and implementing tasks. Ms. Sanura Latham assisted with locating studies and creating tables. Ms. Tracy Shields and Ms. Rachel Walden, library scientists on the project, lent their keen searching skills to the review.