# References

1 European Pressure Ulcer Advisory Panel, National Pressure Ulcer Advisory Panel. Prevention and treatment of pressure ulcers: quick reference guide. Washington DC. National Pressure Ulcer Advisory Panel. 2009.
2 Lyder C. Pressure ulcer prevention and management. JAMA. 2003;289(2):223-226. [pmid: 12517234].
3 National Pressure Ulcer Advisory Panel. Pressure ulcers in America: prevalence, incidence, and implications for the future. An executive summary of the National Pressure Ulcer Advisory Panel monograph. Adv Skin Wound Care. 2001;14(4):208-215. [pmid: 11902346].
4 VanGilder C, Amlung S, Harrison P, Meyer S. Results of the 2008–2009 International Pressure Ulcer Prevalence Survey and a 3-year, acute care, unit-specific analysis. Ostomy Wound Manage. 2009;55(11):39-45. [pmid: 19934462].
5 Lyder C, Ayello E. Pressure ulcers: a patient safety issue. Hughes R, editor. Patient safety and quality: an evidence-based handbook for nurses. AHRQ Publication No. 08-0043. Rockville, MD. Agency for Healthcare Research and Quality. 2008:1-33.
6 Russo CA, Steiner C, Spector W. Hospitalizations related to pressure ulcers, 2006. HCUP Statistical Brief #64. December 2008. Agency for Healthcare Research and Quality. Rockville, MD. 2008. Available at www.hcup-us.ahrq.gov/reports/statbriefs/sb64.pdf.
7 Redelings MD, Lee NE, Sorvillo F. Pressure ulcers: more lethal than we thought?. Adv Skin Wound Care. 2005;18(7):367-372. [pmid: 16160463].
8 Kuhn BA, Coulter SJ. Balancing the pressure ulcer cost and quality equation. Nurs Econ. 1992;10(5):353-359. [pmid: 1465158].
9 Fogerty MD, Abumrad NN, Nanney L, Arbogast PG, Poulose B, Barbul A. Risk factors for pressure ulcers in acute care hospitals. Wound Repair Regen. 2008;6(1):11-18. [pmid: 18211574].
10 Oot-Giromini B, Bidwell FC, Heller NB, Parks ML, Wicks P, Williams PM. Evolution of skin care: pressure ulcer prevalence rates pre/post intervention. Decubitus. 1989;2(2):54-55. [pmid: 2787659].
11 Rich SE, Shardell M, Margolis D, Baumgarten M. Pressure ulcer preventive device use among elderly patients early in the hospital stay. Nurs Res. 2009;58(2):95-104. [pmid: 19289930].
12 Bonomini J. Effective interventions for pressure ulcer prevention. Nurs Stand. 2003;17(52):45-50. [pmid: 14533226].
13 Webster J, Coleman K, Mudge A, et al. Pressure ulcers: effectiveness of risk-assessment tools. A randomised controlled trial (the ULCER trial). BMJ Qual Saf. 2011;20(4):297-306. [pmid: 21262791].
14 O’Tuathail C, Taqi R. Evaluation of three commonly used pressure ulcer risk assessment scales. Br J Nurs. 2011;20(6):S27-S34. [pmid: 21471902].
15 Ayello E, Sibbald R. Preventing pressure ulcers and skin tears. Capezuti EZD, Mezey M, Fulmer T, editors. Evidence-based geriatric nursing protocols for best practice. 3rd ed. New York, NY. Springer Publishing Co. 2008:403-429.
16 Ratliff C, Tomaselli N. WOCN update on evidence-based guidelines for pressure ulcers. J Wound Ostomy Continence Nurs. 2010;37:459-460. [pmid: 20838310].
17 Bergstrom N, Braden B, Laguzza A. The Braden Scale for predicting pressure sore risk. Nurs Res. 1987;36(4):205-210. [pmid: 3299278].
18 Pang S, Wong T. Predicting pressure sore risk with the Norton, Braden, and Waterlow scales in a Hong Kong rehabilitation hospital. Nurs Res. 1998;47:147-153. [pmid: 9610648].
19 Waterlow J. Waterlow pressure ulcer prevention/treatment policy card. 2005. Revised. Available at www.judy-waterlow.co.uk/downloads/Waterlow%20Score%20Card-front.pdf.
20 Kim E, Lee S, Lee E, Eom M. Comparison of the predictive validity among pressure ulcer risk assessment scales for surgical ICU patients. Aust J Adv Nurs. 2009;26(4):87-94.
21 Seongsook RNJ, Ihnsook RNJ, Younghee RNL. Validity of pressure ulcer risk assessment scales; Cubbin and Jackson, Braden, and Douglas scale. Int J Nurs Stud. 2004;41(2):199-204. [pmid: 14725784].
22 Braden BJ, Bergstrom N. Predictive validity of the Braden Scale for pressure sore risk in a nursing home population. Res Nurs Health. 1994;17(6):459-470. [pmid: 7972924].
23 Jalali R, Rezaie M. Predicting pressure ulcer risk: comparing the predictive validity of 4 scales. Adv Skin Wound Care. 2005;18(2):92-97. [pmid: 15788914].
24 Lindgren M, Unosson M, Krantz A, Ek A. A risk assessment scale for the prediction of pressure sore development: reliability and validity. J Adv Nurs. 2002;38(2):190-199. [pmid: 11940132].
25 Boyle M, Green M. Pressure sores in intensive care: defining their incidence and associated factors and assessing the utility of two pressure sore risk assessment tools. Aust Crit Care. 2001;14(1):24-30. [pmid: 11899757].
26 National Pressure Ulcer Advisory Panel. Support surfaces standardinitiative: terms and definitions related to support surfaces. Ver. 01/29/2007. Available at http://www.npuap.org/NPUAP_S3I_TD.pdf.
27 Clark M. Understanding Support Surfaces. Wounds Int. 2011;2:3. Available at: http://woundsinternational.com/product-reviews/understanding-support-surfaces/page-1.
28 Saha S, Smith B, Totten A, et al. Pressure ulcer treatment strategies: a Comparative Effectiveness Review. Rockville, MD. Agency for Healthcare Research and Quality. [Forthcoming].
29 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10 (11)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. 2011.
30 Altman DG, Bland JM. Diagnostic tests 3: receiver operating characteristic plots. BMJ. 1994;309(6948):188. [pmid: 8044101].
31 Zweig MH, Campbell G. Receiver-operating characteristic (ROC) plots: a fundamental evaluation tool in clinical medicine. Clin Chem. 1993;39(4):561-577. [pmid: 8472349].
32 Downs SH, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. 1998;52(6):377-384. [pmid: 9764259].
33 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3S):21-35. [pmid: 11306229].
34 Whiting PF, Rutjes AW, Westwood ME, et al. QUADAS-2: A revised tool for the Quality Assessment of Diagnostic Accuracy Studies. Ann Intern Med. 2011;155(8):529-536. [pmid: 22007046].
35 Campbell MK, Elbourne DR, Altman DG. CONSORT statement: extension to cluster randomised trials. BMJ. 2004;328(7441):702-708. [pmid: 15031246].
36 Agency for Healthcare Research and Quality. Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews. Assessing the Risk of Bias of Individual Studies when Comparing Medical Interventions. 2011. Rockville, MD. Available at http://effectivehealthcare.ahrq.gov/ehc/products/322/714/Assessing%20the%20Risk%20of%20Bias_Draft%20Report.pdf.
37 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011;64(11):1198-1207. [pmid: 21463926].
38 Bolton L. Which pressure ulcer risk assessment scales are valid for use in the clinical setting?. J Wound Ostomy Continence Nurs. 2007;34(4):368-381. [pmid: 17667083].
39 Bergstrom N, Demuth PJ, Braden BJ. A clinical trial of the Braden Scale for Predicting Pressure Sore Risk. Nurs Clin North Am. 1987;22(2):417-428. [pmid: 3554150].
40 Bergstrom N, Braden B, Kemp M, Champagne M, Ruby E. Predicting pressure ulcer risk: a multisite study of the predictive validity of the Braden Scale. Nurs Res. 1998;47(5):261-269. [pmid: 9766454].
41 Defloor T, Grypdonck MF. Pressure ulcers: validation of two risk assessment scales. J Clin Nurs. 2005;14(3):373-382. [pmid: 15707448].
42 Kwong E, Pang S, Wong T, Ho J, Shao-ling X, Li-jun T. Predicting pressure ulcer risk with the modified Braden, Braden, and Norton scales in acute care hospitals in Mainland China. Appl Nur Res. 2005;18(2):122-128. [pmid: 15991112].
43 Weststrate JT, Hop WC, Aalbers AG, Vreeling AW, Bruining HA. The clinical relevance of the Waterlow pressure sore risk scale in the ICU. Intensive Care Med. 1998;24(8):815-820. [pmid: 9757926].
44 Owens D, Lohr KN, Atkins D, et al. AHRQ Series Paper 5: Grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. 2010;63(5):513-523. [pmid: 19595577].
45 Bale S, Finlay I, Harding KG. Pressure sore prevention in a hospice. J Wound Care. 1995;4(10):465-468. [pmid: 8548573].
46 Saleh M, Anthony D, Parboteeah S. The impact of pressure ulcer risk assessment on patient outcomes among hospitalised patients. J Clin Nurs. 2009;18:1923-1929. [pmid: 19374691].
47 Hodge J, Mounter J, Gardner G, Rowley G. Clinical trial of the Norton Scale in acute care settings. Aust J Adv Nurs. 1990;8(1):39-46. [pmid: 2091682].
48 Andersen KE, Jensen O, Kvorning SA, Bach E. Prevention of pressure sores by identifying patients at risk. Br Med J (Clin Res Ed). 1982;284(6326):1370-1371. [pmid: 6803980].
49 Baldwin KM, Ziegler SM. Pressure ulcer risk following critical traumatic injury. Adv Wound Care. 1998;11(4):168-173. [pmid: 10326336].
50 Barnes D, Payton RG. Clinical application of the Braden Scale in the acute-care setting. Dermatol Nurs. 1993;5(5):386-388. [pmid: 8274348].
51 Bergstrom N, Braden B. A prospective study of pressure sore risk among institutionalized elderly. J Am Geriatr Soc. 1992;40(8):747-758. [pmid: 1634717].
52 Bergstrom N, Braden BJ. Predictive validity of the Braden Scale among Black and White subjects. Nurs Res. 2002;51(6):398-403. [pmid: 12464760].
53 Capobianco ML, McDonald DD. Factors affecting the predictive validity of the Braden Scale. Adv Wound Care. 1996;9(6):32-36. [pmid: 9069754].
54 Chan EY, Tan SL, Lee CKS, Lee JY. Prevalence, incidence and predictors of pressure ulcers in a tertiary hospital in Singapore. J Wound Care. 2005;14(8):383-388. [pmid: 16178294].
55 Chan WS, Pang SMC, Kwong EWY. Assessing predictive validity of the modified Braden scale for prediction of pressure ulcer risk of orthopaedic patients in an acute care setting. J Clin Nurs. 2009;18(11):1565-1573. [pmid: 19490294].
56 Compton F, Hoffmann F, Hortig T, et al. Pressure ulcer predictors in ICU patients: nursing skin assessment versus objective parameters. J Wound Care. 2008;17(10):417-424. [pmid: 18947019].
57 Edwards M. The levels of reliability and validity of the Waterlow pressure sore risk calculator. J Wound Care. 1995;4(8):373-378. [pmid: 7553188].
58 Feuchtinger J, Halfens R, Dassen T. Pressure ulcer risk assessment immediately after cardiac surgery—does it make a difference? A comparison of three pressure ulcer risk assessment instruments within a cardiac surgery population. Nurs Crit Care. 2007;12(1):42-49. [pmid: 17883663].
59 Goodridge DM, Sloan JA, LeDoyen YM, McKenzie J, Knight WE, Gayari M. Risk-assessment scores, prevention strategies, and the incidence of pressure ulcers among the elderly in four Canadian health-care facilities. Can J Nurs Res. 1998;30(2):23-44. [pmid: 9807287].
60 Hagisawa S, Barbenel J. The limits of pressure sore prevention. J R Soc Med. 1999;92(11):576-578. [pmid: 10703495].
61 Halfens RJ, Van Achterberg T, Bal RM. Validity and reliability of the braden scale and the influence of other risk factors: a multi-centre prospective study. Int J Nurs Stud. 2000;37(4):313-319. [pmid: 10760538].
62 Hatanaka N, Yamamoto Y, Ichihara K, et al. A new predictive indicator for development of pressure ulcers in bedridden patients based on common laboratory tests results. J Clin Pathol. 2008;61(4):514-518. [pmid: 18375746].
63 Langemo DK, Olson B, Hunter S, Hanson D, Burd C, Cathcart-Silberberg T. Incidence and prediction of pressure ulcers in five patient care settings. Decubitus. 1991;4(3):25-36. [pmid: 1872975].
64 Lewicki LJ, Mion LC, Secic M. Sensitivity and specificity of the Braden Scale in the cardiac surgical population. J Wound Ostomy Continence Nurs. 2000;27(1):36-41. [pmid: 10649141].
65 Lincoln R, Roberts R, Maddox A, Levine S, Patterson C. Use of the Norton Pressure Sore Risk Assessment Scoring System with elderly patients in acute care. J Enterostomal Ther. 1986;13(4):132-138. [pmid: 3636346].
66 Lyder CH, Yu C, Stevenson D, et al. Validating the Braden Scale for the prediction of pressure ulcer risk in blacks and Latino/Hispanic elders: a pilot study. Ostomy Wound Manage. 1998;44(3A Suppl):42S-49S. discussion 50S. [pmid: 9625997].
67 Lyder CH, Yu C, Emerling J, et al. The Braden Scale for pressure ulcer risk: evaluating the predictive validity in Black and Latino/Hispanic elders. Appl Nur Res. 1999;12(2):60-68. [pmid: 10319520].
68 Olson K, Tkachuk L, Hanson J. Preventing pressure sores in oncology patients. Clin Nurs Res. 1998;7(2):207-224. [pmid: 9633340].
69 Page KN, Barker AL, Kamar J. Development and validation of a pressure ulcer risk assessment tool for acute hospital patients. Wound Repair Regen. 2011;19(1):31-37. [pmid: 21134037].
70 Perneger TV, Rae AC, Gaspoz JM, Borst F, Vitek O, Heliot C. Screening for pressure ulcer risk in an acute care hospital: development of a brief bedside scale. J Clin Epidemiol. 2002;55(5):498-504. [pmid: 12007553].
71 Ramundo JM. Reliability and validity of the Braden Scale in the home care setting. J Wound Ostomy Continence Nurs. 1995;22(3):128-134. [pmid: 7599722].
72 Salvadalena GD, Snyder ML, Brogdon KE. Clinical trial of the Braden Scale on an acute care medical unit. J ET Nurs. 1992;19(5):160-165. [pmid: 1420528].
73 Schoonhoven L, Haalboom JRE, Bousema MT, et al. Prospective cohort study of routine use of risk assessment scales for prediction of pressure ulcers. BMJ. 2002;325(7368):797. [pmid: 12376437].
74 Serpa LF, de Gouveia Santos VLC, Gomboski G, Rosado SM. Predictive validity of Waterlow Scale for pressure ulcer development risk in hospitalized patients. J Wound Ostomy Continence Nurs. 2009;36(6):640-646. [pmid: 19920745].
75 Serpa LF, Santos VLCdG, Campanili TCGF, Queiroz M. Predictive validity of the Braden scale for pressure ulcer risk in critical care patients. Rev Lat Am Enfermagem. 2011;19(1):50-57. [pmid: 21412629].
76 Stotts NA, Paul SM. Pressure ulcer development in surgical patients. Decubitus. 1988;1(3):24-30. [pmid: 3254238].
77 Tourtual DM, Riesenberg LA, Korutz CJ, et al. Predictors of hospital acquired heel pressure ulcers. Ostomy Wound Manage. 1997;43(9):24-40. [pmid: 9369740].
78 Towey AP, Erland SM. Validity and reliability of an assessment tool for pressure ulcer risk. Decubitus. 1988;1(2):40-48. [pmid: 3254237].
79 van den Bosch MA, van der Graaf Y, Eikelboom BC, Algra A, Mali WP. Smart Study Group. Second Manifestations of ARTerial Disease. Distal aortic diameter and peripheral arterial occlusive disease. J Vasc Surg. 2001;34(6):1085-1089. [pmid: 11743565].
80 Wai-Han C, Kit-Wai C, French P, Yim-Sheung L, Lai-Kwan T. Which pressure sore risk calculator? A study of the effectiveness of the Norton scale in Hong Kong. Int J Nurs Stud. 1997;34(2):165-169. [pmid: 9134472].
81 Webster J, Gavin N, Nicholas C, Coleman K, Gardner G. Validity of the Waterlow scale and risk of pressure injury in acute care. Br J Nurs. 2010;19(6):S14-S22. [pmid: 20335924].
82 VandenBosch T, Montoye C, Satwicz M, Durkee-Leonard K, Boylan-Lewis B. Predictive validity of the Braden Scale and nurse perception in identifying pressure ulcer risk. Appl Nur Res. 1996;9(2):80-86. [pmid: 8871435].
83 Stotts NA. Predicting pressure ulcer development in surgical patients. Heart Lung. 1988;17(6 Pt 1):641-647. [pmid: 3192408].
84 van Marum RJ, Ooms ME, Ribbe MW, van Eijk JT. The Dutch pressure sore assessment score or the Norton scale for identifying at-risk nursing home patients?. Age Aging. 2000;29(1):63-68. [pmid: 10690698].
85 Andersen KE, Jensen O, Kvorning SA, Bach E. Decubitus prophylaxis: a prospective trial on the efficiency of alternating-pressure air-mattresses and water-mattresses. Acta Derm Venereol. 1982;63(3):227-230. [pmid: 6192636].
86 Brienza D, Kelsey S, Karg P, et al. A randomized clinical trial on preventing pressure ulcers with wheelchair seat cushions. J Am Geriatr Soc. 2010;58(12):2308-2314. [pmid: 21070197].
87 Cavicchioli A, Carella G. Clinical effectiveness of a low-tech versus high-tech pressure-redistributing mattress. J Wound Care. 2007;16(7):285-289. [pmid: 17708377].
88 Collier ME. Pressure-reducing mattresses. J Wound Care. 1996;5(5):207-211. [pmid: 8850903].
89 Conine TA, Daechsel D, Lau MS. The role of alternating air and Silicore overlays in preventing decubitus ulcers. Int J Rehabil Res. 1990;13(1):57-65. [pmid: 2394540].
90 Conine TA, Daechsel D, Hershler C. Pressure sore prophylaxis in elderly patients using slab foam or customized contoured foam wheelchair cushions. Occup Ther J Res. 1993;13(2):101-116.
91 Conine TA, Hershler C, Daechsel D, Peel C, Pearson A. Pressure ulcer prophylaxis in elderly patients using polyurethane foam or Jay wheelchair cushions. Int J Rehabil Res. 1994;17(2):123-137. [pmid: 7960335].
92 Cooper PJ, Gray DG, Mollison J. A randomised controlled trial of two pressure-reducing surfaces. J Wound Care. 1998;7(8):374-376. [pmid: 9832744].
93 Daechsel D, Conine TA. Special mattresses: effectiveness in preventing decubitus ulcers in chronic neurologic patients. Arch Phys Med Rehabil. 1985;66(4):246-248. [pmid: 3985778].
94 Demarre L, Beeckman D, Vanderwee K, Defloor T, Grypdonck M, Verhaeghe S. Multi-stage versus single-stage inflation and deflation cycle for alternating low pressure air mattresses to prevent pressure ulcers in hospitalised patients: a randomised-controlled clinical trial. Int J Nurs Stud. 2012;49(4):416-426. [pmid: 22056165].
95 Donnelly J, Winder J, Kernohan WG, Stevenson M. An RCT to determine the effect of a heel elevation device in pressure ulcer prevention post-hip fracture. J Wound Care. 2011;20(7). [pmid: 21841719].
96 Gebhardt KS, Bliss MR, Winwright PL, Thomas J. Pressure-relieving supports in an ICU. J Wound Care. 1996;5(3):116-121. [pmid: 8826270].
97 Geyer MJ, Brienza DM, Karg P, Trefler E, Kelsey S. A randomized control trial to evaluate pressure-reducing seat cushions for elderly wheelchair users. Adv Skin Wound Care. 2001;14(3):120-129. [pmid: 11905977].
98 Gilcreast DM, Warren JB, Yoder LH, Clark JJ, Wilson JA, Mays MZ. Research comparing three heel ulcer-prevention devices. J Wound Ostomy Continence Nurs. 2005;32(2):112-120. [pmid: 15867701].
99 Goldstone LA, Norris M, O’Reilly M, White J. A clinical trial of a bead bed system for the prevention of pressure sores in elderly orthopaedic patients. J Adv Nurs. 1982;7(6):545-548. [pmid: 6759553].
100 Gray DG. A randomized clinical trial of two types of foam mattresses. J Tissue Viability. 1994;4:128-132.
101 Gray DG, Smith M. Comparison of a new foam mattress with the standard hospital mattress. J Wound Care. 2000;9(1):29-31. [pmid: 10827665].
102 Gunningberg L, Lindholm C, Carlsson M, Sjoden PO. Effect of visco-elastic foam mattresses on the development of pressure ulcers in patients with hip fractures. J Wound Care. 2000;9(10):455-460. [pmid: 11933449].
103 Hampton S. Efficacy and cost-effectiveness of the Thermo contour mattress. Br J Nurs. 1999;8(15):990-996. [pmid: 10711028].
104 Hofman A, Geelkerken RH, Wille J, Hamming JJ, Hermans J, Breslau PJ. Pressure sores and pressure-decreasing mattresses: controlled clinical trial. Lancet. 1994;343(8897):568-571. [pmid: 7906329].
105 Inman KJ, Sibbald WJ, Rutledge FS, Clark BJ. Clinical utility and cost-effectiveness of an air suspension bed in the prevention of pressure ulcers. JAMA. 1993;269(9):1139-1143. [pmid: 8433469].
106 Jesurum J, Joseph K, Davis JM, Suki R. Balloons, beds, and breakdown. Effects of low-air loss therapy on the development of pressure ulcers in cardiovascular surgical patients with intra-aortic balloon pump support. Crit Care Nurs Clin North Am. 1996;8(4):423-440. [pmid: 9095813].
107 Jolley DJ, Wright R, McGowan S, et al. Preventing pressure ulcers with the Australian Medical Sheepskin: an open-label randomised controlled trial. Med J Aust. 2004;180(7):324-327. [pmid: 15059051].
108 Kemp MG, Kopanke D, Tordecilla L, et al. The role of support surfaces and patient attributes in preventing pressure ulcers in elderly patients. Res Nurs Health. 1993;16(2):89-96. [pmid: 8502770].
109 Keogh A, Dealey C. Profiling beds versus standard hospital beds: effects on pressure ulcer incidence outcomes. J Wound Care. 2001;10(2):15-19. [pmid: 12964222].
110 Lazzara DJ, Buschmann MT. Prevention of pressure ulcers in elderly nursing home residents: are special support surfaces the answer?. Decubitus. 1991;4(4):42-48. [pmid: 1760125].
111 Lim R, Sirett R, Conine TA, Daechsel D. Clinical trial of foam cushions in the prevention of decubitis ulcers in elderly patients. J Rehabil Res Dev. 1988;25(2):19-26. [pmid: 3361457].
112 McGowan S, Montgomery K, Jolley D, Wright R. The role of sheepskins in preventing pressure ulcers in elderly orthopaedic patients. First World Wound Healing Congress. 2000.
113 Mistiaen P, Achterberg W, Ament A, et al. The effectiveness of the Australian Medical Sheepskin for the prevention of pressure ulcers in somatic nursing home patients: a prospective multicenter randomized-controlled trial (ISRCTN17553857). Wound Repair Regen. 2010;18(6):572-579. [pmid: 20946141].
114 Nixon J, Nelson EA, Cranny G, et al. Pressure relieving support surfaces: a randomised evaluation. Health Technology Assessment. 2006;10(22):1-180.
115 Nixon J, Cranny G, Iglesias C, et al. Randomised, controlled trial of alternating pressure mattresses compared with alternating pressure overlays for the prevention of pressure ulcers: PRESSURE (pressure relieving support surfaces) trial. BMJ. 2006;332(7555). [pmid: 16740530].
116 Russell LJ, Reynolds TM, Park C, et al. Randomized clinical trial comparing 2 support surfaces: results of the Prevention of Pressure Ulcers Study. Adv Skin Wound Care. 2003;16(6):317-327. [pmid: 14652518].
117 Sanada H, Sugama J, Matsui Y, et al. Randomised controlled trial to evaluate a new double-layer air-cell overlay for elderly patients requiring head elevation. J Tissue Viability. 2003;13(3):112-121. [pmid: 12889398].
118 Sideranko S, Quinn A, Burns K, Froman RD. Effects of position and mattress overlay on sacral and heel pressures in a clinical population. Res Nurs Health. 1992;15(4):245-251. [pmid: 1496149].
119 Stapleton M. Preventing pressure sores - an evaluation of three products. Geriatr Nurs (Lond). 1986;6:23-25. [pmid: 3635484].
120 Takala J, Varmavuo S, Soppi E. Prevention of pressure sores in acute respiratory failure: A randomised controlled trial. Clin Intensive Care. 1996;7(5):228-235.
121 Taylor L. Evaluating the Pegasus Trinova: a data hierarchy approach. Br J Nurs. 1999;8(12):771-774. [pmid: 10670292].
122 Theaker C, Kuper M, Soni N. Pressure ulcer prevention in intensive care - a randomised control trial of two pressure-relieving devices. Anaesthesia. 2005;60(4):395-399. [pmid: 15766343].
123 Tymec AC, Pieper B, Vollman K. A comparison of two pressure-relieving devices on the prevention of heel pressure ulcers. Adv Wound Care. 1997;10(1):39-44. [pmid: 9204803].
124 van Leen M, Hovius S, Neyens J, Halfens R, Schols J. Pressure relief, cold foam or static air? A single center, prospective, controlled randomized clinical trial in a Dutch nursing home. J Tissue Viability. 2011;20(1):30-34. [pmid: 20510611].
125 Vanderwee K, Grypdonck MH, Defloor T. Effectiveness of an alternating pressure air mattress for the prevention of pressure ulcers. Age Aging. 2005;34(3):261-267. [pmid: 15764622].
126 Vyhlidal SK, Moxness D, Bosak KS, Van Meter FG, Bergstrom N. Mattress replacement or foam overlay? A prospective study on the incidence of pressure ulcers. Appl Nur Res. 1997;10(3):111-120. [pmid: 9274063].
127 Aronovitch SA, Wilber M, Slezak S, Martin T, Utter D. A comparative study of an alternating air mattress for the prevention of pressure ulcers in surgical patients. Ostomy Wound Manage. 1999;45(3):34-40. [pmid: 10347518].
128 Berthe JV, Bustillo A, Melot C, de Fontaine S. Does a foamy-block mattress system prevent pressure sores? A prospective randomised clinical trial in 1729 patients. Acta Chir Belg. 2007;107(2):155-161. [pmid: 17515264].
129 Feuchtinger J, de Bie R, Dassen T, Halfens R. A 4-cm thermoactive viscoelastic foam pad on the operating room table to prevent pressure ulcer during cardiac surgery. J Clin Nurs. 2006;15(2):162-167. [pmid: 16422733].
130 Hoshowsky VM, Schramm CA. Intraoperative pressure sore prevention: an analysis of bedding materials. Res Nurs Health. 1994;17(5):333-339. [pmid: 8090944].
131 Nixon J, McElvenny D, Mason S, Brown J, Bond S. A sequential randomised controlled trial comparing a dry visco-elastic polymer pad and standard operating table mattress in the prevention of post-operative pressure sores. Int J Nurs Stud. 1998;35(4):193-203. [pmid: 9801935].
132 Russell JA, Lichtenstein SL. Randomized controlled trial to determine the safety and efficacy of a multi-cell pulsating dynamic mattress system in the prevention of pressure ulcers in patients undergoing cardiovascular surgery. Ostomy Wound Manage. 2000;46(2):46-55. [pmid: 10745855].
133 Schultz AA, Bien M, Dumond K, Brown K, Myers A. Etiology and incidence of pressure ulcers in surgical patients. Aorn J. 1999;70:434-449. [pmid: 10514891].
134 Gebhardt K. A randomized trial of alternating pressure (AP) and constant low pressure (CLP) supports for the prevention of pressure sores. J Tissue Viability. 1994;4(3):93.
135 Theilla M, Singer P, Cohen J, Dekeyser F. A diet enriched in eicosapentanoic acid, gamma-linolenic acid and antioxidants in the prevention of new pressure ulcer formation in critically ill patients with acute lung injury: A randomized, prospective, controlled study. Clin Nutr. 2007;26(6):752-757. [pmid: 17933438].
136 Bourdel-Marchasson I, Barateau M, Rondeau V, et al. A multi-center trial of the effects of oral nutritional supplementation in critically ill older inpatients. Nutrition. 2000;16(1):1-5. [pmid: 10674226].
137 Delmi M, Rapin CH, Bengoa JM, Bonjour JP, Vasey H, Delmas PD. Dietary supplementation in elderly patients with fractured neck of the femur. Lancet. 1990;335(8696):1013-1016. [pmid: 1970070].
138 Ek AC, Unosson M, Larsson J, Von Schenck H, Bjurulf P. The development and healing of pressure sores related to the nutritional state. Clin Nutr. 1991;10(5):245-250. [pmid: 16839927].
139 Houwing RH, Rozendaal M, Wouters-Wesseling W, Beulens JW, Buskens E, Haalboom JR. A randomised, double-blind assessment of the effect of nutritional supplementation on the prevention of pressure ulcers in hip-fracture patients. Clin Nutr. 2003;22(4):401-405. [pmid: 12880608].
140 Hartgrink HH, Wille J, Konig P, Hermans J, Breslau PJ. Pressure sores and tube feeding in patients with a fracture of the hip: a randomized clinical trial. Clin Nutr (Edinburgh, Scotland). 1998;17(6):287-292. [pmid: 10205352].
141 Brown MM, Cornwell J, Weist JK. Reducing the risks to the institutionalized elderly: Part I. Depersonalization, negative relocation effects, and medical care deficiencies. Part II. Fire, food poisoning, decubitus ulcer and drug abuse. J Gerontol Nurs. 1981;7(7):401-407. [pmid: 6912266].
142 Defloor T, De Bacquer D, Grypdonck MHF. The effect of various combinations of turning and pressure reducing devices on the incidence of pressure ulcers. Int J Nurs Stud. 2005;42(1):37-46. [pmid: 15582638].
143 Moore Z, Cowman S, Conroy RM. A randomised controlled clinical trial of repositioning, using the 30° tilt, for the prevention of pressure ulcers. J Clin Nurs. 2011;20(17/18):2633-2644. [pmid: 21702861].
144 Smith AM, Malone JA. Preventing pressure ulcers in institutionalized elders: assessing the effects of small, unscheduled shifts in body position. Decubitus. 1990;3(4):20-24. [pmid: 2242233].
145 Young T. The 30 degree tilt position versus the 90 degree lateral and supine positions in reducing the incidence of non-blanching erythema in a hospital inpatient population: a randomised controlled trial. J Tissue Viability. 2004;14(3):88-96. [pmid: 15709355].
146 Vanderwee K, Grypdonck MH, De Bacquer D, Defloor T. Effectiveness of turning with unequal time intervals on the incidence of pressure ulcer lesions. J Adv Nurs. 2007;57(1):59-68. [pmid: 17184374].
147 Brindle CT, Wegelin JA. Prophylactic dressing application to reduce pressure ulcer formation in cardiac surgery patients. J Wound Ostomy Continence Nurs. 2012;39(2):133-142. [pmid: 22415123].
148 Fader M, Clarke-O’Neill S, Cook D, et al. Management of night-time urinary incontinence in residential settings for older people: an investigation into the effects of different pad changing regimes on skin health. J Clin Nurs. 2003;12(3):374-386. [pmid: 12709112].
149 Nakagami G, Sanada H, Konya C, Kitagawa A, Tadaka E, Matsuyama Y. Evaluation of a new pressure ulcer preventive dressing containing ceramide 2 with low frictional outer layer. J Adv Nurs. 2007;59(5):520-529. [pmid: 17681081].
150 Scott EM, Leaper DJ, Clark M, Kelly PJ. Effects of warming therapy on pressure ulcers--a randomized trial. Aorn J. 2001;73(5):921-938. [pmid: 11378948].
151 Barton AA, Barton M. Drug-based prevention of pressure-sores. Lancet. 1976;2(7983):443-444. [pmid: 73744].
152 Verbelen J. Use of polarised light as a method of pressure ulcer prevention in an adult intensive care unit. J Wound Care. 2007;16(4):145-150. [pmid: 17444378].
153 Cooper P, Gray D. Comparison of two skin care regimes for incontinence. Br J Nurs. 2001;10(6 Suppl):S6-S20. [pmid: 12070396].
154 Torra i Bou JE, Segovia Gomez T, Verdu Soriano J, Nolasco Bonmati A, Rueda Lopez J, Arboix i, Perejamo M. The effectiveness of a hyperoxygenated fatty acid compound in preventing pressure ulcers. J Wound Care. 2005;14(3):117-121. [pmid: 15779642].
155 Smith RG, Everett E, Tucker L. A double blind trial of silicone barrier cream in the prevention of pressure sores in elderly patients. J Clin Exp Gerontol. 1986;7(4):337-346.
156 van der Cammen TJ, O’Callaghan U, Whitefield M. Prevention of pressure sores. A comparison of new and old pressure sore treatments. Br J Clin Pract. 1987;41(11):1009-1011. [pmid: 3332839].
157 Declair V. The usefulness of topical application of essential fatty acids (EFA) to prevent pressure ulcers. Ostomy Wound Manage. 1997;43(5):48-52. [pmid: 9233238].
158 Duimel-Peeters IG, RJGH, Ambergen AW, Houwing RH, MPFB, Snoeckx LH. The effectiveness of massage with and without dimethyl sulfoxide in preventing pressure ulcers: a randomized, double-blind cross-over trial in patients prone to pressure ulcers. Int J Nurs Stud. 2007;44(8):1285-1295. [pmid: 17553503].
159 Houwing R, van Asbeck S, Halfens R, Arends JW. An unexpected deterimental effect on the incidence of heel pressure ulcers after local 5% DMSO cream application: a randomized, double-blind study in patients at risk for pressure ulcers. Wounds. 2008;20(4):84-88.
160 Pring J, Millman P. Evaluating pressure-relieving mattresses. J Wound Care. 1998;7(4):177-179. [pmid: 9644426].
161 Bergstrom N. Preventing pressure ulcers: a multi-site RCT in nursing facilities (Clinical Trial NCT00665535). [Forthcoming].
162 Moore ZE, Cowman S. Risk assessment tools for the prevention of pressure ulcers. Cochrane Database Syst Rev. 2008;3:CD006471. [pmid: 18646157].
163 Pancorbo-Hidalgo P, Garcia-Fernandez F, Lopez-Medina I, et al. Risk assessment scales for pressure ulcer prevention: a systematic review. J Adv Nurs. 2006;54:94-110. [pmid: 16553695].
164 Bergquist S, Frantz R. Braden scale: validity in community-based older adults receiving home health care. Appl Nur Res. 2001;14(1):36-43. [pmid: 11172228].
165 Lothian P. Wound care: identifying and protecting patients who may get pressure sores. Nurs Stand. 1989;4(4):26-29. [pmid: 2511474].
166 Fuentelsaz Gallego C. Validation of the EMINA scale: tool for the evaluation of risk of developing pressure ulcers in hospitalized patients. Enfermeria Clinica. 2001;11(3):97-103.
167 Smith I. Waterlow/Norton scoring system: a ward view Smith. Care: Science and Practice. 1989;7(4):93-95.
168 McInnes E, Jammali-Blasi A, Bell-Syer S, Dumville JC, Cullum N. Support surfaces for pressure ulcer prevention. Cochrane Database Syst Rev. 2011;4:CD001735. [pmid: 21491384].
169 Reddy M, Gill S, Rochon P. Preventing pressure ulcers: a systematic review. JAMA. 2006;296(8):974-984. [pmid: 16926357].
170 Krapfl LA, Gray M. Does regular repositioning prevent pressure ulcers?. J Wound Ostomy Continence Nurs. 2008;35(6):571-577. [pmid: 19018196].
171 Lyder CH. Examining the inclusion of ethnic minorities in pressure ulcer prediction studies. J Wound Ostomy Continence Nurs. 1996;23(5):257-260. [pmid: 9043271].
172 Gartlehner G, Hansen RA, Nissman D, Lohr KN, Carey TS. A simple and valid tool distinguished efficacy from effectiveness studies. J Clin Epidemiol. 2006;59(10):1040-1048. [pmid: 16980143].
173 Morrison A, Moulton K, Clark M, et al. English-language restriction when conducting systematic review-based meta-analyses: systematic review of published studies. Ottawa. Canadian Agency for Drugs and Technologies in Health. 2009.
174 Sterne JA, Sutton AJ, Ioannidis JP, et al. Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ. 2011;343. [pmid: 21784880].
175 Cobb GA, Yoder LH, Warren JB. Pressure ulcers: patient outcomes on a KinAir bed or EHOB waffle mattress. TriService Nursing Research Program. 1997.