# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Elizabeth Ayello, Ph.D., R.N., A.C.N.S.-B.C., C.W.O.N., E.T.N., M.A.P.W.C.A., FAAN
  Professor, Geriatric Advisor, John A. Hartford Institute for Geriatric Nursing; School of Nursing
  Excelsior College
  Albany, NY
- Mona Baumgarten, Ph.D., M.Sc.
  Associate Professor, Department of Epidemiology and Preventive Medicine
  University of Maryland School of Medicine
  Baltimore, MD
- Dan Berlowitz, M.D., M.P.H.
  Professor of Health Policy and Management
  Boston University
  Director of the Center for Health Quality, Outcomes and Economic Research
  Bedford VA Medical Center
  Bedford, MA
- Joyce Black, R.N., Ph.D.
  Associate Professor, College of Nursing
  University of Nebraska Medical Center
  Omaha, NE
- Nicky Cullum, Ph.D., R.G.N.
  Professor of Nursing
  University of Manchester
  Manchester, England
- Ruud J.G. Halfens, Ph.D.
  Professor, CAPHRI School of Public Health and Primary Care, Department of Health Care and Nursing Science, Faculty of Health, Medicine and Life Sciences
  Maastricht University
  Maastricht, The Netherlands
- Elizabeth McInnes, R.N., Ph.D.
  Associate Professor and Deputy Director, Nursing Research Institute
  Australian Catholic University
  Sydney, Australia
- Tanveer Mir, M.D., M.A.C.P.
  American College of Physicians
  Associate Chief, Geriatric and Palliative Medicine
  Long Island Jewish Medical Center
  Hyde Park, NY
- Zena Moore, Ph.D., M.Sc., P.G. Dip., FFNMRCSI
  Faculty of Nursing and Midwifery, Royal College of Surgeons in Ireland
  Dublin, Ireland
- JoAnne D. Whitney, R.N., Ph.D.
  Associate Professor, School of Nursing
  University of Washington
  Seattle, WA