# Technical Expert Panel

The EPC also consulted several technical and content experts regarding the study questions and methodology during the early stages of the report. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Dan Berlowitz, M.D., M.P.H.
  Professor of Health Policy and Management
  Boston University
  Director of the Center for Health Quality, Outcomes and Economic Research
  Bedford VA Medical Center
  Bedford, MA
- Joyce Black, R.N., Ph.D.
  Associate Professor, College of Nursing
  University of Nebraska Medical Center
  Omaha, NE
- Tom Denberg, M.D., Ph.D.
  American College of Physicians
  Vice President, Quality and Patient Safety
  Atrius Health and Harvard Vanguard Medical Associates
  Cambridge, MA
- Courtney H. Lyder, N.D., G.N.P., FAAN
  Professor, Internal Medicine and Geriatrics
  Dean, School of Nursing
  University of California – Los Angeles
  Los Angeles, CA
- Tanveer Mir, M.D., M.A.C.P.
  American College of Physicians
  Associate Chief, Geriatric and Palliative Medicine
  Long Island Jewish Medical Center
  Hyde Park, NY