# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Mona Baumgarten, Ph.D., M.Sc.
  Associate Professor, Department of Epidemiology and Preventive Medicine
  University of Maryland School of Medicine
  Baltimore, MD
- Barbara Braden, Ph.D., R.N.
  Creighton University, University College Deans Office
  Omaha, NE
- Tom Denberg, M.D., Ph.D.
  American College of Physicians
  Vice President, Quality and Patient Safety
  Atrius Health and Harvard Vanguard Medical Associates
  Cambridge, MA
- Mary Forceia, M.D., M.P.H.
  Clinical Associate Professor of Medicine
  University of Pennsylvania
  Philadelphia, PA
- Bonnie Hilburn
  Senior National Service Officer
  Paralyzed Veterans of America
  Kansas City, MO
- Courtney H. Lyder, N.D., G.N.P., FAAN
  Professor, Internal Medicine and Geriatrics
  Dean and Professor, School of Nursing
  University of California–Los Angeles
  Los Angeles, CA
- Lana McKenzie
  Associate Executive Director of Medical Services and Health Policy
  Paralyzed Veterans of America
  Washington, DC
- Susan Miller
  Centers for Medicare & Medicaid Services
  Timonium, MD
- Zena Moore, Ph.D., M.Sc., P.G. Dip., FFNMRCSI
  Faculty of Nursing and Midwifery, Royal College of Surgeons in Ireland
  Dublin, Ireland
- Jennifer Murphy, M.D.
  Assistant Professor in the Department of Surgery
  Oregon Health & Science University
  Portland, OR
- Jyme Schafer, M.D., M.P.H.
  Centers for Medicare & Medicaid Services
  Timonium, MD
- JoAnne D. Whitney, R.N., Ph.D.
  Associate Professor, University of Washington School of Nursing
  University of Washington
  Seattle, WA