# Acknowledgments

We thank our colleagues at the Oregon Evidence-based Practice Center, Leah Williams, B.S., and Elaine Graham, M.L.S., for editorial support and Teresa Goodell, Ph.D., R.N., C.N.S., C.C.R.N., A.P.R.N., B.C., for providing clinical expertise. We appreciate and acknowledge the contributions of the AHRQ Task Order Officer/Medical Officer Christine Chang, M.D., M.P.H. We also thank the Key Informants, members of the Technical Expert Panel, and Peer Reviewers.