# Discussion

## Summary

Table 17 summarizes the findings of this review. Details about the factors used to determine the overall strength of evidence for each key question are shown in Appendix F.

Table 17 Summary of evidence

Key Question and Subcategories | Strength of Evidence | Conclusion
Key Question 1. For adults in various settings, is the use of any risk-assessment tool effective in reducing the incidence or severity of pressure ulcers compared with other risk-assessment tools, clinical judgment alone, and/or usual care?
Pressure ulcer incidence or severity: Waterlow scale vs. clinical judgment | Low | One good-quality randomized trial (n = 1,231) found no difference in pressure ulcer incidence between patients assessed with either the Waterlow scale or Ramstadius tool compared with clinical judgment alone (RR, 1.4; 95% CI, 0.82 to 2.4; and RR, 0.77; 95% CI, 0.44 to 1.4, respectively).
Pressure ulcer incidence or severity: Norton scale vs. clinical judgment | Insufficient | One poor-quality nonrandomized study (n = 240) found that use of a modified version of the Norton scale to guide use of preventive interventions was associated with lower risk of pressure ulcers compared with nurses’ clinical judgment alone (RR, 0.11; 95% CI, 0.03 to 0.46).
Pressure ulcer incidence or severity: Braden scale vs. clinical judgment | Insufficient | One poor-quality cluster randomized trial (n = 521) found no difference between training in and use of the Braden score vs. nurses’ clinical judgment in risk of incident pressure ulcers but included patients with prevalent ulcers.
Key Question 1a. Do the effectiveness and comparative effectiveness of risk-assessment tools differ according to setting? | Insufficient | No study evaluated how effectiveness of risk-assessment tools varies according to care setting.
Key Question 1b. Do the effectiveness and comparative effectiveness of risk-assessment tools differ according to patient characteristics and other known risk factors for pressure ulcers, such as nutritional status or incontinence? | Insufficient | No study evaluated how effectiveness of risk-assessment tools varies in subgroups defined by patient characteristics.
Key Question 2. How do various risk-assessment tools compare with one another in their ability to predict the incidence of pressure ulcers?
Diagnostic accuracy: Braden scale | Moderate | In 2 good- and 5 fair-quality studies, the median AUROC for the Braden scale was 0.77 (range, 0.55 to 0.88). In 16 studies, based on a cutoff of ≤18, the median sensitivity was 0.74 (range, 0.33 to 1.0) and median specificity 0.68 (range, 0.34 to 0.86), for a positive likelihood ratio of 2.31 and negative likelihood ratio of 0.38.
Diagnostic accuracy: Norton scale | Moderate | In 3 studies (1 good and 2 fair quality), the median AUROC for the Norton scale was 0.74 (range, 0.56 to 0.75). In 5 studies, using a cutoff of ≤14, median sensitivity was 0.75 (range, 0.0 to 0.89) and median specificity 0.68 (range, 0.59 to 0.95), for a positive likelihood ratio of 1.83 and negative likelihood ratio of 0.42.
Diagnostic accuracy: Waterlow scale | Moderate | In 4 studies (1 good and 3 fair quality), the median AUROC for the Waterlow scale was 0.61 (range, 0.54 to 0.66). In 2 studies, based on a cutoff of ≥10, sensitivities were 0.88 and 1.0, and specificities 0.13 and 0.29, for positive likelihood ratios of 1.15 and 1.24 and negative likelihood ratios of 0.0 and 0.41.
Diagnostic accuracy: Cubbin and Jackson scale | Moderate | In 3 studies (1 good and 2 fair quality), the median AUROC for the Cubbin and Jackson scale was 0.83 (range, 0.72 to 0.90). In 3 studies, based on a cutoff of ≤24 to 29, median sensitivity was 0.89 (range, 0.83 to 0.95) and median specificity was 0.61 (0.42 to 0.82), for positive likelihood ratios that ranged from 1.43 to 5.28 and negative likelihood ratios that ranged from 0.06 to 0.40.
Diagnostic accuracy: direct comparisons between risk-assessment scales | Moderate | In 2 good- and 4 fair-quality studies that directly compared risk-assessment tools, there were no clear differences between scales based on the AUROC.
Key Question 2a. Does the predictive validity of various risk-assessment tools differ according to setting?
Diagnostic accuracy: Braden scale, across settings | Low | One fair-quality study found that a Braden scale score of ≤18 was associated with similar sensitivities and specificities in acute care and skilled nursing settings. Twenty-eight studies (10 good, 16 fair, and 2 poor quality) that evaluated the Braden scale in different settings found no clear differences in the AUROC or in sensitivities and specificities at standard (≤15 to 18) cutoffs.
Diagnostic accuracy: Cubbin and Jackson scale, ICU setting | Low | Two studies (1 good and 1 fair quality) found that the Cubbin and Jackson scale was associated with similar diagnostic accuracy compared with the Braden or Waterlow scales in intensive care patients.
Diagnostic accuracy: Braden scale, optimal cutoff in different settings | Low | One good-quality study reported a lower optimal cutoff on the Braden scale in an acute care setting (sensitivity 0.55 and specificity 0.94 at a cutoff of ≤15) than a long-term care setting (sensitivity 0.57 and specificity 0.61 at a cutoff of ≤18), but the statistical significance of differences in diagnostic accuracy was not reported. Two studies of surgical patients (1 good and 1 fair quality) found lower optimal cutoff scores than observed in studies of patients in other settings.
Key Question 2b. Does the predictive validity of various risk-assessment tools differ according to patient characteristics?
Diagnostic accuracy: Braden scale, differences according to race | Low | One fair-quality study reported similar AUROCs for the Braden scale in black and white patients in acute care and skilled nursing settings.
Diagnostic accuracy: Braden scale, differences according to baseline pressure ulcer risk | Moderate | Three studies (1 good and 2 fair quality) found no clear difference in AUROC estimates based on the presence of higher or lower mean baseline pressure ulcer risk scores.
Key Question 3. In patients at increased risk of developing pressure ulcers, what are the effectiveness and comparative effectiveness of preventive interventions in reducing the incidence or severity of pressure ulcers?
Pressure ulcer incidence or severity: advanced static mattresses or overlays vs. standard hospital mattress | Moderate | One good-quality trial (n = 1,166) and 4 fair-quality trials (n = 83 to 543) found that a more advanced static mattress or overlay was associated with lower risk of incident pressure ulcers than a standard mattress (RR range, 0.16 to 0.82), although the difference was not statistically significant in 2 trials. Six poor-quality trials reported results that were generally consistent with these findings. Three trials found no difference in length of stay. The static support surfaces evaluated in the trials varied, although a subgroup of 3 trials each found that an Australian medical sheepskin overlay was associated with lower risk of ulcers than a standard mattress (RR, 0.30, 0.58, and 0.58).
Pressure ulcer incidence or severity: advanced static mattress or overlay vs. advanced static mattress or overlay | Moderate | Three fair-quality trials (n = 52 to 100) found no differences between different advanced static support mattresses or overlays in risk of pressure ulcers. One fair-quality trial (n = 40) of nursing home patients found that a foam replaceable-parts mattress was associated with lower risk of ulcers compared with a 4-inch thick, dimpled foam overlay (25% vs. 60%; RR, 0.42; 95% CI, 0.18 to 0.96). Six poor-quality trials (n = 37 to 407) also found no differences between different advanced static mattresses or overlays.
Pressure ulcer incidence or severity: low-air-loss bed vs. standard hospital mattress | Low | One fair-quality trial (n = 98) found that a low-air-loss bed was associated with lower likelihood of 1 or more pressure ulcers in ICU patients (12% vs. 51%; RR, 0.23; 95% CI, 0.10 to 0.51), but a small (n = 36) poor-quality trial found no difference between a low-air-loss mattress compared with a standard hospital bed following cardiovascular surgery.
Pressure ulcer incidence or severity: low-air-loss mattress compared with dual option (constant low pressure/alternating air) mattress | Low | One fair-quality trial (n = 62) found no clear difference between a low-air-loss mattress compared with the Hill-Rom Duo^®^ mattress (options for constant low pressure or alternating air) in risk of ulcers.
Pressure ulcer incidence or severity: alternating air pressure overlay or mattress vs. standard hospital mattress | Low | Three poor-quality trials (n = 108 to 487) found lower incidence of pressure ulcers with use of an alternating air pressure mattress or overlay compared with a standard hospital mattress.
Pressure ulcer incidence or severity: alternating air pressure overlay or mattress vs. advanced static overlay or mattress | Moderate | Six trials (n = 32 to 487; 1 good quality, 1 fair quality, and 4 poor quality) found no difference between an alternating air pressure overlay or mattress compared with various advanced static mattresses or overlays in pressure ulcer incidence or severity.
Pressure ulcer incidence or severity: alternating air pressure overlay or mattress vs. alternating air pressure overlay or mattress | Moderate | Four trials (n = 44 to 1,972; 1 good quality, 2 fair quality, and 1 poor quality) found no clear differences between different alternating air mattresses or overlays. The good-quality (n = 1,972) trial found no difference in risk of stage 2 ulcers between an alternating air pressure overlay and an alternating air pressure mattress (RR, 1.0, 95% CI, 0.81 to 1.3; adjusted OR, 0.94, 95% CI, 0.68 to 1.3).
Pressure ulcer incidence or severity: heel supports or boots vs. usual care | Low | One fair-quality trial (n = 239) of fracture patients found that the Heelift^®^ Suspension Boot was associated with decreased risk of heel, foot, or ankle ulcers compared with usual care without leg elevation (7% vs. 26% for any ulcer, RR, 0.26, 95% CI, 0.12 to 0.53; 3.3% vs. 13.4% for stage 2 ulcers, RR, 0.25, 95% CI, 0.09 to 0.72). One poor-quality trial (n = 52) of hospitalized patients found no difference in risk of ulcers between a boot (Foot Waffle^®^) and usual care (hospital pillow to prop up legs).
Pressure ulcer incidence or severity: heel ulcer preventive intervention vs. heel ulcer preventive intervention | Insufficient | One poor-quality trial (n = 240) of hospitalized patients found no differences between three different types of boots (bunny boot, egg-crate heel lift positioner, and Foot Waffle^®^) in risk of ulcers, although the overall incidence of ulcers was low (5% over 3 years) and results could have been confounded by differential use of cointerventions.
Pressure ulcer incidence or severity: more sophisticated wheelchair cushions vs. standard wheelchair cushions | Low | Four fair-quality trials (n = 32 to 248) of older nursing home patients found inconsistent evidence on effects of more sophisticated wheelchair cushions compared with standard wheelchair cushions on risk of pressure ulcers, with the largest trial finding no difference between a contoured, individually customized foam cushion compared with a slab cushion. Results are difficult to interpret because the trials evaluated different cushions.
Pressure ulcer incidence or severity: nutritional supplementation vs. standard hospital diet | Low | Five of 6 trials (1 fair quality and 5 poor quality; n = 59 to 672) found no difference between nutritional supplementation compared with standard hospital diet in risk of pressure ulcers. Four trials evaluated supplementation by mouth and 2 evaluated enteral supplementation.
Pressure ulcer incidence or severity: repositioning intervention vs. usual care | Low | One fair-quality cluster trial (n = 213) found that repositioning at a 30-degree tilt every 3 hours was associated with lower risk of pressure ulcers compared with usual care (90-degree lateral repositioning every 6 hours during the night) after 28 days (3.0% vs. 11%; RR, 0.27; 95% CI, 0.08 to 0.93), and 1 fair-quality trial (n = 235) found no difference in risk of pressure ulcers between different repositioning intervals. Two other trials (n = 46 and 838) evaluated repositioning interventions but followed patients for only 1 night or were susceptible to confounding due to differential use of support surfaces.
Pressure ulcer incidence or severity: small unscheduled shifts in body position vs. usual care | Low | Two small (n = 15 and 19) poor-quality trials found that the addition of small unscheduled shifts in body position (using a small rolled towel to designated areas during nurse-patient interactions) to standard repositioning every 2 hours had no effect on risk on pressure ulcers, but the studies reported only 1 or 2 ulcers in each trial.
Pressure ulcer incidence or severity: silicone border foam sacral dressing vs. no silicone border foam dressing | Low | One fair-quality (n = 85) trial of patients undergoing cardiac surgery found that a silicone border foam sacral dressing applied at ICU admission (the Mepilex^®^ Border sacrum) was associated with lower likelihood of pressure ulcers compared with standard care (including preoperative placement of a silicone border foam dressing for surgery and use of a low-air-loss bed), but the difference was not statistically significant (2.0% vs. 12%; RR, 0.18; 95% CI, 0.02 to 1.5).
Pressure ulcer incidence or severity: REMOIS pad vs. no pad | Insufficient | One poor-quality randomized trial (n = 37) found that use of the REMOIS pad (consisting of a hydrocolloid skin adhesive layer, a support layer of urethane film, and an outer layer of multifilament nylon) on the greater trochanter was associated with decreased risk of stage 1 ulcers compared with no pad on the contralateral trochanter after 4 weeks (5.4% vs. 30%; RR, 0.18; 95% CI, 0.05 to 0.73).
Pressure ulcer incidence or severity: changing incontinence pad 3 vs. 2 times per day | Low | One fair-quality crossover trial (n = 81) found no statistically significant difference in risk of pressure ulcers between changing incontinence pads 3 times vs. twice after 4 weeks.
Pressure ulcer incidence or severity: intraoperative warming vs. usual care | Low | One fair-quality randomized trial (n = 324) of patients undergoing major surgery found no statistically significant difference in risk of pressure ulcers between patients who received an intraoperative warming intervention (forced-air warming and warming of all intravenous fluids) compared with usual care.
Pressure ulcer incidence or severity: corticotropin vs. sham | Insufficient | One poor-quality randomized trial (n = 85) of patients undergoing femur or hip surgery found no difference in risk of pressure ulcers between those who received 80 IU of corticotropin intramuscularly compared with a sham injection.
Pressure ulcer incidence or severity: polarized light | Insufficient | One small poor-quality randomized trial (n = 23) found no statistically significant difference between polarized light compared with standard care in risk of pressure ulcers.
Pressure ulcer incidence or severity: fatty acid cream vs. placebo | Low | One fair-quality trial (n = 331) and 1 poor-quality trial (n = 86) found that creams with fatty acids were associated with decreased risk of new pressure ulcers compared with placebo (RR, 0.42, 95% CI, 0.22 to 0.80; RR, 0.17, 95% CI, 0.04 to 0.70).
Pressure ulcer incidence or severity: other cream or lotion vs. placebo | Insufficient | Evidence from 3 poor-quality trials (n = 79 to 258) was insufficient to determine effectiveness of other creams or lotions for preventing pressure ulcers.
Pressure ulcer incidence or severity: skin cleanser vs. standard soap and water | Low | One fair-quality randomized trial (n = 93) found that the Clinisan^™^ cleanser was associated with lower risk of ulcer compared with standard soap and water in patients with incontinence at baseline (18% vs. 42%; RR, 0.43; 95% CI, 0.19 to 0.98).
Key Question 3a. Do the effectiveness and comparative effectiveness of preventive interventions differ according to risk level as determined by different risk-assessment methods and/or by particular risk factors?
Pressure ulcer incidence or severity: static foam overlay vs. standard care, lower risk surgical population | Moderate | Two trials (1 good and 1 fair quality; n = 175 and 413) found that use of a static foam overlay was associated with increased risk of pressure ulcers compared with standard care in lower risk surgical patients, although the difference was not statistically significant in 1 trial (OR, 1.9, 95% CI, 1.0 to 3.7; RR, 1.6, 95% CI, 0.76 to 3.3).
Pressure ulcer incidence or severity: static dry polymer overlay vs. standard care, lower risk surgical population | Low | Two trials (1 good and 1 poor quality) found that a dry polymer overlay was associated with decreased risk of pressure ulcers compared with standard care in lower risk surgical patients.
Pressure ulcer incidence or severity: static foam block mattress vs. standard care, lower risk surgical population | Insufficient | One poor-quality trial found no significant difference between a static foam block mattress and a standard hospital mattress in pressure ulcer incidence.
Pressure ulcer incidence or severity: alternating air vs. static mattress or overlay, lower risk surgical population | Low | Two trials (1 good and 1 poor quality; n = 198 and 217) found no differences between alternating compared with static support surfaces in risk of pressure ulcer incidence or severity.
Key Question 3b. Do the effectiveness and comparative effectiveness of preventive interventions differ according to setting? | Insufficient | No study evaluated how effectiveness of preventive interventions varies according to care setting.
Key Question 3c. Do the effectiveness and comparative effectiveness of preventive interventions differ according to patient characteristics? | Insufficient | No study evaluated how effectiveness of preventive interventions varies in subgroups defined by patient characteristics.
Key Question 4. What are the harms of interventions for the prevention of pressure ulcers?
Harms: support surfaces | Low | Nine of 48 trials of support surfaces reported harms.; - Three trials (n = 297 to 588) reported cases of heat-related discomfort with sheepskin overlays, with 1 trial reporting increased risk of withdrawal due to heat discomfort compared with a standard mattress (5% vs. 0%; RR, 0.95; 95% CI, 0.93 to 0.98).; - One trial (n = 39) that compared different dynamic mattresses reported some differences in pain and sleep disturbance, and 2 trials (n = 610 and 1,972) found no differences in risk of withdrawal due to discomfort.; - One trial (n =198) reported no differences in risk of adverse events between a multicell pulsating dynamic mattress compared with a static gel pad overlay.; - One trial (n = 239) of heel ulcer preventive interventions reported no difference in risk of adverse events between the Heelift^®^ Suspension Boot and standard care in hip fracture patients.; - One trial (n = 141) reported that a urethane and gel wheelchair pad (Jay^®^ cushion) was associated with increased risk of withdrawal due to discomfort compared with a standard foam wheelchair pad (8% vs. 1%; RR, 6.2; 95% CI, 0.77 to 51).
Harms: nutritional supplementation | Low | One trial of nutritional supplementation found that tube feeds were tolerated poorly, with 54% having the tube removed within 1 week and 67% prior to completing the planned 2-week intervention. Four trials of nutritional supplementation by mouth did not report harms.
Harms: repositioning | Low | Two (n = 46 and 838) of 6 trials of repositioning interventions reported harms. Both trials reported more nonadherence due to intolerability of a 30-degree tilt position compared with standard positioning.
Harms: lotions and creams | Low | Three (n = 93 to 203) of 6 trials of lotions or creams reported harms. One trial found no differences in rash between different creams, and 2 trials each reported 1 case of a wet sore or rash.
Harms: dressings | Low | One (n = 37) of 3 trials of dressings reported harms. It reported that application of the REMOIS pad resulted in pruritus in 1 patient.
Key Question 4a. Do the harms of preventive interventions differ according to the type of intervention? | Insufficient | No study evaluated how harms of preventive interventions vary according to the type of intervention.
Key Question 4b. Do the harms of preventive interventions differ according to setting? | Insufficient | No study evaluated how harms of preventive interventions vary according to care setting.
Key Question 4c. Do the harms of preventive interventions differ according to patient characteristics? | Insufficient | No study evaluated how harms of preventive interventions vary in subgroups defined by patient characteristics

Note: AUROC=area under the receiver operating characteristic, CI=confidence interval, ICU=intensive care unit, OR=odds ratio, RR=risk ratio.

Evidence on optimal methods to prevent pressure ulcers was extremely limited in a number of areas, including the effects of use of risk assessment instruments on the subsequent incidence of pressure ulcers and benefits of preventive interventions other than support surfaces. Evidence on harms of preventive interventions was extremely sparse, with most trials not reporting harms at all, and poor reporting of harms in those that did. Nonetheless, serious harms seem rare, consistent with what might be expected given the generally noninvasive nature of most of the preventive interventions evaluated (skin care, oral nutritional support, repositioning, and support surfaces). In addition, limited evidence was available to evaluate how the diagnostic accuracy of risk assessment instruments or benefits and harms of preventive interventions might vary depending on differences in setting, patient characteristics, or other factors. Very few studies directly assessed how estimates varied according to these factors, and indirect comparisons across trials were not possible due to small numbers of studies, differences in interventions and comparisons, and methodological shortcomings.

Only one good- and two poor-quality studies13,45,46 attempted to evaluate the effects of standardized use of a risk assessment instrument on the incidence of pressure ulcers. The good-quality trial found no difference in risk of pressure ulcers or length of stay in patients assessed with the Waterlow scale, the Ramstadius tool, or clinical judgment alone.13 The two poor-quality studies evaluated the modified Norton scale45 and the Braden scale,46 with only a nonrandomized study of the Norton scale45 finding reduced risk of pressure ulcer compared with clinical judgment.13,45,46

Studies of diagnostic accuracy found that commonly used risk assessment instruments (such as the Braden, Norton, and Waterlow scales) can help identify patients at increased risk for ulcers who might benefit from more intense or targeted interventions, but appear to be relatively weak predictors, based on likelihood ratios at commonly used cutoffs. However, diagnostic accuracy may have been underestimated in these studies if patients at higher risk were more likely to receive effective interventions to prevent ulcers. Studies of diagnostic accuracy rarely reported risk estimates, and no study that reported risk estimates attempted to control for potential confounding effects of differential use of interventions. There was no clear difference between commonly used risk assessment instruments in diagnostic accuracy, though direct comparisons were limited.20,21,25,41,70,73

About three-quarters of the trials of preventive interventions focused on evaluations of support surfaces. In higher-risk populations, good- and fair-quality randomized trials consistently found more advanced static mattresses and overlays associated with lower risk of pressure ulcers compared with standard mattresses in higher-risk patients (relative risk [RR] range 0.20 to 0.60),100,107,113,116,124 with no clear differences between different advanced static support surfaces.88,92,101,103,108,110,111,118,119,126 Although the mattresses and overlays evaluated in the trials varied, three trials consistently found an Australian medical sheepskin overlay associated with lower risk of ulcers than a standard hospital mattress, though the sheepskin was also associated with heat-related discomfort, in some cases resulting in withdrawal.107,112,113 Evidence on the effectiveness and comparative effectiveness of other specific support surfaces, including alternating air mattresses and low-air-low mattresses, was limited, with most trials85,87,89,93,106,118,125 showing no clear differences between these types of mattresses and various static mattresses and overlays. One fair-quality trial found stepped care starting with alternating air mattresses associated with substantially decreased risk of ulcers compared with stepped care primarily with static mattresses,96 suggesting that this might be both an effective as well as efficient approach, since care was initiated with the least expensive alternatives and advanced to more expensive alternatives based on a preset algorithm. In lower-risk populations of patients undergoing surgery, two trials found use of a foam overlay associated with an increased risk of pressure ulcers compared with a standard operating room mattress.129,133 The few trials that evaluated length of stay found no differences between various support surfaces.104–107,118,121,122

Evidence on other preventive interventions (nutritional supplementation; repositioning; pads and dressings; lotions, creams, and cleansers; and intraoperative warming therapy for patients undergoing surgery) was sparse and insufficient to reach reliable conclusions, in part because most trials had important methodological shortcomings. An exception was repositioning, for which there were three good- or fair-quality trials, though these reported somewhat inconsistent results.142,143,146 One trial found a repositioning intervention was more effective than usual care in preventing pressure ulcers.143 Although other trials of repositioning did not clearly find decreased risk of pressure ulcers compared with usual care, the usual care control group incorporated standard repositioning practices (i.e., the trials compared more intense repositioning with usual repositioning, not vs. no repositioning). A recently completed trial of repositioning, consisting of high-risk and moderate-risk arms that are randomized to repositioning at 2-, 3-, or 4-hour intervals, should provide more rigorous evidence on the effectiveness of repositioning.161

## Findings in Relationship to What Is Already Known

Our findings of limited evidence on effects of risk assessment tools in reducing the incidence or severity of pressure ulcers are consistent with other recent systematic reviews.162,163 One of these reviews also evaluated the diagnostic accuracy of risk assessment tools.163 It reported higher sensitivity and lower specificity for the Waterlow (0.82 and 0.27) compared with the Norton (0.47 and 0.62) and Braden (0.57 and 0.68) scales, but pooled data without regard for differences in cutoff scores and across study settings, and included four studies that we excluded due to retrospective design,164 inadequate details to determine eligibility for inclusion,165 availability only in Spanish,166 or that we were unable to obtain.167

Our findings on effectiveness of preventive interventions are generally consistent with other systematic reviews that found some evidence that more advanced static support surfaces are associated with decreased risk of pressure ulcers compared with standard hospital mattresses,168,169 limited evidence on the effectiveness and comparative effectiveness of dynamic support surfaces,168,169 and limited evidence on other preventive interventions.169,170 All reviews noted methodological shortcomings in the trials and variability in interventions and comparisons across studies. These reviews differed from ours by including trials that enrolled patients with higher stage pre-existing ulcers and including trials published only as abstracts.

## Applicability

The studies included in this review generally enrolled patients at higher risk for pressure ulcers, though eligibility criteria varied between studies. The studies are most applicable to acute care and long-term care settings, with few studies evaluating patients in community or home settings, including specific populations such as wheelchair bound people in the community, patients at end of life, and spinal cord injury patients. Some trials specifically evaluated lower risk patients undergoing surgery and were reviewed separately (see Key Question 3a). Although black patients and Hispanics represent the fastest growing populations of frail elderly in the United States, these populations were severely underrepresented in the studies.171

Some interventions evaluated in older trials may no longer be available, and the control interventions (e.g., standard hospital mattresses) have also changed over time. However, conclusions were unchanged when analyses were restricted to trials conducted more recently. In addition, many trials of support surfaces evaluated specific brand name products and it might be difficult to generalize results to other products in the same class. This problem is compounded by the constantly changing nature of products sold and marketed by support surface manufacturers.

Another important issue in interpreting the applicability of this review is that patients in studies of diagnostic accuracy as well as in studies of interventions generally received standard of care treatments. For example, no study of diagnostic accuracy blinded caregivers to the results of risk assessment scores (blinding might be difficult for ethical reasons), which would be expected to lead to the use of more intensive preventive interventions and care in higher-risk people. If such interventions are truly effective, they would be expected to result in decreased incidence of pressure ulcers, thus affecting estimates of diagnostic accuracy. For trials of preventive interventions, usual care varied and was not always well described, but generally includes repositioning every 2 to 4 hours, skin care, standard nutrition, and standard support surfaces. Therefore, most trials of preventive interventions represent comparisons of more intensive interventions plus multi-component standard care compared with standard care alone, rather than compared with no care. One factor that may affect applicability is that the more intensive preventive interventions evaluated in many of the studies included in this review may require additional training or resources. In addition, the applicability of trial findings to clinical practice could be limited by delays in use of preventive interventions or differences in the quality of care between research and typical clinical settings.

Evidence to evaluate potential differences in comparative benefits or harms in patient subgroups based on baseline pressure ulcer risk, specific risk factors for ulcers, setting of care, and other factors was very limited, which precluded any reliable conclusions.

Although the studies included in this review generally enrolled patients in whom pressure ulcer risk assessment and preventive interventions would typically be considered and evaluated clinically relevant usual care comparison arms, they frequently did not meet a number of other criteria for effectiveness studies, such as assessment of adverse events, adequate sample sizes to detect clinically important differences, and use of intention-to-treat analysis.172

The results of this CER are not applicable to populations excluded from the review, including patients with higher stage pressure ulcers at baseline, or patients with lower stage pressure ulcers in which the risk of incident ulcers was not reported. A separate CER focuses on treatment of patients with pressure ulcers at baseline.28

## Implications for Clinical and Policy Decisionmaking

Our review has potential implications for clinical and policy decisionmaking. Despite insufficient evidence to determine whether use of risk assessment instruments reduces risk of incident pressure ulcers, studies suggest that: a) commonly used instruments can predict which patients are more likely to develop an ulcer, and b) there are no clear differences in diagnostic accuracy. Decisions about whether to use risk assessment instruments and which risk assessment instrument to use may depend on considerations such as a desire to standardize and monitor practices within a clinical setting, ease of use, nursing preferences, and other factors. In some populations, such as spinal cord injured patients, risk assessment instruments have not been well studied, but may not be highly relevant since all patients may be considered to be at risk.

Evidence suggests that more advanced static support surfaces are more effective than standard mattresses for reducing risk of pressure ulcers, though more evidence is needed to understand the effectiveness and comparative effectiveness of dynamic and other support surfaces. Despite limited evidence showing that they are more effective at preventing pressure ulcers compared with static mattresses and overlays, alternating air and low-air-loss mattresses and overlays are used in hospitals in many areas of the United States. Such support surfaces can be quite costly, though one trial found that a stepped care approach that utilized lower-cost dynamic support surfaces before switching to higher-cost interventions in patients with early ulcers could be effective as well as efficient; this finding warrants further study.96 Although evidence is insufficient to guide recommendations on use of other preventive interventions, these findings are contingent on an understanding that usual care practices were the comparator treatment in most studies. Therefore, it would be inappropriate to conclude that standard repositioning, skin care, nutrition, and other practices should be abandoned, as these were the basis of usual care comparisons.

Although studies of preventive interventions primarily focused on effects on pressure ulcer incidence and severity, other factors such as effects on resource utilization (including length of hospitalization and costs) and patient preferences may affect clinical decisions. However, cost and patient preferences were outside the scope of this report and data on resource utilization was limited to a small numbers of studies that found no effects of various support surfaces on length of stay.

## Limitations of the Comparative Effectiveness Review Process

Our review had some potential limitations. We excluded non-English language articles which could result in language bias (Appendix E), though a recent systematic review found little empirical evidence that exclusion of non-English language articles leads to biased estimates for noncomplementary or alternative medicine interventions.173 In addition, we did not exclude poor-quality studies a priori. Rather, we described the limitations of the studies, emphasized higher-quality studies when synthesizing the evidence, and performed sensitivity analyses that excluded poor-quality studies.

We did not attempt to pool studies of diagnostic accuracy due to clinical heterogeneity across studies and methodological shortcomings. Rather, we synthesized results qualitatively, and described the range of results, in order to highlight the greater uncertainty in findings.

We did not formally assess for publication bias with funnel plots due to small numbers (<10) of studies for all comparisons and due to important clinical heterogeneity and methodological shortcomings in the available studies. Small numbers of studies can make interpretation of funnel plots unreliable, and experts suggest 10 studies as the minimum number of studies to perform funnel plots.174 Inclusion of two studies of preventive interventions published only as conference abstracts would not have changed our results.134,175

## Limitations of the Evidence Base

We identified a number of limitations in the evidence base on preventive interventions. Most included studies had important methodological shortcomings, with 4 of 47 studies of diagnostic accuracy and 35 of 72 studies of preventive interventions rated poor-quality, and only 12 studies of diagnostic accuracy and six studies of preventive interventions rated good-quality. Few studies of diagnostic accuracy reported measures of discrimination such as the AUROC, many studies failed to predefine cutoff thresholds, few studies reported differential use of interventions according to baseline risk score (which could affect estimates of diagnostic accuracy), and some studies evaluated modified or ad hoc versions of standard risk assessment instruments. An important limitation of the evidence on preventive interventions is that few trials compared the same intervention, and methods for assessing and reporting ulcers varied. There was almost no evidence to determine how diagnostic accuracy of risk assessment instruments or the effectiveness and comparative effectiveness of preventive interventions varies according to care setting, patient characteristics, or other factors. Harms were reported in only 16 of 72 trials of preventive interventions, and harms were poorly reported even when some data were provided. Only about half of the studies reported funding source. Among those that did report funding source, most were sponsored by institutions or governmental organizations.

## Future Research

Future research is needed on the effectiveness of standardized use of risk assessment tools compared with clinical judgment or nonstandardized use in preventing pressure ulcers. Studies should evaluate validated risk assessment instruments and employ a clearly described protocol for use of preventive interventions based on the risk assessment score. In addition to comparing the risk and severity of ulcers across groups, studies should also report effects on use of preventive interventions as well as other important outcomes, such as length of hospital stay and measures of resource utilization.

Future research that simultaneously evaluates the diagnostic accuracy of different risk assessment instruments is needed to provide more direct evidence on how their performance compares with one another. Studies should at a minimum report how use of preventive interventions differed across intervention groups, and consider reporting adjusted risk estimates to account for such potential confounders. Studies of diagnostic accuracy should also use predefined, standardized cutoffs and routinely report measures of discrimination such as the AUROC. Research is also needed to understand how the different components of risk assessment instruments contribute to predictive utility, and on whether the addition of aspects not addressed well in standard risk assessments (such as decreased perfusion) improves diagnostic accuracy, in order to refine prediction instruments. Studies are also needed to understand how risk prediction instruments perform in specific patient populations and settings and whether the diagnostic accuracy of risk prediction instruments varies for different types of ulcers (e.g., heel ulcers vs. sacral or other ulcers).

More research is needed to understand the effectiveness of preventive interventions. It is critical that future studies of preventive interventions adhere to methodological standards including appropriate use of blinding (such as blinding of outcome assessors even when blinding of patients and caregivers is not feasible) and clearly describe usual care and other comparison treatments. Studies should routinely report baseline pressure ulcer risk in enrolled patients and consider predefined subgroup analyses to help better understand how preventive interventions might be optimally targeted. More studies are needed to better understand the comparative effectiveness of dynamic and reactive support surfaces compared with static support surfaces, as well as strategies such as stepped care that might be more efficient than using costly interventions in all patients.