# Evidence Tables and Quality Assessment Tables

Appendix Table H1 Key Question 1: data extraction of pressure ulcer screening and clinical outcome studies

Appendix Table H2 Key Question 1: quality assessment of [underlined: pressure ulcer screening and clinical outcome trials]

Appendix Table H3 Key Question 1: quality assessment of pressure ulcer screening and clinical outcome cohort studies

Appendix Table H4 Key Question 2: data extraction of pressure ulcer risk assessment studies

Appendix Table H5 Key Question 2: quality assessment of pressure ulcer risk assessment scales

Appendix Table H6 Key Question 2: sensitivity and specificity of pressure ulcer risk assessment scales

Appendix Table H7 Key Question 2: sensitivity and specificity of pressure ulcer risk assessment scales—setting

Appendix Table H8 Key Question 2: pressure ulcer risk assessment scales area under the receiver operating characteristic curve—setting

Appendix Table H9 Key Question 2: optimal pressure ulcer risk assessment scale cutoffs

Appendix Table H10 Key Question 2: area under the receiver operating characteristic curve by baseline risk score

Appendix Table H11 Key Questions 3 and 4: data extraction of support surfaces trials

Appendix Table H12 Key Questions 3 and 4: quality assessment of support surfaces trials

Appendix Table H13 Key Questions 3 and 4: data extraction of nutrition trials

Appendix Table H14 Key Questions 3 and 4: quality assessment of nutrition trials

Appendix Table H15 Key Questions 3 and 4: data extraction of repositioning trials

Appendix Table H16 Key Questions 3 and 4: quality assessment of repositioning trials

Appendix Table H17 Key Questions 3 and 4: data extraction of dressing trials

Appendix Table H18 Key Questions 3 and 4: quality assessment of dressing trials

Appendix Table H19 Key Questions 3 and 4: data extraction of other intervention trials

Appendix Table H20 Key Questions 3 and 4: quality assessment of other intervention trials

Appendix Table H21 Key Questions 3 and 4: data extraction of lotion trials

Appendix Table H22 Key Questions 3 and 4: quality assessment of lotion trials

## Appendix H References

1 Bale S, Finlay I, Harding KG. Pressure sore prevention in a hospice. J Wound Care. 1995;4(10):465-8. [pmid: 8548573].
2 Saleh M, Anthony D, Parboteeah S. The impact of pressure ulcer risk assessment on patient outcomes among hospitalised patients. J Clin Nurs. 2009;(18):1923-9. [pmid: 19374691].
3 Webster J, Coleman K, Mudge A, et al. Pressure ulcers: effectiveness of risk-assessment tools. A randomised controlled trial (the ULCER trial). BMJ Qual Saf. 2011;20(4):297-306. [pmid: 21262791].
4 Boyle M, Green M. Pressure sores in intensive care: defining their incidence and associated factors and assessing the utility of two pressure sore risk assessment tools. Aust Crit Care. 2001;14(1):24-30. [pmid: 11899757].
5 Defloor T, Grypdonck MF. Pressure ulcers: validation of two risk assessment scales. J Clin Nurs. 2005;14(3):373-82. [pmid: 15707448].
6 Feuchtinger J, Halfens R, Dassen T. Pressure ulcer risk assessment immediately after cardiac surgery--does it make a difference? A comparison of three pressure ulcer risk assessment instruments within a cardiac surgery population. Nurs Crit Care. 2007;12(1):42-9. [pmid: 17883663].
7 Jalali R, Rezaie M. Predicting pressure ulcer risk: comparing the predictive validity of 4 scales. Adv Skin Wound Care. 2005;18(2):92-7. [pmid: 15788914].
8 Kim E, Lee S, Lee E, et al. Comparison of the predictive validity among pressure ulcer risk assessment scales for surgical ICU patients. Aust J Adv Nurs. 2009;26(4):87-94.
9 Kwong E, Pang S, Wong T, et al. Predicting pressure ulcer risk with the modified Braden, Braden, and Norton, scales in acute care hospitals in Mainland China. Appl Nur Res. 2005;18(2):122-8. [pmid: 15991112].
10 Pang S, Wong T. Predicting pressure sore risk with the Norton, Braden, and Waterlow scales in a Hong Kong rehabilitation hospital. Nurs Res. 1998;47:147-53. [pmid: 9610648].
11 Perneger TV, Rae AC, Gaspoz JM, et al. Screening for pressure ulcer risk in an acute care hospital: development of a brief bedside scale. J Clin Epidemiol. 2002;55(5):498-504. [pmid: 12007553].
12 Salvadalena GD, Snyder ML, Brogdon KE. Clinical trial of the Braden Scale on an acute care medical unit. J ET Nurs. 1992;19(5):160-5. [pmid: 1420528].
13 Schoonhoven L, Haalboom JRE, Bousema MT, et al. Prospective cohort study of routine use of risk assessment scales for prediction of pressure ulcers. BMJ. 2002;325(7368):797. [pmid: 12376437].
14 Seongsook RNJ, Ihnsook RNJ, Younghee RNL. Validity of pressure ulcer risk assessment scales; Cubbin and Jackson, Braden, and Douglas scale. Int J Nurs Stud. 2004;41(2):199-204. [pmid: 14725784].
15 van Marum RJ, Ooms ME, Ribbe MW, et al. The Dutch pressure sore assessment score or the Norton, scale for identifying at-risk nursing home patients?. Age Aging. 2000;29(1):63-8. [pmid: 10690698].
16 VandenBosch T, Montoye C, Satwicz M, et al. Predictive validity of the Braden Scale and nurse perception in identifying pressure ulcer risk. Appl Nur Res. 1996;9(2):80-6. [pmid: 8871435].
17 Wai-Han C, Kit-Wai C, French P, et al. Which pressure sore risk calculator? A study of the effectiveness of the Norton scale in Hong Kong. Int J Nurs Stud. 1997;34(2):165-9. [pmid: 9134472].
18 Baldwin KM, Ziegler SM. Pressure ulcer risk following critical traumatic injury. Adv Wound Care. 1998;11(4):168-73. [pmid: 10326336].
19 Barnes D, Payton RG. Clinical application of the Braden Scale in the acute-care setting. Dermatol Nurs. 1993;5(5):386-8. [pmid: 8274348].
20 Bergstrom N, Braden B, Laguzza A. The Braden Scale for predicting pressure sore risk. Nurs Res. 1987;36(4):205-10. [pmid: 3299278].
21 Bergstrom N, Demuth PJ, Braden BJ. A clinical trial of the Braden Scale for Predicting Pressure Sore Risk. Nurs Clin North Am. 1987;22(2):417-28. [pmid: 3554150].
22 Bergstrom N, Braden B. A prospective study of pressure sore risk among institutionalized elderly. J Am Geriatr Soc. 1992;40(8):747-58. [pmid: 1634717].
23 Bergstrom N, Braden B, Kemp M, et al. Predicting pressure ulcer risk: a multisite study of the predictive validity of the Braden Scale. Nurs Res. 1998;47(5):261-9. [pmid: 9766454].
24 Bergstrom N, Braden BJ. Predictive validity of the Braden Scale among Black and White subjects. Nurs Res. 2002;51(6):398-403. [pmid: 12464760].
25 Braden BJ, Bergstrom N. Predictive validity of the Braden Scale for pressure sore risk in a nursing home population. Res Nurs Health. 1994;17(6):459-70. [pmid: 7972924].
26 Capobianco ML, McDonald DD. Factors affecting the predictive validity of the Braden Scale. Adv Wound Care. 1996;9(6):32-6. [pmid: 9069754].
27 Chan EY, Tan SL, Lee CKS, et al. Prevalence, incidence and predictors of pressure ulcers in a tertiary hospital in Singapore. J Wound Care. 2005;14(8):383-4. 6. 8. [pmid: 16178294].
28 Chan WS, Pang SMC, Kwong EWY. Assessing predictive validity of the modified Braden scale for prediction of pressure ulcer risk of orthopaedic patients in an acute care setting. J Clin Nurs. 2009;18(11):1565-73. [pmid: 19490294].
29 Goodridge DM, Sloan JA, LeDoyen YM, et al. Risk-assessment scores, prevention strategies, and the incidence of pressure ulcers among the elderly in four Canadian health-care facilities. Can J Nurs Res. 1998;30(2):23-44. [pmid: 9807287].
30 Hagisawa S, Barbenel J. The limits of pressure sore prevention. J R Soc Med. 1999;92(11):576-8. [pmid: 10703495].
31 Halfens RJ, Van Achterberg T, Bal RM. Validity and reliability of the braden scale and the influence of other risk factors: a multi-centre prospective study. Int J Nurs Stud. 2000;37(4):313-9. [pmid: 10760538].
32 Langemo DK, Olson B, Hunter S, et al. Incidence and prediction of pressure ulcers in five patient care settings. Decubitus. 1991;4(3):25-36. [pmid: 1872975].
33 Lewicki LJ, Mion LC, Secic M. Sensitivity and specificity of the Braden Scale in the cardiac surgical population. J Wound Ostomy Continence Nurs. 2000;27(1):36-41. [pmid: 10649141].
34 Lyder CH, Yu C, Stevenson D, et al. Validating the Braden Scale for the prediction of pressure ulcer risk in blacks and Latino/Hispanic elders: a pilot study. Ostomy Wound Manage. 4. 1998;44(3A Suppl):2S-49S. [pmid: 9625997].
35 Lyder CH, Yu C, Emerling J, et al. The Braden Scale for pressure ulcer risk: evaluating the predictive validity in Black and Latino/Hispanic elders. Appl Nur Res. 1999;12(2):60-8. [pmid: 10319520].
36 Olson K, Tkachuk L, Hanson J. Preventing pressure sores in oncology patients. Clin Nurs Res. 1998;7(2):207-24. [pmid: 9633340].
37 Ramundo JM. Reliability and validity of the Braden Scale in the home care setting. J Wound Ostomy Continence Nurs. 1995;22(3):128-34. [pmid: 7599722].
38 Serpa LF, Santos VLCdG, Campanili TCGF, et al. Predictive validity of the Braden scale for pressure ulcer risk in critical care patients. Rev Lat Am Enfermagem. 2011;19(1):50-7. [pmid: 21412629].
39 Tourtual DM, Riesenberg LA, Korutz CJ, et al. Predictors of hospital acquired heel pressure ulcers. Ostomy Wound Manage. 1997;43(9):24-40. [pmid: 9369740].
40 Lincoln R, Roberts R, Maddox A, et al. Use of the Norton Pressure Sore Risk Assessment Scoring System with elderly patients in acute care. J Enterostomal Ther. 1986;13(4):132-8. [pmid: 3636346].
41 Stotts NA, Paul SM. Pressure ulcer development in surgical patients. Decubitus. 1988;1(3):24-30. [pmid: 3254238].
42 Compton F, Hoffmann F, Hortig T, et al. Pressure ulcer predictors in ICU patients: nursing skin assessment versus objective parameters. J Wound Care. 2008;17(10):417-20. 22. 4. [pmid: 18947019].
43 Edwards M. The levels of reliability and validity of the Waterlow pressure sore risk calculator. J Wound Care. 1995;4(8):373-8. [pmid: 7553188].
44 Serpa LF, de Gouveia Santos VLC, Gomboski G, et al. Predictive validity of Waterlow Scale for pressure ulcer development risk in hospitalized patients. J Wound Ostomy Continence Nurs. 2009;36(6):640-6. [pmid: 19920745].
45 Webster J, Gavin N, Nicholas C, et al. Validity of the Waterlow scale and risk of pressure injury in acute care. Br J Nurs. 2010;19(6):S14-S22. [pmid: 20335924].
46 Weststrate JT, Hop WC, Aalbers AG, et al. The clinical relevance of the Waterlow pressure sore risk scale in the ICU. Intensive Care Med. 1998;24(8):815-20. [pmid: 9757926].
47 Andersen KE, Jensen O, Kvorning SA, et al. Prevention of pressure sores by identifying patients at risk. Br Med J (Clin Res Ed). 1982;284(6326):1370-1. [pmid: 6803980].
48 Hatanaka N, Yamamoto Y, Ichihara K, et al. A new predictive indicator for development of pressure ulcers in bedridden patients based on common laboratory tests results. J Clin Pathol. 2008;61(4):514-8. [pmid: 18375746].
49 Lindgren M, Unosson M, Krantz A, et al. A risk assessment scale for the prediction of pressure sore development: reliability and validity. J Adv Nurs. 2002;38(2):190-9. [pmid: 11940132].
50 Page KN, Barker AL, Kamar J. Development and validation of a pressure ulcer risk assessment tool for acute hospital patients. Wound Repair Regen. 2011;19(1):31-7. [pmid: 21134037].
51 Towey AP, Erland SM. Validity and reliability of an assessment tool for pressure ulcer risk. Decubitus. 1988;1(2):40-8. [pmid: 3254237].
52 van den Bosch MA, van der Graaf Y, Eikelboom BC, et al. Distal aortic diameter and peripheral arterial occlusive disease. J Vasc Surg. 2001;34(6):1085-9. [pmid: 11743565].
53 Stotts NA. Predicting pressure ulcer development in surgical patients. Heart Lung. 1988;17(6 Pt 1):641-7. [pmid: 3192408].
54 Andersen KE, Jensen O, Kvorning SA, et al. Decubitus prophylaxis: a prospective trial on the efficiency of alternating-pressure air-mattresses and water-mattresses. Acta Derm Venereol. 1982;63(3):227-30. [pmid: 6192636].
55 Aronovitch SA, Wilber M, Slezak S, et al. A comparative study of an alternating air mattress for the prevention of pressure ulcers in surgical patients. Ostomy Wound Manage. 1999;45(3):34-40. [pmid: 10347518].
56 Berthe JV, Bustillo A, Melot C, et al. Does a foamy-block mattress system prevent pressure sores ? A prospective randomised clinical trial in 1729 patients. Acta Chir Belg. 2007;107(2):155-61. [pmid: 17515264].
57 Brienza D, Kelsey S, Karg P, et al. A randomized clinical trial on preventing pressure ulcers with wheelchair seat cushions. J Am Geriatr Soc. 2010;58(12):2308-14. [pmid: 21070197].
58 Cavicchioli A, Carella G. Clinical effectiveness of a low-tech versus high-tech pressure-redistributing mattress. J Wound Care. 2007;16(7):285-9. [pmid: 17708377].
59 Collier ME. Pressure-reducing mattresses. J Wound Care. 1996;5(5):207-11. [pmid: 8850903].
60 Conine TA, Daechsel D, Lau MS. The role of alternating air and Silicore overlays in preventing decubitus ulcers. Int J Rehabil Res. 1990;13(1):57-65. [pmid: 2394540].
61 Conine TA, Daechsel D, Hershler C. Pressure sore prophylaxis in elderly patients using slab foam or customized contoured foam wheelchair cushions. Occup Ther J Res. 1993;13(2):101-16.
62 Conine TA, Hershler C, Daechsel D, et al. Pressure ulcer prophylaxis in elderly patients using polyurethane foam or Jay wheelchair cushions. Int J Rehabil Res. 1994;17(2):123-37. [pmid: 7960335].
63 Cooper PJ, Gray DG, Mollison J. A randomised controlled trial of two pressure-reducing surfaces. J Wound Care. 1998;7(8):374-6. [pmid: 9832744].
64 Daechsel D, Conine TA. Special mattresses: effectiveness in preventing decubitus ulcers in chronic neurologic patients. Arch Phys Med Rehabil. 1985;66(4):246-8. [pmid: 3985778].
65 Demarre L, Beeckman D, Vanderwee K, et al. Multi-stage versus single-stage inflation and deflation cycle for alternating low pressure air mattresses to prevent pressure ulcers in hospitalised patients: a randomised-controlled clinical trial. Int J Nurs Stud. 2012;49(4):416-26. [pmid: 22056165].
66 Donnelly J, Winder J, Kernohan WG, et al. An RCT to determine the effect of a heel elevation device in pressure ulcer prevention post-hip fracture. J Wound Care. 2011;20(7). [pmid: 21841719].
67 Feuchtinger J, de Bie R, Dassen T, et al. A 4-cm thermoactive viscoelastic foam pad on the operating room table to prevent pressure ulcer during cardiac surgery. J Clin Nurs. 2006;15(2):162-167. [pmid: 16422733].
68 Gebhardt KS, Bliss MR, Winwright PL, et al. Pressure-relieving supports in an ICU. J Wound Care. 1996;5(3):116-21. [pmid: 8826270].
69 Geyer MJ, Brienza DM, Karg P, et al. A randomized control trial to evaluate pressure-reducing seat cushions for elderly wheelchair users. Adv Skin Wound Care. 2001;14(3):120-129. [pmid: 11905977].
70 Gilcreast DM, Warren JB, Yoder LH, et al. Research comparing three heel ulcer-prevention devices. J Wound Ostomy Continence Nurs. 2005;32(2):112-20. [pmid: 15867701].
71 Goldstone LA, Norris M, O’Reilly M, et al. A clinical trial of a bead bed system for the prevention of pressure sores in elderly orthopaedic patients. J Adv Nurs. 1982;7(6):545-8. [pmid: 6759553].
72 Gray DG. A randomized clinical trial of two types of foam mattresses. J Tissue Viability. 1994;(4):128-32.
73 Gray DG, Smith M. Comparison of a new foam mattress with the standard hospital mattress. J Wound Care. 2000;9(1):29-31. [pmid: 10827665].
74 Gunningberg L, Lindholm C, Carlsson M, et al. Effect of visco-elastic foam mattresses on the development of pressure ulcers in patients with hip fractures. J Wound Care. 2000;9(10):455-60. [pmid: 11933449].
75 Hampton S. Efficacy and cost-effectiveness of the Thermo contour mattress. British Journal of Nursing. 1999;8(15):990-6. [pmid: 10711028].
76 Hofman A, Geelkerken RH, Wille J, et al. Pressure sores and pressure-decreasing mattresses: controlled clinical trial. Lancet. 1994;343(8897):568-71. [pmid: 7906329].
77 Hoshowsky VM, Schramm CA. Intraoperative pressure sore prevention: an analysis of bedding materials. Res Nurs Health. 1994;17(5):333-9. [pmid: 8090944].
78 Inman KJ, Sibbald WJ, Rutledge FS, et al. Clinical utility and cost-effectiveness of an air suspension bed in the prevention of pressure ulcers. JAMA. 1993;269(9):1139-43. [pmid: 8433469].
79 Jesurum J, Joseph K, Davis JM, et al. Balloons, beds, and breakdown. Effects of low-air loss therapy on the development of pressure ulcers in cardiovascular surgical patients with intra-ortic balloon pump support. Crit Care Nurs Clin North Am. 1996;8(4):423-40. [pmid: 9095813].
80 Jolley DJ, Wright R, McGowan S, et al. Preventing pressure ulcers with the Australian Medical Sheepskin: an open-label randomised controlled trial. Med J Aust. 2004;180(7):324-7. [pmid: 15059051].
81 Kemp MG, Kopanke D, Tordecilla L, et al. The role of support surfaces and patient attributes in preventing pressure ulcers in elderly patients. Res Nurs Health. 1993;16(2):89-96. [pmid: 8502770].
82 Keogh A, Dealey C. Profiling beds versus standard hospital beds: effects on pressure ulcer incidence outcomes. J Wound Care. 2001;10(2):15-9. [pmid: 12964222].
83 Lazzara DJ, Buschmann MT. Prevention of pressure ulcers in elderly nursing home residents: are special support surfaces the answer?. Decubitus. 1991;4(4):42-4. 6. 8. [pmid: 1760125].
84 Lim R, Sirett R, Conine TA, et al. Clinical trial of foam cushions in the prevention of decubitis ulcers in elderly patients. J Rehabil Res Dev. 1988;25(2):19-26. [pmid: 3361457].
85 McGowan S, Montgomery K, Jolley D, et al. The role of sheepskins in preventing pressure ulcers in elderly orthopaedic patients. First World Wound Healing Congress. 2000.
86 Mistiaen P, Achterberg W, Ament A, et al. The effectiveness of the Australian Medical Sheepskin for the prevention of pressure ulcers in somatic nursing home patients: a prospective multicenter randomized-controlled trial (ISRCTN17553857). Wound Repair Regen. 2010;18(6):572-9. [pmid: 20946141].
87 Nixon J, McElvenny D, Mason S, et al. A sequential randomised controlled trial comparing a dry visco-elastic polymer pad and standard operating table mattress in the prevention of post-operative pressure sores. Int J Nurs Stud. 1998;35(4):193-203. [pmid: 9801935].
88 Nixon J, Cranny G, Iglesias C, et al. Randomised, controlled trial of alternating pressure mattresses compared with alternating pressure overlays for the prevention of pressure ulcers: PRESSURE (pressure relieving support surfaces) trial. BMJ. 2006;332(7555):1413. [pmid: 16740530].
89 Russell JA, Lichtenstein SL. Randomized controlled trial to determine the safety and efficacy of a multi-cell pulsating dynamic mattress system in the prevention of pressure ulcers in patients undergoing cardiovascular surgery. Ostomy Wound Manage. 2000;46(2):46-51. 4. 5. [pmid: 10745855].
90 Russell LJ, Reynolds TM, Park C, et al. Randomized clinical trial comparing 2 support surfaces: results of the Prevention of Pressure Ulcers Study. Adv Skin Wound Care. 2003;16(6):317-27. [pmid: 14652518].
91 Sanada H, Sugama J, Matsui Y, et al. Randomised controlled trial to evaluate a new double-layer air-cell overlay for elderly patients requiring head elevation. J Tissue Viability. 2003;13(3):112-4. 6. 8 passim. [pmid: 12889398].
92 Schultz AA, Bien M, Dumond K, et al. Etiology and incidence of pressure ulcers in surgical patients. AORN J. 1999;70:434-49. [pmid: 10514891].
93 Sideranko S, Quinn A, Burns K, et al. Effects of position and mattress overlay on sacral and heel pressures in a clinical population. Res Nurs Health. 1992;15(4):245-51. [pmid: 1496149].
94 Stapleton M. Preventing pressure sores - an evaluation of three products. Geriatr Nurs (Lond). 1986;6:23-25. [pmid: 3635484].
95 Takala J, Varmavuo S, Soppi E. Prevention of pressure sores in acute respiratory failure: A randomised controlled trial. Clin Intensive Care. 1996;7(5):228-35.
96 Taylor L. Evaluating the Pegasus Trinova: a data hierarchy approach. Br J Nurs. 1999;8(12):771-4. [pmid: 10670292].
97 Theaker C, Kuper M, Soni N. Pressure ulcer prevention in intensive care - a randomised control trial of two pressure-relieving devices. Anaesthesia. 2005;60(4):395-9. [pmid: 15766343].
98 Tymec AC, Pieper B, Vollman K. A comparison of two pressure-relieving devices on the prevention of heel pressure ulcers. Adv Wound Care. 1997;10(1):39-44. [pmid: 9204803].
99 van Leen M, Hovius S, Neyens J, et al. Pressure relief, cold foam or static air? A single center, prospective, controlled randomized clinical trial in a Dutch nursing home. J Tissue Viability. 2011;20(1):30-4. [pmid: 20510611].
100 Vanderwee K, Grypdonck MH, Defloor T. Effectiveness of an alternating pressure air mattress for the prevention of pressure ulcers. Age Ageing. 2005;34(3):261-7. [pmid: 15764622].
101 Vyhlidal SK, Moxness D, Bosak KS, et al. Mattress replacement or foam overlay? A prospective study on the incidence of pressure ulcers. Appl Nur Res. 1997;10(3):111-20. [pmid: 9274063].
102 Bourdel-Marchasson I, Barateau M, Rondeau V, et al. A multi-center trial of the effects of oral nutritional supplementation in critically ill older inpatients. Nutrition. 2000;16(1):1-5. [pmid: 10674226].
103 Ek AC, Unosson M, Larsson J, et al. The development and healing of pressure sores related to the nutritional state. Clin Nutr. 1991;10(5):245-50. [pmid: 16839927].
104 Hartgrink HH, Wille J, Konig P, et al. Pressure sores and tube feeding in patients with a fracture of the hip: a randomized clinical trial. Clin Nutr (Edinburgh, Scotland). 1998;17(6):287-92.
105 Houwing RH, Rozendaal M, Wouters-Wesseling W, et al. A randomised, double-blind assessment of the effect of nutritional supplementation on the prevention of pressure ulcers in hip-fracture patients. Clin Nutr. 2003;22(4):401-5. [pmid: 12880608].
106 Delmi M, Rapin CH, Bengoa JM, et al. Dietary supplementation in elderly patients with fractured neck of the femur. Lancet. 1990;335(8696):1013-6. [pmid: 1970070].
107 Theilla M, Singer P, Cohen J, et al. A diet enriched in eicosapentanoic acid, gamma-linolenic acid and antioxidants in the prevention of new pressure ulcer formation in critically ill patients with acute lung injury: A randomized, prospective, controlled study. Clin Nutr. 2007;26(6):752-7. [pmid: 17933438].
108 Brown MM, Cornwell J, Weist JK. Reducing the risks to the institutionalized elderly: Part I. Depersonalization, negative relocation effects, and medical care deficiencies. Part II. Fire, food poisoning, decubitus ulcer and drug abuse. J Gerontol Nurs. 1981;7(7):401-407. [pmid: 6912266].
109 Defloor T, De Bacquer D, Grypdonck MHF. The effect of various combinations of turning and pressure reducing devices on the incidence of pressure ulcers. Int J Nurs Stud. 2005;42(1):37-46. [pmid: 15582638].
110 Moore Z, Cowman S, Conroy RM. A randomised controlled clinical trial of repositioning, using the 30° tilt, for the prevention of pressure ulcers. J Clin Nurs. 2011;20(17/18):2633-44. [pmid: 21702861].
111 Smith AM, Malone JA. Preventing pressure ulcers in institutionalized elders: assessing the effects of small, unscheduled shifts in body position. Decubitus. 1990;3(4):20-4. [pmid: 2242233].
112 Vanderwee K, Grypdonck MH, De Bacquer D, et al. Effectiveness of turning with unequal time intervals on the incidence of pressure ulcer lesions. J Adv Nurs. 2007;57(1):59-68. [pmid: 17184374].
113 Young T. The 30 degree tilt position versus the 90 degree lateral and supine positions in reducing the incidence of non-blanching erythema in a hospital inpatient population: a randomised controlled trial. J Tissue Viability. 2004;14(3):88-96. [pmid: 15709355].
114 Brindle CT, Wegelin JA. Prophylactic Dressing Application to Reduce Pressure Ulcer Formation in Cardiac Surgery Patients. J Wound Ostomy Continence Nurs. 2012;39(2):133-142. [pmid: 22415123].
115 Fader M, Clarke-O’Neill S, Cook D, et al. Management of night-time urinary incontinence in residential settings for older people: an investigation into the effects of different pad changing regimes on skin health. J Clin Nurs. 2003;12(3):374-86. [pmid: 12709112].
116 Nakagami G, Sanada H, Konya C, et al. Evaluation of a new pressure ulcer preventive dressing containing ceramide 2 with low frictional outer layer. J Adv Nurs. 2007;59(5):520-9. [pmid: 17681081].
117 Barton AA, Barton M. Drug-based prevention of pressure-sores. Lancet. 1976;2(7983):443-4. [pmid: 73744].
118 Scott EM, Leaper DJ, Clark M, et al. Effects of warming therapy on pressure ulcers--a randomized trial. AORN J. 2001;73(5):921-7. 9. 33. 36. 8. [pmid: 11378948].
119 Verbelen J. Use of polarised light as a method of pressure ulcer prevention in an adult intensive care unit. J Wound Care. 2007;16(4):145-50. [pmid: 17444378].
120 Cooper P, Gray D. Comparison of two skin care regimes for incontinence. Br J Nurs. 2001;10(6 Suppl):S6-S20. [pmid: 12070396].
121 Declair V. The usefulness of topical application of essential fatty acids (EFA) to prevent pressure ulcers. Ostomy Wound Manage. 1997;43(5):48-52. [pmid: 9233238].
122 Duimel-Peeters IG, RJGH, Ambergen AW, et al. The effectiveness of massage with and without dimethyl sulfoxide in preventing pressure ulcers: a randomized, double-blind cross-over trial in patients prone to pressure ulcers. Int J Nurs Stud. 2007;44(8):1285-95. [pmid: 17553503].
123 Houwing R, van Asbeck S, Halfens R, et al. An unexpected deterimental effect on the incidence of heel pressure ulcers after local 5% DMSO cream application: a randomized, double-blind study in patients at risk for pressure ulcers. Wounds. 2008;20(4):84-8.
124 Smith RG, Everett E, Tucker L. A double blind trial of silicone barrier cream in the prevention of pressure sores in elderly patients. J Clin Exp Gerontol. 1986;7(4):337-46.
125 Torra i Bou JE, Segovia Gomez T, Verdu Soriano J, et al. The effectiveness of a hyperoxygenated fatty acid compound in preventing pressure ulcers. J Wound Care. 2005;14(3):117-21. [pmid: 15779642].
126 van der Cammen TJ, O’Callaghan U, Whitefield M. Prevention of pressure sores. A comparison of new and old pressure sore treatments. Br J Clin Pract. 1987;41(11):1009-11. [pmid: 3332839].
127 Barbenel JC, Jordan MM, Nicol SM, et al. Inicidence of pressure-sores in the greater Glasgow Health Board area. Lancet. 1977;310(8037):548-50. [pmid: 95742].