# Overall Strength of Evidence Tables

Appendix Table G1 Strength of evidence for Key Question 1

Details | Number of studies | Quality (Good, Fair, Poor) | Consistency (High, Moderate, Low) | Directness (Direct or indirect) | Precision (High, Moderate, Low) | Number of subjects | Strength of evidence
Pressure ulcer incidence or severity: Waterlow scale vs. clinical judgment | 1 | Good | Not applicable (1 study) | Direct | Low | 1,231 | Low
Pressure ulcer incidence or severity: Norton scale vs. clinical judgment | 1 | Poor | Not applicable (1 study) | Direct | Low | 240 | Insufficient
Pressure ulcer incidence or severity: Braden scale vs. clinical judgment | 1 | Poor | Not applicable (1 study) | Direct | Low | 521 | Insufficient

Note: Key Question 1. For adults in various settings, is the use of any risk assessment tool effective in reducing the incidence or severity of pressure ulcers, compared with other risk assessment tools, clinical judgment alone, and/or usual care?

Appendix Table G2 Strength of evidence for Key Question 1a

Details | Number of studies | Quality (Good, Fair, Poor) | Consistency (High, Moderate, Low) | Directness (Direct or indirect) | Precision (High, Moderate, Low) | Number of subjects | Strength of evidence
Not relevant | 0 | No evidence | No evidence | No evidence | No evidence | No evidence | Insufficient

Note: Key Question 1a. Does the effectiveness and comparative effectiveness of risk assessment tools differ according to setting?

Appendix Table G3 Strength of evidence for Key Question 1b

Details | Number of studies | Quality (Good, Fair, Poor) | Consistency (High, Moderate, Low) | Directness (Direct or indirect) | Precision (High, Moderate, Low) | Number of subjects | Strength of evidence
Not relevant | 0 | No evidence | No evidence | No evidence | No evidence | No evidence | Insufficient

Note: Key Question 1b. Does the effectiveness and comparative effectiveness of risk assessment tools differ according to patient characteristics, and other known risk factors for pressure ulcers, such as nutritional status or incontinence?

Appendix Table G4 Strength of evidence for Key Question 2

Details | Number of studies | Quality (Good, Fair, Poor) | Consistency (High, Moderate, Low) | Directness (Direct or indirect) | Precision (High, Moderate, Low) | Number of subjects | Strength of evidence
Diagnostic accuracy: Braden Scale | AUROC: 7 Sensitivity/specificity, cutoff ≤18: 16; all cut-offs: 32 | Fair | Moderate | Direct | Moderate | AUROC: 4,811 Sensitivity/specificity, cutoff ≤18: 5,462; all cut-offs: 11,596 | Moderate
Diagnostic accuracy: Norton scale | AUROC: 3 Sensitivity/specificity, cutoff ≤14: 5; all cut-offs: 12 | Fair | Moderate | Direct | Low | AUROC: 4,191 Sensitivity/specificity: Cutoff ≤14: 2,809 All cut-offs: 5,910 | Moderate
Diagnostic accuracy: Waterlow scale | AUROC: 4 Sensitivity/specificity, cutoff ≥10: 2; all cut-offs: 10 | Fair | Moderate | Direct | Low | AUROC: 2,559 Sensitivity/specificity, cutoff ≥10: 419 all cut-offs: 3,979 | Moderate
Diagnostic accuracy: Cubbin and Jackson scale | AUROC: 3 Sensitivity/specificity, cutoff ≤24 to 29: 3 | Fair | Moderate | Direct | Low | AUROC: 865 Sensitivity/specificity, cutoff ≤24 to 29: 865 | Moderate
Diagnostic accuracy: Direct comparisons between risk assessment scales | AUROC: 6 Sensitivity/specificity, all scales, common cut-offs: 8; all scales, all cut-offs: 14 | Fair | Moderate | Direct | Moderate | AUROC: 5,921 Sensitivity/specificity, all scales, common cut-offs: 4,637 all scales, all cut-offs: 6,528 | Moderate

Note: Key Question 2. How do various risk assessment tools compare with one another in their ability to predict the incidence of pressure ulcers?

Appendix Table G5 Strength of evidence for Key Question 2a

Details | Number of studies | Quality (Good, Fair, Poor) | Consistency (High, Moderate, Low) | Directness (Direct or indirect) | Precision (High, Moderate, Low) | Number of subjects | Strength of evidence
Diagnostic accuracy: Braden scale, across settings (direct evidence) | 29 | Fair | Moderate | Indirect | Low | 10,705 | Low
Diagnostic accuracy: Cubbin and Jackson, ICU setting | 2 | Fair | Moderate | Direct | Low | 646 | Low
Diagnostic accuracy: Braden scale, optimal cutoff in different settings | 9 | Fair | Moderate | Indirect | Low | 3,654 | Low

Note: Key Question 2a. Does the predictive validity of various risk assessment tools differ according to setting?

Appendix Table G6 Strength of evidence for Key Question 2b

Details | Number of studies | Quality (Good, Fair, Poor) | Consistency (High, Moderate, Low) | Directness (Direct or indirect) | Precision (High, Moderate, Low) | Number of subjects | Strength of evidence
Diagnostic accuracy: Braden scale, differences according to race | 2 | Fair | Low | Direct | Low | 917 | Low
Diagnostic accuracy: Braden scale, differences according to baseline pressure ulcer risk | 3 | Fair | Moderate | Direct | Low | 3,535 | Moderate

Note: Key Question 2b. Does the predictive validity of various risk assessment tools differ according to patient characteristics?

Appendix Table G7 Strength of evidence for Key Question 3

Details | Number of studies | Quality (Good, Fair, Poor) | Consistency (High, Moderate, Low) | Directness (Direct or indirect) | Precision (High, Moderate, Low) | Number of subjects | Strength of evidence
Pressure ulcer incidence or severity: Advanced static mattresses or overlays vs. a standard hospital mattress | 12 | Fair | High | Direct | Moderate | 2,533 | Moderate
Pressure ulcer incidence or severity: Advanced static mattress or overlay vs. advanced static mattress or overlay | 11 | Fair | Moderate | Direct | Moderate | 1,170 | Moderate
Pressure ulcer incidence or severity: Low-air-loss bed vs. standard hospital mattress | 2 | Fair | Low | Direct | Low | 134 | Low
Pressure ulcer incidence or severity: Low-air-loss mattresss versus dual option (constant low pressure/alternating air) mattress | 1 | Fair | Not applicable (1 study) | Direct | Low | 62 | Low
Pressure ulcer incidence or severity: Alternating air pressure overlay or mattress vs. standard hospital mattress | 3 | Poor | High | Direct | Moderate | 768 | Low
Pressure ulcer incidence or severity: Alternating air pressure overlay or mattress vs. advanced static overlay or mattress | 6 | Fair | Moderate | Direct | Moderate | 1,339 | Moderate
Pressure ulcer incidence or severity: Alternating air pressure overlay or mattress vs. alternating air pressure overlay or mattress | 4 | Fair | Moderate | Direct | Moderate | 2,734 | Moderate
Pressure ulcer incidence or severity: Heel ulcer supports or boots vs. usual care | 2 | Fair | Low | Direct | Low | 291 | Low
Pressure ulcer incidence or severity: Heel ulcer preventive intervention vs. heel ulcer preventive intervention | 1 | Poor | Not applicable (1 study) | Direct | Low | 240 | Insufficient
Pressure ulcer incidence or severity: More sophisticated wheelchair cushions vs. standard wheelchair cushions | 4 | Fair | Low | Direct | Moderate | 653 | Low
Pressure ulcer incidence or severity: Nutritional supplementation vs. standard hospital diet | 6 | Poor | Moderate | Direct | Low | 1,553 | Low
Pressure ulcer incidence or severity: Repositioning intervention vs. usual care | 4 | Fair | Moderate | Direct | Low | 1,332 | Low
Pressure ulcer incidence or severity: Small, unscheduled shifts in body position vs. usual care | 2 | Poor | High | Direct | Low | 34 | Low
Pressure ulcer incidence or severity: Silicone border foam sacral dressing vs. no silicone border foam dressing | 1 | Fair | Not applicable (1 study) | Direct | Low | 85 | Low
Pressure ulcer incidence or severity: REMOIS pad vs. no pad | 1 | Poor | Not applicable (1 study) | Direct | Low | 37 | Insufficient
Pressure ulcer incidence or severity: Changing incontinence pad three vs. two times daily | 1 | Fair | Not applicable (1 study) | Direct | Low | 81 | Low
Pressure ulcer incidence or severity: Intraoperative warming vs. usual care | 1 | Fair | Not applicable (1 study) | Direct | Low | 324 | Low
Pressure ulcer incidence or severity: Corticotropin vs. sham | 1 | Poor | Not applicable (1 study) | Direct | Low | 85 | Insufficient
Pressure ulcer incidence or severity: Polarized light | 1 | Poor | Not applicable (1 study) | Direct | Low | 23 | Insufficient
Pressure ulcer incidence or severity: Fatty acid cream vs. placebo | 2 | Fair | Moderate | Direct | Moderate | 417 | Low
Pressure ulcer incidence or severity: Other cream or lotion vs. placebo | 3 | Poor | Moderate | Direct | Low | 534 | Insufficient
Pressure ulcer incidence or severity: Skin cleanser vs. standard soap and water | 1 | Fair | Not applicable (1 study) | Direct | Low | 93 | Low

Note: Key Question 3. In patients at increased risk of developing pressure ulcers, what is the effectiveness and comparative effectiveness of preventive interventions in reducing the incidence or severity of pressure ulcers?

Appendix Table G8 Strength of evidence for Key Question 3a

Details | Number of studies | Quality (Good, Fair, Poor) | Consistency (High, Moderate, Low) | Directness (Direct or indirect) | Precision (High, Moderate, Low) | Number of subjects | Strength of evidence
Pressure ulcer incidence or severity: Static foam overlay vs. standard care, lower-risk surgical population | 2 | Good | High | Direct | Low | 588 | Moderate
Pressure ulcer incidence or severity: Static dry polymer overlay vs. standard care, lower-risk surgical population | 2 | Fair | High | Direct | Low | 921 | Low
Pressure ulcer incidence or severity: Static foam block mattress vs. standard care, lower-risk surgical population | 1 | Poor | Not applicable (1 study) | Direct | Low | 1,729 | Insufficient
Pressure ulcer incidence or severity: Alternating air vs. static mattress or overlay, lower-risk surgical population | 2 | Fair | High | Direct | Low | 415 | Low

Note: Key Question 3a. Does the effectiveness and comparative effectiveness of preventive interventions differ according to [underlined: risk level] as determined by different risk assessment methods and/or by particular risk factors?

Appendix Table G9 Strength of evidence for Key Question 3b

Details | Number of studies | Quality (Good, Fair, Poor) | Consistency (High, Moderate, Low) | Directness (Direct or indirect) | Precision (High, Moderate, Low) | Number of subjects | Strength of evidence
Not relevant | No evidence | No evidence | No evidence | No evidence | No evidence | No evidence | Insufficient

Note: Key Question 3b. Does the effectiveness and comparative effectiveness of preventive interventions differ according to [underlined: setting]?

Appendix Table G10 Strength of evidence for Key Question 3c

Details | Number of studies | Quality (Good, Fair, Poor) | Consistency (High, Moderate, Low) | Directness (Direct or indirect) | Precision (High, Moderate, Low) | Number of subjects | Strength of evidence
Not relevant | No evidence | No evidence | No evidence | No evidence | No evidence | No evidence | Insufficient

Note: Key Question 3c. Does the effectiveness and comparative effectiveness of preventive interventions differ according to [underlined: patient characteristics]?

Appendix Table G11 Strength of evidence for Key Question 4

Details | Number of studies | Quality (Good, Fair, Poor) | Consistency (High, Moderate, Low) | Directness (Direct or indirect) | Precision (High, Moderate, Low) | Number of subjects | Strength of evidence
Harms: Support surfaces | 9 | Fair | Moderate | Direct | Low | 4,524 | Low^*^
Harms: Nutritional supplementation | 1 | Fair | Not applicable (1 study) | Direct | Low | 129 | Low^*^
Harms: Repositioning | 2 | Fair | Moderate | Direct | Low | 884 | Low^*^
Harms: Lotions, creams and cleansers | 3 | Fair | Moderate | Direct | Low | 424 | Low^*^
Harms: Dressings | 1 | Poor | Not applicable (1 study) | Direct | Low | 37 | Low^*^

Note: Key Question 4. What are the harms of interventions for the prevention of pressure ulcers?

Appendix Table G12 Strength of evidence for Key Question 4a

Details | Number of studies | Quality (Good, Fair, Poor) | Consistency (High, Moderate, Low) | Directness (Direct or indirect) | Precision (High, Moderate, Low) | Number of subjects | Strength of evidence
Not relevant | No evidence | No evidence | No evidence | No evidence | No evidence | No evidence | Insufficient

Note: Key Quesiton 4a. Do the harms of preventive interventions differ according to the type of intervention?

Appendix Table G13 Strength of evidence for Key Question 4b

Details | Number of studies | Quality (Good, Fair, Poor) | Consistency (High, Moderate, Low) | Directness (Direct or indirect) | Precision (High, Moderate, Low) | Number of subjects | Strength of evidence
Not relevant | No evidence | No evidence | No evidence | No evidence | No evidence | No evidence | Insufficient

Note: Key Question 4b. Do the harms of preventive interventions differ according to setting?

Appendix Table G14 Strength of evidence for Key Question 4c

Details | Number of studies | Quality (Good, Fair, Poor) | Consistency (High, Moderate, Low) | Directness (Direct or indirect) | Precision (High, Moderate, Low) | Number of subjects | Strength of evidence
Not relevant | No evidence | No evidence | No evidence | No evidence | No evidence | No evidence | Insufficient

* Selective reporting of harms also noted.

Note: Key Question 4c. Do the harms of preventive interventions differ according to patient characteristics?

## Appendix G Reference

Owens D, Lohr KN, Atkins D, et al. AHRQ Series Paper 5: Grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].