# Inclusion and Exclusion Criteria by Key Question

| Include | Exclude
KQ 1
Population | All adult patients, ages ≥18 years old in the following settings: acute care hospital, long-term care facility, rehabilitation facility, operating room, home care, and wheelchair users in the community | Children and adolescents
Patient characteristics | Such as age, race or skin tone, physical impairment, body weight, specific medical comorbidities (e.g., diabetes, peripheral vascular disease) | Baseline pressure ulcers (>10%)
Interventions | Pressure ulcer risk-assessment tools, including Braden Scale, Norton Scale, Waterlow Scale, other tools | Individual predictors/risk factors
Comparators | Clinical judgment and/or usual care Different risk-assessment tools and reference standard
Outcomes | Incidence of pressure ulcers, further examining effects of setting and patient characteristics on incidence Severity/stage of pressure ulcers, further examining effects of setting and patient characteristics on severity/stage Resource utilization (e.g., length of stay, number of hospitalizations)
Settings | Acute care hospital, long-term care facility, rehabilitation facility, operating room, home care, and wheelchair users in the community
Study designs | Controlled or comparative randomized and nonrandomized trials and controlled or comparative observational studies
KQ 2
Population | All adult patients, ages ≥18 years old in the following settings: acute care hospital, long-term care facility, rehabilitation facility, operating room, home care, and wheelchair users in the community | Children and adolescents
Patient characteristics | Such as age, race or skin tone, physical impairment, body weight, specific medical comorbidities (e.g., diabetes, peripheral vascular disease) | Baseline pressure ulcers (>10%)
Interventions | Pressure ulcer risk-assessment tools, including Braden Scale, Norton Scale, Waterlow Scale, other tools | Individual predictors/risk factors
Comparators | Different risk-assessment tools and reference standard
Outcomes | Predictive validity of tools, further examining effects of setting and patient characteristics on predictive validity. E.g., diagnostic accuracy = sensitivity, specificity, positive and negative likelihood ratios, positive and negative predictive values; measures of risk = HR, OR, RR; calibration; discrimination = area under receiver operating characteristic (ROC) curve, etc. | Inter-rater reliability
Settings | Acute care hospital, long-term care facility, rehabilitation facility, operating room, home care, and wheelchair users in the community
Study designs | Studies of predictive validity; Prospective studies | Retrospective studies; Case-control studies
KQ 3
Population | Adult patients, ages ≥18 years old | Children and adolescents
Patient characteristics | Such as age, race or skin tone, physical impairment, body weight, specific medical comorbidities (e.g., diabetes, peripheral vascular disease) | >20% stage 2 ulcers at baseline, or proportion with ulcers at baseline not reported and includes patients with stage 2 or higher ulcers
Interventions | Interventions to prevent pressure ulcers: Support surfaces (e.g., beds, overlays for mattresses), Dressings, Nutritional support, Nursing interventions (e.g., turning, repositioning), Self-care education, Wheelchair features, Combined treatment modalities | Non-preventive treatment interventions (covered in a separate review) Nursing education
Comparators | Usual care, placebo, no treatment, different preventive interventions (including different preventive interventions within the same category; e.g., alternating pressure mattress vs. foam overlay)
Outcomes | Incidence of pressure ulcers, further examining effects of risk level, setting, and patient characteristics on incidence Severity/stage of pressure ulcers, further examining effects of risk level, setting, and patient characteristics on severity/stage Resource utilization (e.g., length of stay, number of hospitalizations) More specific measures of comfort: sleep deprivation, quality of life, etc. | Comfort
Settings | Acute care hospital, long-term care facility, rehabilitation facility, operating room, home care, and wheelchair users in the community
Study designs | Randomized controlled trials | Observational studies
KQ 4
Population | Adult patients, ages ≥18 years old | Children and adolescents
Patient characteristics | Such as age, race or skin tone, physical impairment, body weight, specific medical comorbidities (e.g., diabetes, peripheral vascular disease) | >20% stage 2 ulcers at baseline, or proportion with ulcers at baseline not reported and includes patients with stage 2 or higher ulcers
Interventions | Interventions to prevent pressure ulcers: Support surfaces (e.g., beds, overlays for mattresses), Dressings, Nutritional support, Nursing interventions (e.g., turning, repositioning), Self-care education, Wheelchair features, Combined treatment modalities | Non-preventive treatment interventions (covered in a separate review)
Comparators | Usual care, placebo, no treatment, different preventive interventions (including different preventive interventions within the same category; e.g., alternating pressure mattress vs. foam overlay)
Outcomes | Harms of preventive interventions/strategies, such as dermatologic reactions, pain, or infection, further examining effects of categories of impairment, setting, and patient characteristics
Settings | Acute care hospital, long-term care facility, rehabilitation facility, operating room, home care, and wheelchair users in the community
Study designs | Randomized controlled trials, cohort studies, and other observational studies.