# Search Strategies

## Overall

Database: EBM Reviews - Cochrane Database of Systematic Reviews

1. ((pressure or decubitus) and ulcer$).ti,ab.
2. ((pressure or decubitus) and sore$).ti,ab.
3. (bed sore$ or bedsore$).ti,ab.
4. or/1–3

## Risk Assessment

Database: Ovid MEDLINE^®^ and Ovid OLDMEDLINE^®^

1. Pressure Ulcer/
2. ((pressure or decubitus) and ulcer$).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier]
3. ((pressure or decubitus) and sore$).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier]
4. (bed sore$ or bedsore$).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier]
5. or/1–4
6. Risk Assessment/
7. Risk Factors/
8. Nursing Assessment/
9. “Predictive Value of Tests”/
10. ROC Curve/
11. “Sensitivity and Specificity”/
12. “Reproducibility of Results”/
13. or/6–12
14. (risk adj2 (factor$ or assess$)).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier]
15. 13 or 14
16. 5 and 15
17. “Severity of Illness Index”/
18. 5 and 17
19. 16 or 18
20. limit 19 to “all adult (19 plus years)”
21. limit 20 to humans

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. Pressure Ulcer/
2. ((pressure or decubitus) and ulcer$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3. ((pressure or decubitus) and sore$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4. (bed sore$ or bedsore$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
5. or/1–4
6. Risk Assessment/
7. Risk Factors/
8. Nursing Assessment/
9. “Predictive Value of Tests”/
10. ROC Curve/
11. “Sensitivity and Specificity”/
12. “Reproducibility of Results”/
13. or/6–12
14. (risk adj2 (factor$ or assess$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
15. 13 or 14
16. 5 and 15
17. “Severity of Illness Index”/
18. 5 and 17
19. 16 or 18

Database: EBSCO CINAHL Plus^®^

S1 (MH “Pressure Ulcer”)
S2 “pressure ulcer*”
S3 “decubitus ulcer*”
S4 “bedsore*”
S5 “bed sore*”
S6 S1 or S2 or S3 or S4 or S5
S7 (MH “Risk Assessment”) OR “risk assessment”
S8 (MH “Risk Factors”) OR “risk factors”
S9 (MH “Nursing Assessment”)
S10 (MH “Predictive Value of Tests”)
S11 (MH “Sensitivity and Specificity”)
S12 (MH “Reproducibility of Results”)
S13 (MH “ROC Curve”)
S14 S7 or S8 or S9 or S10 or S11 or S12 or S13
S15 “risk factor*”
S16 “risk assess*”
S17 S14 or S15 or S16
S20 Limiters - Exclude MEDLINE records
S19 Limiters - Age Groups: All Adult
S18 S6 and S17
S21 S18 and S19
S22 S18 and S20
S23 S21 and S22

## Risk Assessment—Prognosis

Database: Ovid MEDLINE^®^ and Ovid OLDMEDLINE^®^

1. Pressure Ulcer/
2. ((pressure or decubitus) and ulcer$).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier]
3. ((pressure or decubitus) and sore$).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier]
4. (bed sore$ or bedsore$).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier]
5. or/1–4
6. Risk Assessment/
7. Risk Factors/
8. Nursing Assessment/
9. “Predictive Value of Tests”/
10. ROC Curve/
11. “Sensitivity and Specificity”/
12. “Reproducibility of Results”/
13. or/6–12
14. (risk adj2 (factor$ or assess$)).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier]
15. 13 or 14
16. 5 and 15
17. “Severity of Illness Index”/
18. 5 and 17
19. 16 or 18
20. limit 19 to “all adult (19 plus years)”
21. limit 20 to humans
22. Prognosis/
23. 16 and 22
24. limit 23 to “all adult (19 plus years)”

## Prevention

Database: Ovid MEDLINE^®^ and Ovid OLDMEDLINE^®^

1. Pressure Ulcer/
2. ((pressure or decubitus) and ulcer$).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier]
3. ((pressure or decubitus) and sore$).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier]
4. (bed sore$ or bedsore$).mp. [mp=protocol supplementary concept, rare disease supplementary concept, title, original title, abstract, name of substance word, subject heading word, unique identifier]
5. or/1–4
6. 5 and pc.fs.
7. 5 and prevent$.mp.
8. 6 or 7
9. limit 8 to “all adult (19 plus years)”
10. limit 9 to humans

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. Pressure Ulcer/
2. ((pressure or decubitus) and ulcer$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3. ((pressure or decubitus) and sore$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4. (bed sore$ or bedsore$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
5. or/1–4
6. 5 and pc.fs.
7. 5 and prevent$.mp.
8. 6 or 7

Database: EBSCO CINAHL Plus^®^

S1 (MH “Pressure Ulcer”)
S2 “pressure ulcer*”
S3 “decubitus ulcer*”
S4 “bedsore*”
S5 “bed sore*”
S6 S1 or S2 or S3 or S4 or S5
S7 “prevent*”
S8 S6 and S7
S9 S6 and S7 Limiters - Exclude MEDLINE records
S10 S6 and S7 Limiters - Age Groups: All Adult