# Abbreviations

Abbreviation: Definition
AHRQ: Agency for Healthcare Research and Quality
AUROC: Area under the receiver operating characteristic
CER: Comparative effectiveness review
CI: Confidence interval
EPC: Evidence-based Practice Center
NPUAP: National Pressure Ulcer Advisory Panel
OR: Odds ratio
PICOTS: Populations, Interventions, Comparators, Outcomes, Timing and Setting
RR: Risk ratio
SIP: Scientific information packet
TEP: Technical Expert Panel
USPSTF: United States Preventive Services Task Force