# References

1 Walters AS, Walters AS, Aldrich MS, et al. Toward a better definition of the restless legs syndrome. Movement disorders: official journal of the Movement Disorder Society. Sep. 1995;10(5):634-42. [pmid: 8552117].
2 Allen RP, Picchietti D, Hening WA, et al. Restless legs syndrome: diagnostic criteria, special considerations, and epidemiology A report from the restless legs syndrome diagnosis and epidemiology workshop at the National Institutes of Health. Sleep medicine. Apr. 01. 2003;r00108(4):101-19. [pmid: 14592341].
3 Trenkwalder C, Paulus W. Restless legs syndrome: pathophysiology, clinical presentation and management. Nature Reviews Neurology. Jul. 2010;6(6):337-46. [pmid: 20531433].
4 García-Borreguero D, Egatz R, Winkelmann J, et al. Epidemiology of restless legs syndrome: The current status. Sleep medicine reviews. Jul. 2006;10(3):153-67. [pmid: 16762806].
5 Leschziner G, Gringras P. Restless legs syndrome. BMJ. 2012;344:e3056. [pmid: 22623643].
6 Silber MH, Ehrenberg BL, Allen RP, et al. An algorithm for the management of restless legs syndrome. Mayo Clinic proceedings. Mayo Clinic. Jul. 2004;79(7):916-22. [pmid: 15244390].
7 Garcia-Borreguero D, Williams AM. Dopaminergic augmentation of restless legs syndrome. Sleep Med Rev. Oct. 2010;14(5):339-46. [pmid: 20219397].
8 Cornelius JR, Tippmann-Peikert M, Slocumb NL, et al. Impulse control disorders with the use of dopaminergic agents in restless legs syndrome: a case-control study. Sleep. Jan. 2010;33(1):81-7. [pmid: 20120624].
9 Cesnik E, Casetta I, Turri M, et al. Transient RLS during pregnancy is a risk factor for the chronic idiopathic form. Neurology. Dec. 7. 2010;75(23):2117-20. [pmid: 21135386].
10 Manconi M, Govoni V, De Vito A, et al. Restless legs syndrome and pregnancy. Neurology. Sep. 28. 2004;63(6):1065-9. [pmid: 15452299].
11 Higgins JPT, Green S, editors. Cochrane handbook for systematic reviews of interventions. The Cochrane Collaboration. 2008.
12 Centre TNC. Reveiw Manager Version. 50 ed. Copenhagen. The Cochrane Collaboration. 2008.
13 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. Journal of Clinical Epidemiology. May. 2010;63(5):513-23. [pmid: 19595577].
14 Atkins D, Chang S, Gartlehner G, et al. Assessing the Applicability of Studies When Comparing Medical Interventions. Quality AfHRa. December. 2010. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayProduct&productID=603#2412.
15 Allen RP, Adler CH, Du W, et al. Clinical efficacy and safety of IV ferric carboxymaltose (FCM) treatment of RLS: a multi-centred, placebo-controlled preliminary clinical trial. Sleep Medicine. Oct. 2011;12(9):906-13. [pmid: 21978726].
16 Bassetti CL, Bornatico F, Fuhr P, et al. Pramipexole versus dual release levodopa in restless legs syndrome: a double blind, randomised, cross-over trial. Swiss Medical Weekly. 2011;141:w13274. [pmid: 22101745].
17 Trenkwalder C, Benes H, Grote L, et al. Cabergoline compared to levodopa in the treatment of patients with severe restless legs syndrome: results from a multi-center, randomized, active controlled trial. Movement Disorders. Apr. 15. 2007;22(5):696-703. [pmid: 17274039].
18 Lettieri CJ, Eliasson AH. Pneumatic compression devices are an effective therapy for restless legs syndrome: a prospective, randomized, double-blinded, sham-controlled trial. Chest. Jan. 2009;135(1):74-80. [pmid: 19017878].
19 Aukerman MM, Aukerman D, Bayard M, et al. Exercise and restless legs syndrome: a randomized controlled trial. Journal of the American Board of Family Medicine: JABFM. Sep–Oct. 2006;19(5):487-93. [pmid: 16951298].
20 Cuellar NG, Ratcliffe SJ. Does valerian improve sleepiness and symptom severity in people with restless legs syndrome?. Alternative Therapies in Health & Medicine. Mar–Apr. 2009;15(2):22-8. [pmid: 19284179].
21 Mitchell UH, Myrer JW, Johnson AW, et al. Restless legs syndrome and near-infrared light: An alternative treatment option. Physiotherapy Theory & Practice. Jul. 2011;27(5):345-51. [pmid: 20977377].
22 Adler CH, Hauser RA, Sethi K, et al. Ropinirole for restless legs syndrome: a placebo-controlled crossover trial. Neurology. Apr. 27. 2004;62(8):1405-7. [pmid: 15111683].
23 Bogan RK, Fry JM, Schmidt MH, et al. Ropinirole in the treatment of patients with restless legs syndrome: a US-based randomized, double-blind, placebo-controlled clinical trial. Mayo Clinic Proceedings. Jan. 2006;81(1):17-27. [pmid: 16438474].
24 Ferini-Strambi L, Aarskog D, Partinen M, et al. Effect of pramipexole on RLS symptoms and sleep: a randomized, double-blind, placebo-controlled trial. Sleep Medicine. Dec. 2008;9(8):874-81. [pmid: 18952497].
25 Hening WA, Allen RP, Ondo WG, et al. Rotigotine improves restless legs syndrome: a 6-month randomized, double-blind, placebo-controlled trial in the United States. Movement Disorders. Aug. 15. 2010;25(11):1675-83. [pmid: 20629075].
26 Hogl B, Garcia-Borreguero D, Trenkwalder C, et al. Efficacy and augmentation during 6 months of double-blind pramipexole for restless legs syndrome. Sleep Medicine. Apr. 2011;12(4):351-60. [pmid: 21354368].
27 Kushida CA, Geyer J, Tolson JM, et al. Patient- and physician-rated measures demonstrate the effectiveness of ropinirole in the treatment of restless legs syndrome. Clinical Neuropharmacology. Sep–Oct. 2008;31(5):281-6. [pmid: 18836346].
28 Montagna P, Hornyak M, Ulfberg J, et al. Randomized trial of pramipexole for patients with restless legs syndrome (RLS) and RLS-related impairment of mood. Sleep Medicine. Jan. 2011;12(1):34-40. [pmid: 20965780].
29 Montplaisir J, Karrasch J, Haan J, et al. Ropinirole is effective in the long-term management of restless legs syndrome: a randomized controlled trial. Movement Disorders. Oct. 2006;21(10):1627-35. [pmid: 16874755].
30 Oertel WH, Benes H, Bodenschatz R, et al. Efficacy of cabergoline in restless legs syndrome: a placebo-controlled study with polysomnography (CATOR). Neurology. Sep. 26. 2006;67(6):1040-6. [pmid: 16931508].
31 Oertel WH, Benes H, Garcia-Borreguero D, et al. Rotigotine transdermal patch in moderate to severe idiopathic restless legs syndrome: a randomized, placebo-controlled polysomnographic study. Sleep Medicine. Oct. 2010;11(9):848-56. [pmid: 20813583].
32 Oertel WH, Stiasny-Kolster K, Bergtholdt B, et al. Efficacy of pramipexole in restless legs syndrome: a six-week, multicenter, randomized, double-blind study (effect-RLS study). Movement Disorders. Jan. 15. 2007;22(2):213-9. [pmid: 17133582].
33 Stiasny-Kolster K, Benes H, Peglau I, et al. Effective cabergoline treatment in idiopathic restless legs syndrome. [Summary for patients in Neurology. 2004 Dec 28;63(12):E21–2; PMID: 15623673]. Neurology. Dec. 28. 2004;63(12):2272-9. [pmid: 15623686].
34 Trenkwalder C, Benes H, Poewe W, et al. Efficacy of rotigotine for treatment of moderate-to-severe restless legs syndrome: a randomised, double-blind, placebo-controlled trial. Lancet Neurology. Jul. 2008;7(7):595-604. [pmid: 18515185].
35 Trenkwalder C, Garcia-Borreguero D, Montagna P, et al. Ropinirole in the treatment of restless legs syndrome: results from the TREAT RLS 1 study, a 12 week, randomised, placebo controlled study in 10 European countries. Journal of Neurology, Neurosurgery & Psychiatry. Jan. 2004;75(1):92-7. [pmid: 14707315].
36 Walters AS, Ondo WG, Dreykluft T, et al. Ropinirole is effective in the treatment of restless legs syndrome. TREAT RLS 2: a 12-week, double-blind, randomized, parallel-group, placebo-controlled study. Movement Disorders. Dec. 2004;19(12):1414-23. [pmid: 15390050].
37 Winkelman JW, Sethi KD, Kushida CA, et al. Efficacy and safety of pramipexole in restless legs syndrome. Neurology. Sep. 26. 2006;67(6):1034-9. [pmid: 16931507].
38 Benes H, Mattern W, Peglau I, et al. Ropinirole improves depressive symptoms and restless legs syndrome severity in RLS patients: a multicentre, randomized, placebo-controlled study. Journal of Neurology. Jun. 2011;258(6):1046-54. [pmid: 21188406].
39 Oertel WH, Benes H, Garcia-Borreguero D, et al. Efficacy of rotigotine transdermal system in severe restless legs syndrome: a randomized, double-blind, placebo-controlled, six-week dose-finding trial in Europe. Sleep Medicine. Mar. 2008;9(3):228-39. [pmid: 17553743].
40 Lee DO, Ziman RB, Perkins AT, et al. A randomized, double-blind, placebo-controlled study to assess the efficacy and tolerability of gabapentin enacarbil in subjects with restless legs syndrome. Journal of Clinical Sleep Medicine. Jun. 15. 2011;7(3):282-92. [pmid: 21677899].
41 Bogan RK, Bornemann MAC, Kushida CA, et al. Long-term maintenance treatment of restless legs syndrome with gabapentin enacarbil: a randomized controlled study. [Erratum appears in Mayo Clin Proc. 2010 Jul;85(7);693–4]. Mayo Clinic Proceedings. Jun. 2010;85(6):512-21. [pmid: 20511481].
42 Allen R, Chen C, Soaita A, et al. A randomized, double-blind, 6-week, dose-ranging study of pregabalin in patients with restless legs syndrome. Sleep Medicine. Jun. 2010;11(6):512-9. [pmid: 20466589].
43 Garcia-Borreguero D, Larrosa O, de la Llave Y, et al. Treatment of restless legs syndrome with gabapentin: a double-blind, cross-over study. Neurology. Nov. 26. 2002;59(10):1573-9. [pmid: 12451200].
44 Garcia-Borreguero D, Larrosa O, Williams AM, et al. Treatment of restless legs syndrome with pregabalin: a double-blind, placebo-controlled study. Neurology. Jun. 8. 2010;74(23):1897-904. [pmid: 20427750].
45 Kushida CA, Becker PM, Ellenbogen AL, et al. Randomized, double-blind, placebo-controlled study of XP13512/GSK1838262 in patients with RLS. Neurology. Feb. 3. 2009;72(5):439-46. [pmid: 19188575].
46 Winkelman JW, Bogan RK, Schmidt MH, et al. Randomized polysomnography study of gabapentin enacarbil in subjects with restless legs syndrome. Movement Disorders. Sep. 2011;26(11):2065-72. [pmid: 21611981].
47 Bayard M, Bailey B, Acharya D, et al. Bupropion and restless legs syndrome: a randomized controlled trial. Journal of the American Board of Family Medicine: JABFM. Jul–Aug. 2011;24(4):422-8. [pmid: 21737767].
48 Allen RP, Ondo WG, Ball E, et al. Restless legs syndrome (RLS) augmentation associated with dopamine agonist and levodopa usage in a community sample. Sleep Medicine. May. 2011;12(5):431-9. [pmid: 21493132].
49 Benes H, Garcia-Borreguero D, Allen R, et al. Augmentation in long-term therapy of the restless legs syndrome with transdermal ritigotine-a retrospective systematic analysis of two large open-label 1 year trials. Movement Disorders. Suppl 1. 2009:S348.
50 Ellenbogen AL, Thein SG, Winslow DH, et al. A 52-week study of gabapentin enacarbil in restless legs syndrome. Clinical Neuropharmacology. Jan–Feb. 2011;34(1):8-16. [pmid: 21242741].
51 Ferini-Strambi L. Restless legs syndrome augmentation and pramipexole treatment. Sleep Medicine. Nov. Suppl. 2002;3:S23-5. [pmid: 14592163].
52 Frauscher B, Gschliesser V, Brandauer E, et al. The severity range of restless legs syndrome (RLS) and augmentation in a prospective patient cohort: association with ferritin levels. Sleep Medicine. Jun. 2009;10(6):611-5. [pmid: 19200780].
53 Garcia-Borreguero D, Grunstein R, Sridhar G, et al. A 52-week open-label study of the long-term safety of ropinirole in patients with restless legs syndrome. Sleep Medicine. Nov. 2007;8(7–8):742-52. [pmid: 17512789].
54 Godau J, Spinnler N, Wevers A-K, et al. Poor effect of guideline based treatment of restless legs syndrome in clinical practice. Journal of Neurology, Neurosurgery & Psychiatry. Dec. 2010;81(12):1390-5. [pmid: 20884674].
55 Hogl B, Garcia-Borreguero D, Kohnen R, et al. Progressive development of augmentation during long-term treatment with levodopa in restless legs syndrome: results of a prospective multi-center study. Journal of Neurology. Feb. 2010;257(2):230-7. [pmid: 19756826].
56 Inoue Y, Kuroda K, Hirata K, et al. Long-term open-label study of pramipexole in patients with primary restless legs syndrome. Journal of the Neurological Sciences. Jul. 15. 2010;294(1–2):62-6. [pmid: 20451927].
57 Montplaisir J, Fantini ML, Desautels A, et al. Long-term treatment with pramipexole in restless legs syndrome. European Journal of Neurology. Dec. 2006;13(12):1306-11. [pmid: 17116213].
58 Oertel W, Trenkwalder C, Benes H, et al. Long-term safety and efficacy of rotigotine transdermal patch for moderate-to-severe idiopathic restless legs syndrome: a 5-year open-label extension study. Lancet Neurology. Aug. 2011;10(8):710-20. [pmid: 21705273].
59 Ondo W, Romanyshyn J, Vuong KD, et al. Long-term treatment of restless legs syndrome with dopamine agonists. Archives of Neurology. Sep. 2004;61(9):1393-7. [pmid: 15364685].
60 Ondo WG, Lai D. Association between restless legs syndrome and essential tremor. Movement Disorders. Apr. 2006;21(4):515-8. [pmid: 16250022].
61 Silber MH, Girish M, Izurieta R. Pramipexole in the management of restless legs syndrome: an extended study. Sleep. Nov. 1. 2003;26(7):819-21. [pmid: 14655914].
62 Silver N, Allen RP, Senerth J, et al. A 10-year, longitudinal assessment of dopamine agonists and methadone in the treatment of restless legs syndrome. Sleep Medicine. May. 2011;12(5):440-4. [pmid: 21239226].
63 Trenkwalder C, Collado Seidel V, Kazenwadel J, et al. One-year treatment with standard and sustained-release levodopa: appropriate long-term treatment of restless legs syndrome?. Movement Disorders. Oct. 2003;18(10):1184-9. [pmid: 14534925].
64 Walters AS, Winkelmann J, Trenkwalder C, et al. Long-term follow-up on restless legs syndrome patients treated with opioids. Movement Disorders. Nov. 2001;16(6):1105-9. [pmid: 11748742].
65 Winkelman JW, Johnston L. Augmentation and tolerance with long-term pramipexole treatment of restless legs syndrome (RLS). Sleep Medicine. Jan. 2004;5(1):9-14. [pmid: 14725821].
66 Grote L, Leissner L, Hedner J, et al. A randomized, double-blind, placebo controlled, multi-center study of intravenous iron sucrose and placebo in the treatment of restless legs syndrome. Movement Disorders. Jul. 30. 2009;24(10):1445-52. [pmid: 19489063].
67 Wang J, O’Reilly B, Venkataraman R, et al. Efficacy of oral iron in patients with restless legs syndrome and a low-normal ferritin: A randomized, double-blind, placebo-controlled study. Sleep Medicine. Oct. 2009;10(9):973-5. [pmid: 19230757].
68 Woloshin S, Schwartz LM. Giving legs to restless legs: a case study of how the media helps make people sick. PLoS Medicine. 2006;3(4):e170. [pmid: 16597175].
69 Ekbom K. Restless legs syndrome. Neurology. Sep. 01. 1960;10:868-73. [pmid: 13726241].
70 Happe S, Reese JP, Stiasny-Kolster K, et al. Assessing health-related quality of life in patients with restless legs syndrome. Sleep medicine. Apr. 2009;10(3):295-305. [pmid: 18359664].
71 Kohnen R, Allen RP, Benes H, et al. Assessment of restless legs syndrome—Methodological approaches for use in practice and clinical trials. Movement disorders: official journal of the Movement Disorder Society. 2007;22(S18):S485-94. [pmid: 17534967].
72 Walters AS, LeBrocq C, Dhar A, et al. Validation of the International Restless Legs Syndrome Study Group rating scale for restless legs syndrome. Sleep medicine. Apr. 01. 2003;4(2):121-32. [pmid: 14592342].
73 Banerjee D. The Epworth Sleepiness Scale. Occupational Medicine. 2007;57:232.
74 Allen RP, Kosinski M, Hill-Zabala CE, et al. Psychometric evaluation and tests of validity of the Medical Outcomes Study 12-item Sleep Scale (MOS sleep). Sleep Medicine. May. 2009;10(5):531-9. [pmid: 18805054].
75 Buysse DJ, Reynolds CF 3rd, Monk TH, et al. The Pittsburgh Sleep Quality Index: a new instrument for psychiatric practice and research. Psychiatry Res. May. 1989;28(2):193-213. [pmid: 2748771].
76 García-Borreguero D, Kohnen R, Högl B, et al. Validation of the Augmentation Severity Rating Scale (ASRS): A multicentric, prospective study with levodopa on restless legs syndrome. Sleep medicine. Aug. 2007;8(5):455-63. [pmid: 17543579].
77 Hornyak M, Feige B, Riemann D, et al. Periodic leg movements in sleep and periodic limb movement disorder: Prevalence, clinical significance and treatment. Sleep medicine reviews. Jul. 2006;10(3):169-77. [pmid: 16762807].
78 García-Borreguero D, Stillman P, Benes H, et al. Algorithms for the diagnosis and treatment of restless legs syndrome in primary care. BMC neurology. 2011;11(1):28. [pmid: 21352569].
79 Liberati A, Altman DG, Tetzlaff J, et al. The PRISMA statement for reporting systematic reviews and meta-analyses of studies that evaluate health care interventions: explanation and elaboration. Journal of Clinical Epidemiology. Oct. 2009;62(10):e1-34. [pmid: 19631507].
80 Egger M, Davey Smith G, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. BMJ. Sep. 13. 1997;315(7109):629-34. [pmid: 9310563].
81 Hogl B, Garcia-Borreguero D, Sohr M, et al. Similar incidences of augmentation during 26 weeks of double-blind pramipexole treatment for restless legs syndrome in comparison to placebo. Neurology. 2009;72(11 (Suppl 3)):A106.
82 Kushida CA, Walters AS, Becker P, et al. A randomized, double-blind, placebo-controlled, crossover study of XP13512/GSK1838262 in the treatment of patients with primary restless legs syndrome. Sleep. Feb. 2009;32(2):159-68. [pmid: 19238802].
83 Allen RP, Bharmal M, Calloway M. Prevalence and disease burden of primary restless legs syndrome: results of a general population survey in the United States. Movement Disorders. Jan. 2011;26(1):114-20. [pmid: 21322022].
84 Scholz H, Trenkwalder C, Kohnen R, et al. Dopamine agonists for restless legs syndrome. Cochrane Database Syst Rev. 2011;(3):CD006009. [pmid: 21412893].
85 Zintzaras E, Kitsios GD, Papathanasiou AA, et al. Randomized trials of dopamine agonists in restless legs syndrome: a systematic review, quality assessment, and meta-analysis. Clin Ther. Feb. 2010;32(2):221-37. [pmid: 20206780].
86 Scholz H, Trenkwalder C, Kohnen R, Riemann D, Kriston L, Hornyak M. Levodopa for restless legs syndrome. Cochrane database of systematic reviews. 2011;(2):CD005504. [pmid: 21328278].
87 Allen RP, Earley CJ. Validation of the Johns Hopkins restless legs severity scale. Sleep medicine. Jun. 01. 2001;2(3):239-42. [pmid: 11311687].