# Methods

We conducted the comparative effectiveness review (CER) of treatments for restless legs syndrome (RLS) following the methods suggested in the Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews (www.effectivehealthcare.ahrq.gov/methodsguide.cfm). The main subsections in this section reflect the elements of the protocol publicly posted on the AHRQ Effective Health Care program Web site, and they correspond to the PRISMA checklist.79 The methods and analyses were determined a priori.

## Topic Refinement and Review Protocol

The topic for this CER was nominated by a public process available through the Effective Health Care Web site. Investigators developed preliminary Key Questions with input from various stakeholder groups representing patients, providers, and content experts. The Key Questions were posted on AHRQ’s Web site for public comments for 4 weeks from August 2, 2011 to August 30, 2011. Public comments and input from the Technical Expert Panel (TEP), convened to provide methodological and content expertise, aided the development of the final and protocol.

## Literature Search Strategy

We searched the bibliographic databases MEDLINE (via OVID), Embase, and Natural Standards through June 2012 for randomized controlled trials (RCTs) evaluating treatment efficacy and for observational studies (including open-label extensions of RCTs) reporting adverse effects and long-term adherence to RLS treatments. The search algorithm, developed with input from a biomedical librarian and independently reviewed by another librarian, consisted of a combination of search strings that described the condition and search filters designed to retrieve relevant RCTs and observational studies (Appendix A). To identify completed trials and to check for publication bias, we searched Cochrane Central, the International Controlled Trials Registry Platform (ICTRP), Clinicaltrials.gov, FDA Web sites, and the NIH RePORTer. We included other eligible unidentified trials referred by peer reviewers.

### Inclusion and Exclusion Criteria

For treatment efficacy, we included studies if they were RCTs that enrolled individuals with RLS as defined by the International Restless Legs Syndrome Study Group in 1995^1^ and revised in 2003.^2^ Eligible trials must have been published in English, evaluated pharmacologic and/or nonpharmacologic interventions for RLS, lasted at least 4 weeks, and reported validated RLS symptom or quality of life scale scores, clinician and patient global impact scale scores, or measures of sleep quality.

We included observational studies and open-label followup extensions of RCTs reporting long-term (>6 months) adverse effects and adherence. Pharmacologic interventions were limited to drugs approved for use (for any condition) in the United States. Specific eligibility criteria are listed in Table 3.

Table 3 Inclusion criteria

Domain | Criteria for Inclusion
Population | - Individuals diagnosed with RLS using RLS diagnostic criteria
Intervention | - Pharmacological and nonpharmacological treatments for RLS
Comparison | - Placebo (or sham treatment), no treatment, or other active comparator
Outcomes | - Change in RLS symptom severity and impact using reported, validated RLS symptom or quality of life scale scores, clinician and patient global impressions scale scores, or measures of sleep quality.
Setting | - Outpatient settings
Timing | - For RCTs reporting efficacy outcomes, at least 4 weeks; - For observational studies reporting adverse events, from 6 months to decades
Study design | - RCTs and observational studies reporting adverse events; open-label followup studies for RCTs
Publication dates | - Through June 2012
Language | - English

RCT = randomized controlled trial; RLS = restless legs syndrome

## Study Selection

Bibliographic database search results were downloaded to an Endnote™ reference management system. We identified eligible studies in two stages. In the first stage, two investigators independently reviewed titles and abstracts of all references. Studies deemed eligible for inclusion by either investigator were further evaluated. In the second stage, two investigators independently reviewed full text to determine if studies met inclusion criteria. Differences in full-text screening decisions were resolved by discussion or, when necessary, by consultation with a third investigator. Eligibility status and at least one exclusion reason were documented for all studies evaluated at the full-text screening stage. For randomized controlled trials, reasons for exclusion were coded as: non-English language study; not a relevant study design; no relevant intervention or comparator; no relevant outcome; and trial duration <4 weeks. The excluded articles and the reason for exclusion are listed in Appendix B.

## Data Extraction

Data from included studies were abstracted directly into evidence tables by one reviewer and validated by a second reviewer. Disagreements were resolved by consensus or, when needed, by consultation with a third reviewer. We abstracted data on the following:

- Study characteristics including design (e.g. parallel or crossover, long-term extension studies), eligibility criteria, duration, setting, funding source, blinding, intention-to-treat analysis, reporting of dropouts/attrition
- Patient characteristics including age, race, sex, comorbidities, RLS diagnostic criteria, previous RLS medication history, duration of RLS (time since diagnosis), baseline RLS symptom severity and frequency, iron, pregnancy, and end-stage renal disease status
- Intervention/comparator characteristics including type, dosage, titration, and washout period (for crossover trials)
- Outcomes, including International Restless Legs Syndrome (IRLS) responders defined as “patients with ≥50 percent reduction in IRLS scale score” (our primary outcome), mean change in IRLS scale score from baseline, percentage of patients with complete remission, percentage of patients reporting “much improved” or “very much improved” on clinician-assessed global impressions (CGI) or patient-assessed global impressions (PGI) scales, RLS quality of life, patient-reported sleep quality, number of individuals experiencing adverse effects, dropouts, dropouts due to adverse effects, treatment discontinuation due to adverse effects, specific adverse effects, and augmentation

## Risk of Bias of Individual Studies

We assessed risk of bias of RCTs using the Cochrane risk of bias tool.11 We addressed: (1) allocation concealment, (2) blinding methods (participant, investigator, and/or outcome assessor), (3) how incomplete data were addressed, (4) intention-to-treat principle, and (5) whether reasons for dropouts/attrition were reported. We rated studies as good, fair, or poor quality. A rating of good (having good internal validity or low risk of bias) generally indicated that the trial reported adequate allocation concealment, used some blinding methods, analyzed by intent-to-treat, and reported reasons for dropouts/attrition. We then used study quality for the individual RCTs to determine the overall risk of bias to assess strength of evidence for each particular outcome.

## Data Synthesis

For trials that included similar populations, interventions, and outcomes and that presented sufficient data, we calculated pooled random-effects estimates of overall effect size, weighted mean differences (WMDs), or risk ratios (RRs). We used Review Manager 5.1 to pool and analyze the data.12 We calculated risk ratios (RR) for dichotomous outcomes and WMD or standardized mean differences (SMDs) for continuous outcomes using a random-effects model. We assessed statistical heterogeneity between trials and for subgroups of drugs using the I^2^ test and observation of the direction of the effect of the studies. A score of approximately 50 percent and if the effect sizes do not fall on the same side of “no effect” suggests substantial heterogeneity. For the fixed-dose trials, we analyzed only the doses recommended for current clinical practice if possible. Publication bias was assessed through inspection of funnel plots and the Egger intercept test.80

## Strength of the Body of Evidence

We evaluated the overall strength of evidence using methods developed by the Agency for Healthcare Research and Quality and the Effective Health Care Program13 for the following outcomes: mean change in IRLS scale score from baseline; percent of IRLS responders, i.e., patients with ≥50 percent reduction in IRLS scale score; percent of patients reporting “much improved” or “very much improved” on CGI or PGI; quality of life; patient-reported sleep quality; number of individuals experiencing adverse effects, and dropouts due to adverse effects. We evaluated strength of the evidence on four required domains:

1. Risk of bias. Low, medium, or high
2. Consistency. Consistent, inconsistent, or unknown/not applicable (e.g., only one study for the respected outcome evaluated)
3. Directness. Direct or indirect
4. Precision, based on the confidence intervals surrounding an effect estimate. The confidence intervals for an imprecise estimate would be wide enough to include clinically distinct conclusions.

We evaluated individual domains qualitatively and assigned a summary rating of high, moderate, or low strength of evidence. An overall rating of high strength of evidence would imply that the included studies were RCTs with a low risk of bias, with consistent, direct, and precise domains.

Generally for outcomes with multiple studies, evidence was downgraded to moderate strength of evidence if there was either medium/high risk of bias (low quality RCTs), imprecision, indirectness, or inconsistency and low if two or more of the domains were deemed inadequate. Outcomes with only a single trial were usually rated moderate if there was a low risk of bias, and had direct and precise domains.

## Applicability

We assessed applicability separately from strength of evidence based on the following criteria: eligibility requirements used to select patient populations; characteristics of population enrolled such as demographics, baseline RLS severity, duration and etiology (primary or secondary) of RLS, history of previous therapy, and the length of followup.14 We qualitatively compared this to population-based studies that assessed the demographic characteristics and severity and frequency of individuals with RLS.