# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project:

## Technical Expert Panel

Philip M. Becker, M.D.

Clinical Professor, Department of Psychiatry

University of Texas Southwestern Medical Center

Medical Director, Sleep Medicine Institute

Texas Health Presbyterian Hospital

Dallas, TX

Georgianna Bell

Executive Director

Restless Legs Syndrome Foundation

Rochester, MN

Norma G. Cuellar, D.S.N., R.N.

Professor of Nursing

University of Alabama

Birmingham, AL

Erik R. Ensrud, M.D.

Department of Neurology

Brigham and Women’s Hospital

Boston, MA

Linda Humphrey, M.D., M.P.H.

Department of Internal Medicine

Portland VA Medical Center

Portland, OR

James Pacala, M.D., M.S.

Associate Professor and Associate

Department Head

Family Medicine and Community Health

University of Minnesota

Minneapolis, MN

Robert L. Rich, M.D.

Family Medicine

Bladen Medical Associates

Elizabethtown, NC

Michael H. Silber, M.B., Ch.B.

Professor of Neurology

Mayo Clinic

Rochester, MN

## Peer Reviewers

Philip M. Becker, M.D.

Clinical Professor, Department of Psychiatry

University of Texas Southwestern Medical Center

Medical Director, Sleep Medicine Institute

Texas Health Presbyterian Hospital

Dallas, TX

Georgianna Bell

Executive Director

Restless Legs Syndrome Foundation

Rochester, MN

Norma G. Cuellar, D.S.N., R.N.

Professor of Nursing

University of Alabama

Birmingham, AL

Linda Humphrey, M.D., M.P.H.

Department of Internal Medicine

Portland VA Medical Center

Portland, OR

William G. Ondo, M.D.

Professor of Neurology

University of Texas

Houston, TX

Robert L. Rich, M.D.

Family Medicine

Bladen Medical Associates

Elizabethtown, NC

Michael H. Silber, M.B., Ch.B.

Professor of Neurology

Mayo Clinic

Rochester, MN