# Appendix References

1 Bassetti CL, Bornatico F, Fuhr P, et al. Pramipexole versus dual release levodopa in restless legs syndrome: a double blind, randomised, cross-over trial. Swiss Medical Weekly. 2011;141:w13274. [pmid: 22101745].
2 Benes H, Mattern W, Peglau I, et al. Ropinirole improves depressive symptoms and restless legs syndrome severity in RLS patients: a multicentre, randomized, placebo-controlled study. Journal of Neurology. Jun. 2011;258(6):1046-54. [pmid: 21188406].
3 Hogl B, Garcia-Borreguero D, Trenkwalder C, et al. Efficacy and augmentation during 6 months of double-blind pramipexole for restless legs syndrome. Sleep Medicine. Apr. 2011;12(4):351-60. [pmid: 21354368].
4 Montagna P, Hornyak M, Ulfberg J, et al. Randomized trial of pramipexole for patients with restless legs syndrome (RLS) and RLS-related impairment of mood. Sleep Medicine. Jan. 2011;12(1):34-40. [pmid: 20965780].
5 Hening WA, Allen RP, Ondo WG, et al. Rotigotine improves restless legs syndrome: a 6-month randomized, double-blind, placebo-controlled trial in the United States. Movement Disorders. Aug. 15. 2010;25(11):1675-83. [pmid: 20629075].
6 Oertel W, Trenkwalder C, Benes H, et al. Long-term safety and efficacy of rotigotine transdermal patch for moderate-to-severe idiopathic restless legs syndrome: a 5-year open-label extension study. Lancet Neurology. Aug. 2011;10(8):710-20. [pmid: 21705273].
7 Ferini-Strambi L, Aarskog D, Partinen M, et al. Effect of pramipexole on RLS symptoms and sleep: a randomized, double-blind, placebo-controlled trial. Sleep Medicine. Dec. 2008;9(8):874-81. [pmid: 18952497].
8 Kushida CA, Geyer J, Tolson JM, et al. Patient- and physician-rated measures demonstrate the effectiveness of ropinirole in the treatment of restless legs syndrome. Clinical Neuropharmacology. Sep–Oct. 2008;31(5):281-6. [pmid: 18836346].
9 Oertel WH, Benes H, Garcia-Borreguero D, et al. Efficacy of rotigotine transdermal system in severe restless legs syndrome: a randomized, double-blind, placebo-controlled, six-week dose-finding trial in Europe. Sleep Medicine. Mar. 2008;9(3):228-39. [pmid: 17553743].
10 Trenkwalder C, Benes H, Poewe W, et al. Efficacy of rotigotine for treatment of moderate-to-severe restless legs syndrome: a randomised, double-blind, placebo-controlled trial. Lancet Neurology. Jul. 2008;7(7):595-604. [pmid: 18515185].
11 Oertel WH, Stiasny-Kolster K, Bergtholdt B, et al. Efficacy of pramipexole in restless legs syndrome: a six-week, multicenter, randomized, double-blind study (effect-RLS study). Movement Disorders. Jan. 15. 2007;22(2):213-9. [pmid: 17133582].
12 Adler CH, Hauser RA, Sethi K, et al. Ropinirole for restless legs syndrome: a placebo-controlled crossover trial. Neurology. Apr. 27. 2004;62(8):1405-7. [pmid: 15111683].
13 Bogan RK, Fry JM, Schmidt MH, et al. Ropinirole in the treatment of patients with restless legs syndrome: a US-based randomized, double-blind, placebo-controlled clinical trial. Mayo Clinic Proceedings. Jan. 2006;81(1):17-27. [pmid: 16438474].
14 Montplaisir J, Karrasch J, Haan J, et al. Ropinirole is effective in the long-term management of restless legs syndrome: a randomized controlled trial. Movement Disorders. Oct. 2006;21(10):1627-35. [pmid: 16874755].
15 Winkelman JW, Sethi KD, Kushida CA, et al. Efficacy and safety of pramipexole in restless legs syndrome. Neurology. Sep. 26. 2006;67(6):1034-9. [pmid: 16931507].
16 Trenkwalder C, Garcia-Borreguero D, Montagna P, et al. Ropinirole in the treatment of restless legs syndrome: results from the TREAT RLS 1 study, a 12 week, randomised, placebo controlled study in 10 European countries. Journal of Neurology, Neurosurgery & Psychiatry. Jan. 2004;75(1):92-7. [pmid: 14707315].
17 Walters AS, Ondo WG, Dreykluft T, et al. Ropinirole is effective in the treatment of restless legs syndrome. TREAT RLS 2: a 12-week, double-blind, randomized, parallel-group, placebo-controlled study. Movement Disorders. Dec. 2004;19(12):1414-23. [pmid: 15390050].
18 Lee DO, Ziman RB, Perkins AT, et al. A randomized, double-blind, placebo-controlled study to assess the efficacy and tolerability of gabapentin enacarbil in subjects with restless legs syndrome. Journal of Clinical Sleep Medicine. Jun. 15. 2011;7(3):282-92. [pmid: 21677899].
19 Winkelman JW, Bogan RK, Schmidt MH, et al. Randomized polysomnography study of gabapentin enacarbil in subjects with restless legs syndrome. Movement Disorders. Sep. 2011;26(11):2065-72. [pmid: 21611981].
20 Allen R, Chen C, Soaita A, et al. A randomized, double-blind, 6-week, dose-ranging study of pregabalin in patients with restless legs syndrome. Sleep Medicine. Jun. 2010;11(6):512-9. [pmid: 20466589].
21 Bogan RK, Bornemann MAC, Kushida CA, et al. Long-term maintenance treatment of restless legs syndrome with gabapentin enacarbil: a randomized controlled study. [Erratum appears in Mayo Clin Proc. 2010 Jul;85(7):693–4]. Mayo Clinic Proceedings. Jun. 2010;85(6):512-21. [pmid: 20511481].
22 Garcia-Borreguero D, Larrosa O, Williams AM, et al. Treatment of restless legs syndrome with pregabalin: a double-blind, placebo-controlled study. Neurology. Jun. 8. 2010;74(23):1897-904. [pmid: 20427750].
23 Kushida CA, Becker PM, Ellenbogen AL, et al. Randomized, double-blind, placebo-controlled study of XP13512/GSK1838262 in patients with RLS. Neurology. Feb. 3. 2009;72(5):439-46. [pmid: 19188575].
24 Garcia-Borreguero D, Larrosa O, de la Llave Y, et al. Treatment of restless legs syndrome with gabapentin: a double-blind, cross-over study. Neurology. Nov. 26. 2002;59(10):1573-9. [pmid: 12451200].
25 Bayard M, Bailey B, Acharya D, et al. Bupropion and restless legs syndrome: a randomized controlled trial. Journal of the American Board of Family Medicine: JABFM. Jul–Aug. 2011;24(4):422-8. [pmid: 21737767].
26 Allen RP, Adler CH, Du W, et al. Clinical efficacy and safety of IV ferric carboxymaltose (FCM) treatment of RLS: a multi-centred, placebo-controlled preliminary clinical trial. Sleep Medicine. Oct. 2011;12(9):906-13. [pmid: 21978726].
27 Trenkwalder C, Benes H, Grote L, et al. Cabergoline compared to levodopa in the treatment of patients with severe restless legs syndrome: results from a multi-center, randomized, active controlled trial. Movement Disorders. Apr. 15. 2007;22(5):696-703. [pmid: 17274039].
28 Oertel WH, Benes H, Bodenschatz R, et al. Efficacy of cabergoline in restless legs syndrome: a placebo-controlled study with polysomnography (CATOR). Neurology. Sep. 26. 2006;67(6):1040-6. [pmid: 16931508].
29 Stiasny-Kolster K, Benes H, Peglau I, et al. Effective cabergoline treatment in idiopathic restless legs syndrome. [Summary for patients in Neurology. 2004 Dec 28;63(12):E21–2. PMID: 15623673]. Neurology. Dec. 28. 2004;63(12):2272-9. [pmid: 15623686].
30 Grote L, Leissner L, Hedner J, et al. A randomized, double-blind, placebo controlled, multi-center study of intravenous iron sucrose and placebo in the treatment of restless legs syndrome. Movement Disorders. Jul. 30. 2009;24(10):1445-52. [pmid: 19489063].
31 Wang J, O'Reilly B, Venkataraman R, et al. Efficacy of oral iron in patients with restless legs syndrome and a low-normal ferritin: A randomized, double-blind, placebo-controlled study. Sleep Medicine. Oct. 2009;10(9):973-5. [pmid: 19230757].
32 Cuellar NG, Ratcliffe SJ. Does valerian improve sleepiness and symptom severity in people with restless legs syndrome?. Alternative Therapies in Health & Medicine. Mar–Apr. 2009;15(2):22-8. [pmid: 19284179].
33 Lettieri CJ, Eliasson AH. Pneumatic compression devices are an effective therapy for restless legs syndrome: a prospective, randomized, double-blinded, sham-controlled trial. Chest. Jan. 2009;135(1):74-80. [pmid: 19017878].
34 Aukerman MM, Aukerman D, Bayard M, et al. Exercise and restless legs syndrome: a randomized controlled trial. Journal of the American Board of Family Medicine: JABFM. Sep–Oct. 2006;19(5):487-93. [pmid: 16951298].
35 Oertel WH, Benes H, Garcia-Borreguero D, et al. Rotigotine transdermal patch in moderate to severe idiopathic restless legs syndrome: a randomized, placebo-controlled polysomnographic study. Sleep Medicine. Oct. 2010;11(9):848-56. [pmid: 20813583].
36 Mitchell UH, Myrer JW, Johnson AW, et al. Restless legs syndrome and near-infrared light: An alternative treatment option. Physiotherapy Theory & Practice. Jul. 2011;27(5):345-51. [pmid: 20977377].
37 Cuellar NG, Strumpf NE, Ratcliffe SJ. Symptoms of restless legs syndrome in older adults: outcomes on sleep quality, sleepiness, fatigue, depression, and quality of life. Journal of the American Geriatrics Society. Sep. 2007;55(9):1387-92. [pmid: 17915343].
38 Allen RP, Bharmal M, Calloway M. Prevalence and disease burden of primary restless legs syndrome: results of a general population survey in the United States. Movement Disorders. Jan. 2011;26(1):114-20. [pmid: 21322022].
39 Ellenbogen AL, Thein SG, Winslow DH, et al. A 52-week study of gabapentin enacarbil in restless legs syndrome. Clinical Neuropharmacology. Jan–Feb. 2011;34(1):8-16. [pmid: 21242741].
40 Walters AS, Winkelmann J, Trenkwalder C, et al. Long-term follow-up on restless legs syndrome patients treated with opioids. Movement Disorders. Nov. 2001;16(6):1105-9. [pmid: 11748742].
41 Silver N, Allen RP, Senerth J, et al. A 10-year, longitudinal assessment of dopamine agonists and methadone in the treatment of restless legs syndrome. Sleep Medicine. May. 2011;12(5):440-4. [pmid: 21239226].
42 Trenkwalder C, Collado Seidel V, Kazenwadel J, et al. One-year treatment with standard and sustained-release levodopa: appropriate long-term treatment of restless legs syndrome?. Movement Disorders. Oct. 2003;18(10):1184-9. [pmid: 14534925].
43 Inoue Y, Kuroda K, Hirata K, et al. Long-term open-label study of pramipexole in patients with primary restless legs syndrome. Journal of the Neurological Sciences. Jul. 15. 2010;294(1–2):62-6. [pmid: 20451927].
44 Silber MH, Girish M, Izurieta R. Pramipexole in the management of restless legs syndrome: an extended study. Sleep. Nov. 1. 2003;26(7):819-21. [pmid: 14655914].
45 Montplaisir J, Fantini ML, Desautels A, et al. Long-term treatment with pramipexole in restless legs syndrome. European Journal of Neurology. Dec. 2006;13(12):1306-11. [pmid: 17116213].
46 Garcia-Borreguero D, Grunstein R, Sridhar G, et al. A 52-week open-label study of the long-term safety of ropinirole in patients with restless legs syndrome. Sleep Medicine. Nov. 2007;8(7–8):742-52. [pmid: 17512789].
47 Ondo W, Romanyshyn J, Vuong KD, et al. Long-term treatment of restless legs syndrome with dopamine agonists. Archives of Neurology. Sep. 2004;61(9):1393-7. [pmid: 15364685].