# Withdrawals and Adverse Events Tables

Appendix G. Table 1 Withdrawals and adverse effects for the dopamine agonist trials Part A

Study | Any study withdrawals n/N (%) | | Withdrawals due to adverse effects n/N (%) | | Patients with ≥ 1 adverse event n/N (%) | | Patients with ≥ 1 severe adverse effects n/N (%) | | Patients with ≥ 1 serious adverse effects n/N (%)
Study | Treatment | Placebo | Treatment | Placebo | Treatment | Placebo | Treatment | Placebo | Treatment | Placebo
Pramipexole
Bassetti 2011^1^ | 28/67^*^ (41.8) | | | | 38/67 (56.7) | 39/67^**^ (58.2)
Ferini-Stamb, 2008^7^ | 27/182 (14.8) | 52/187 (27.8) | 17/182 (9.3) | 16/187 (8.6) | 106/182 (58.2) | 86/187 (46.0) | 47/182 (25.8) | 49/187 (26.2)
Högl, 2011^3^ | 35/166 (21.1) | 60/163 (36.8) | 19/166 (11.4) | 23/163 (14.1) | 120/166 (72.3) | 106/163 (65.0) | 17/166 (10.2) | 15/163 (9.2) | 8/166 (4.8) | 3/163 (1.8)
Montagna, 2011^4^ | 26/203 (12.8) | 41/201 (20.4) | 9/203 (4.4) | 11/201 (5.5) | 124/203 (61.1) | 103/200 (51.5) | 8/203 (3.9) | 6/200 (3.0)
Oertel, 2007^11^ | 12/230 (5.2) | 8/115 (7.0) | 6/230 (2.6) | 5/115 (4.3) | 150/230 (65.2) | 55/115 (47.8) | 8/230 (3.5) | 9/115 (7.8) | 0/230 (0) | 2/115 (1.7)
Winkelman, 2006^15^ | 53/259 (20.5) | 11/86 (12.8) | 32/258 (12.4) | 6/86 (7.0) | 209/258 (81.0) | 69/86 (80.2) | 45/258 (17.4) | 11/86 (12.8)
Ropinirole
Adler, 2004^12^ | 2/22 (9.1) | 1/22 (4.5) | 1/22 (4.5) | 1/22 (4.5)
Benes, 2011^2^ | 54/199 (27.1) | 29/67 (43.3) | 31/199 (15.6) | 6/67 (9.0) | 123/199 (61.8) | 26/67 (38.8) | 37/197 (18.8) | 3/67 (4.5) | 6/197 (3.0) | 0/67 (0)
Bogan, 2006^13^ | 23/187 (12.3) | 26/194 (13.4) | 7/187 (3.7) | 9/194 (4.6) | 155/187 (82.9) | 129/193 (66.8) | 33/187 (17.6) | 20/193 (10.4) | 0/187 (0) | 1/193 (0.5)
Kushida, 2008^8^ | 25/176 (14.2) | 27/186 (14.5) | 8/176 (4.5) | 6/186 (3.2) | 138/176 (78.4) | 119/186 (64.0) | | | 2/176 (1.1) | 3/186 (1.6)
Montplaisir, 2006^14^ | 15/45 (33.3) | 28/47 (59.6) | 1/45 (2.2) | 0/47 (0) | 26/45 (57.8) | 24/47 (51.1) | 6/45 (13.3) | 6/47 (12.8) | 0/45 (0) | 2/47 (4.3)
Trenkwalder, 2004^16^ | 35/147 (23.8) | 30/139 (21.6) | 16/147 (10.9) | 6/139 (4.3) | 120/146 (82.2) | 103/138 (74.6) | 34/146 (23.3) | 21/138 (15.2) | 3/146 (2.1) | 4/138 (2.9)
Walters, 2004^17^ | 29/131 (22.1) | 29/136 (21.3) | 11/131 (8.4) | 9/136 (6.6) | 112/131 (85.5) | 102/136 (75.0) | 32/131 (24.4) | 24/136 (17.6) | 2/131 (1.5) | 5/136 (3.7)
Rotigotine
Hening, 2010^5^ | 152/404 (37.6) | 33/100 (33.0) | 82/404 (20.3) | 4/100 (4.0) | 355/404 (87.9) | 84/100 (84.0) | 79/404 (19.6) | 12/100 (12.0) | 17/404 (4.2) | 4/100 (4.0)
Oertel, 2010^35^ | 5/46 (10.9) | 1/21 (4.8) | 2/46 (4.3) | 1/21 (4.8) | 34/46 (73.9) | 12/21 (57.1) | 1/46 (2.2) | 1/21 (4.8)
Oertel, 2008^9^ | 23/286 (8.0) | 8/55 (14.5) | 13/286 (4.5) | 2/55 (3.6) | 177/285 (62.1) | 25/55 (45.5) | | | 4/285 (1.4) | 1/55 (1.8)
Trenkwalder, 2008^10^ | 96/341 (28.2) | 49/117 (41.9) | 54/341 (15.8) | 8/117 (6.8) | 265/341 (77.7) | 64/117 (54.7) | 50/341 (14.7) | 9/117 (7.7) | 25/341 (7.3) | 5/117 (4.3)

* All subjects, crossover trial

** Versus levodopa/benserazide

Appendix G. Table 2 Adverse effects for the dopamine agonist trials Part B

Study | Fatigue n/N (%) | | Nausea n/N (%) | | Vomiting n/N (%) | | Headache n/N (%) | | Somnolence n/N (%)
Study | Treatment | Placebo | Treatment | Placebo | Treatment | Placebo | Treatment | Placebo | Treatment | Placebo
Pramipexole
Bassetti 2011^1^ | | | 31%^*^ | 17%^*^ | 8%^*^ | 3%^*^ | 17%^*^ | 11%^*^
Ferini-Stamb, 2008^7^ | 16/182 (8.8) | 4/187 (2.1) | 32/182 (17.6) | 11/187 (5.9) | | | 27/182 (14.8) | 24/187 (12.8)
Högl, 2011^3^ | 18/166 (10.8) | 15/163 (9.2) | 24/166 (14.5) | 6/163 (3.7) | | | 13/166 (7.8) | 17/163 (10.4) | 11/166 (6.6) | 8/163 (4.9)
Montagna, 2011^4^ | 16/203 (7.9) | 8/200 (4.0) | 28/203 (13.8) | 13/200 (6.5) | | | 21/203 (10.3) | 19/200 (9.5)
Oertel, 2007^11^ | 21/230 (9.1) | 7/115 (6.1) | 28/230 (12.2) | 7/115 (6.1) | | | 30/230 (13.0) | 11/115 (9.6)
Winkelman, 2006^15^ | 13/258 (5.0) | 4/86 (4.7) | 49/258 (19.0) | 4/86 (4.7) | | | 46/258 (17.8) | 15/86 (17.4) | 26/258 (10.1) | 4/86 (4.7)
Ropinirole
Adler, 2004^12^ | | | 6/22 (27.3) | 1/22 (4.5) | 3/22 (13.6) | 0/22 (0) | 2/22 (9.1) | 2/22 (9.1) | 3/22 (13.6) | 0/22 (0)
Benes, 2011^2^ | 25/197 (12.7) | 4/67 (6.0) | 64/197 (32.5) | 5/67 (7.5) | 14/197 (7.1) | 0/67 (0) | 38/197 (19.8) | 9/67 (13.4)
Bogan, 2006^13^ | | | 80/187 (42.8) | 15/193 (7.8) | 16/187 (8.6) | 3/193 (1.6) | 31/187 (16.6) | 36/193 (18.7) | 24/187 (12.8) | 13/193 (6.7)
Kushida, 2008^8^ | | | 59/176 (33.5) | 28/186 (15.1) | 18/176 (10.2) | 6/186 (3.2) | 42/176 (23.9) | 33/186 (17.7) | 34/176 (19.3) | 11/186 (5.9)
Montplaisir, 2006^14^ | 38/202^**^ (18.8) | | 8/45 (17.8); 101/202^**^ (50.0) | 1/47 (2.1) | 31/202^*^ (15.3) | | 5/45 (11.1); 44/202^**^ (21.8) | 3/47 (6.4)
Trenkwalder, 2004^16^ | | | 55/146 (37.7) | 9/138 (6.5) | 19/146 (13.0) | 2/138 (1.4) | 29/146 (19.9) | 23/138 (16.7) | 18/146 (12.3) | 10/138 (7.2)
Walters, 2004^17^ | 80/131 (61.1) | 9/136 (6.6) | 52/131 (39.7) | 11/136 (8.1) | 16/131 (12.2) | 3/136 (2.2) | 29/131 (22.1) | 35/136 (25.7)
Rotigotine
Hening, 2010^5^ | 27/404 (6.7) | 4/100 (4.0) | 73/404 (18.1) | 10/100 (10.0) | | | 47/404 (11.6) | 8/100 (8.0) | 47/404 (11.6) | 6/100 (6.0)
Oertel, 2010^35^ | | | 10/46 (21.7) | 1/21 (4.8) | | | 8/46 (17.4) | 3/21 (14.3) | 5/46 (10.9) | 2/21 (9.5)
Oertel, 2008^9^ | 19/285 (6.7) | 5/55 (9.1) | 41/285 (14.4) | 5/55 (9.1) | 11/285 (3.9) | 1/55 (1.8) | 22/285 (7.7) | 4/55 (7.3)
Trenkwalder, 2008^10^ | 37/341 (10.9) | 11/117 (9.4) | 55/341 (16.1) | 4/117 (3.4) | | | 43/341 (12.6) | 8/117 (6.8)

* Crossover trial versus levodopa/benserazide, numbers unclear;

** Single-blind phase, all subjects received ropinirole.

Appendix G. Table 3 Specific adverse effects for the dopamine agonist trials Part C

Study | Application site reactions n/N (%) | | Dizziness n/N (%) | | Augmentation n/N (%) | | Augmentation leading to study withdrawal n/N (%) | | Withdrawal due to insufficient effect n/N (%)
Study | Treatment | Placebo | Treatment | Placebo | Treatment | Placebo | Treatment | Placebo | Treatment | Placebo
Pramipexole
Bassetti, 2011^1^ | | | 13%^*^ | 17%^*^ | 5 events^*^ | 15 events^*^
Ferini-Stamb, 2008^7^ | | | | | | | | | 5/182 (2.7) | 33/187 (17.6)
Högl, 2011^3^ | | | | | 18/152^**^ (11.8) | 14/149^**^ (9.4)
Montagna, 2011^4^ | | | | | | | | | 7/203 (3.4) | 20/201 (10.0)
Oertel, 2007^11^ | | | 8/230 (3.5) | 4/115 (3.5)
Winkelman, 2006^15^ | | | 25/258 (9.7) | 6/86 (7.0) | | | 1/259^†^ (0.4) | 1/86^†^ (1.2)
Ropinirole
Adler, 2004^12^ | | | 5/22 (22.7) | 0/22 (0) | | | | | 1/22 (4.5) | 0/22 (0)
Benes, 2011^2^ | | | 17/197 (8.6) | 2/67 (3.0)
Bogan, 2006^13^ | | | 18/187 (9.6) | 11/193 (5.7) | 3/187 (1.6) | 1/193 (0.5) | | | 2/187 (1.1) | 5/193 (2.6)
Kushida, 2008^8^
Montplaisir, 2006^14^ | | | 36/202^††^ (17.8) | | | | | | 12/45 (26.7) | 20/47 (42.6)
Trenkwalder, 2004^16^ | | | | | | | | | 4/147 (2.7) | 11/139 (7.9)
Walters, 2004^17^ | | | 20/131 (15.3) | 6/136 (4.4) | | | | | 2/131 (1.5) | 6/136 (4.4)
Rotigotine
Hening, 2010^5^ | 109/404 (27.0) | 5/100 (5.0) | 21/404 (5.2) | 6/100 (6.0) | | | | | 19/405 (4.7) | 8/100 (8.0)
Oertel, 2010^35^ | 8/46 (17.4) | 1/21 (4.8) | | | | | | | 1/46 (2.2) | 0/21 (0)
Oertel, 2008^9^ | 50/285 (17.5) | 1/55 (1.8) | 12/285 (4.2) | 4/55 (7.3) | | | | | 3/286 (1.0) | 2/55 (3.6)
Trenkwalder, 2008^10^ | 145/341 (42.5) | 2/117 (1.7) | 18/341 (5.3) | 3/117 (2.6) | ASRS^§^ | 0.30 (0.44)^‡^ | | | 22/341 (6.5) | 37/117 (31.6)

* Crossover trial versus levodopa/benserazide, numbers unclear.

** Classified as augmentation cases. Among the 18 pramipexole cases, 14 augmentation and 4 insufficient data for definitive conformation. Among 14 placebo cases, 9 confirmed augmentation; 5 insufficient data for definitive conformation.

† Defined as “worsened RLS.”

†† Single-blind phase, all subjects received ropinirole.

§ ASRS=Augmentation Severity Rating Scale.

1mg=0.31 (0.46), 2mg=0.24 (0.41), 3mg=0.25 (0·42)^‡^.

‡ Mean (SD).

Appendix G. Table 4 Withdrawals and adverse effects for the alpha-2-delta ligands trials Part A

Study | Any study withdrawals n/N (%) | | Withdrawals due to adverse effects n/N (%) | | Patients with ≥ 1 adverse event n/N (%) | | Patients with ≥ 1 severe adverse effects n/N (%) | | Patients with ≥ 1 serious adverse effects n/N (%)
Study | Treatment | Placebo | Treatment | Placebo | Treatment | Placebo | Treatment | Placebo | Treatment | Placebo
Gabapentin enacarbil
Lee, 2011^18^ | 26/228 (11.4) | 20/97 (20.6) | 15/228 (6.6) | 6/97 (6.2) | | | | | 2/226 (0.9) | 1/96 (1.0)
Winkelman 2011^19,*^ | 22 of 136 patients (16.2%) did complete trial (both phases, GEn=8, placebo=11, and 3 during the washout period) | | 8 of 136 patients (5.9%) (both phases) | | 86/127 (67.7) | 70/132 (53.0)
Bogan, 2010^21,**^ | 12/96 (12.5) | 14/98 (14.3) | 0/96 (0) | 3/98 (3.1) | 49/96 (51.0) | 45/98 (45.9) | 2/96 (2.1) | 5/98 (5.1) | 1/96 (1.0) | 2/98 (2.0)
Kushida, 2009^23^ | 14/114 (12.3) | 16/108 (14.8) | 10/114 (8.8) | 3/108 (2.8) | 93/113 (82.3) | 80/108 (74.1)
Gabapentin
Garcia-Borreguero, 2002^24,*^ | All patients^**^ 3/24 (12.5), 1 during GABA phase and 2 during placebo phase | | All patients^**^ 1/24 (4.2) during placebo phase
Pregabalin
Allen, 2010^20^ | 14/114 (12.3) | 2/23 (8.7) | 10/114 (8.8) | 1/23 (4.3) | 73/114 (64.0) | 13/23 (56.5) | 11 patients total^†^ | | 1/114 (<1) | 0/23
Garcia-Borreguero, 2010^22^ | 6/30 (20.0) | 9/28 (32.1) | 4/30 (13.3) | 0/28 | 25/30 (83.3) | 9/28 (32.1)

* Crossover trial;

** Double-blind phase. All subjects had active treatment in a 24-week single-blind phase and were then randomized to either gabapentin enacarbil or placebo;

† Not broken down by treatment arm;

Appendix G. Table 5 Adverse effects for the alpha-2-delta ligands trials Part B

Study | Somnolence n/N (%) | | Dizziness n/N (%) | | Dry mouth n/N (%) | | Headache n/N (%) | | Fatigue n/N (%)
Study | Treatment | Placebo | Treatment | Placebo | Treatment | Placebo | Treatment | Placebo | Treatment | Placebo
Gabapentin enacarbil
Lee, 2011^18^ | 45/226 (19.9) | 2/96 (2.1) | 39/226 (17.3) | 5/96 (5.2) | 14/226 (6.2) | 2/96 (2.1) | 32/226 (14.1) | 8/96 (8.3) | 9/226 (4.0) | 5/96 (5.2)
Winkelman 2011^19,*^ | 16/127 (12.6) | 2/132 (1.5) | 26/127 (20.5) | 3/132 (2.3) | 6/127 (4.7) | 5/132 (3.8) | 11/127 (8.7) | 9/132 (6.8)
Bogan, 2010^21,**^ | 3/96 (3.1) 97/326 (29.8) during single-blind phase | 1/98 (1.0) | 2/96 (2.1) 72/326 (22.1) during single-blind phase | 1/98 (1.0) | | | 4/96 (4.2) 41/326 (12.6) during single-blind phase | 2/98 (2.0)
Kushida, †2009^23^ | Moderate 19/113 (16.8) Severe 0/113 | Moderate 0/108 Severe 0/108 | Moderate 11/113 (9.7) Severe 0/113 | Moderate 1/108 (0.9) Severe 1/108 (0.9) | | | Moderate 8/113 (7.1) Severe 0/113 | Moderate 4/108 (3.7) Severe 0/108 | Moderate 5/113 (4.4) Severe 1/113 (0.9) | Moderate 0/108 Severe 0/108
Gabapentin
Garcia-Borreguero,^*^ 2002^24^ | 2/23 (8.7) | 0/24 | | | 1/23 (4.3) | 0/24 | 0/23 | 1/24 (4.2) | Malaise 6/23 (26.1) | Malaise 2/24 (8.3)
Pregabalin
Allen, 2010^20^ | 18/114 (15.8) | 1/23 (4.3) | 16/114 (14.0) | 1/23 (4.3) | 6/114 (5.3) | 0/23 | 15/114 (13.2) | 3/23 (13.0) | 9/114 (7.9) | 0/23
Garcia-Borreguero, 2010^22^ | 13/30 (43.3) | 4/28 (14.3) | Unsteadiness 15/30 (50.0) | Unsteadiness 3/28 (10.7) | 3/30 (10.0) | 0/28 | 4/30 (13.3) | 1/28 (3.6)

* Crossover trial;

** Double-blind phase. All subjects had active treatment in a 24-week single-blind phase and were then randomized to either gabapentin enacarbil or placebo;

† Mild effects not reported here

Appendix G. Table 6a Specific adverse effects for the alpha-2-delta ligands trials Part C

Study | Vision effects n/N (%) | | Nausea n/N (%) | | Augmentation/other n/N (%)
Study | Treatment | Placebo | Treatment | Placebo | Treatment | Placebo
Lee, 2011^18^ (gabapentin enacarbil) | | | 12/226 (5.3) | 4/96 (4.2) | Sudden onset of sleep (daytime) 1 subject
Winkelman 2011^19,*^ (gabapentin enacarbil) | | | 6/127 (4.7) | 5/132 (3.8)
Allen, 2010^20^ (pregabalin)
Bogan, 2010^21,**^ (gabapentin enacarbil) | | | 3/96 (3.1) 21/326 (6.4) during single-blind phase | 2/98 (2.0)
Garcia-Borreguero, 2010^22^ (pregabalin) | Blurred vision 3/30 (10.0) | Blurred vision 0/28 | 1/30 (3.3) | 0/28 | 0/30 | 0/28
Kushida, 2009^23^ (gabapentin enacarbil) | Dry eye Moderate 1/113 (0.9) | Dry eye Moderate 0/108 | Moderate 4/113 (3.5) Severe 0/113 | Moderate 2/108 (1.9) Severe 0/108
Garcia-Borreguero, 2002^*,24^(gabapentin) | Dry eye 0/23 | Dry eye 1/24 (4.2) | 0/23 | 1/24 (4.2) | All patients 0/24

* Crossover study;

** Double-blind phase. All subjects had active treatment in a 24-week single-blind phase and were then randomized to either gabapentin enacarbil or placebo;^**^

Appendix G. Table 7 Withdrawals and adverse effects for the dopamine agonist versus levopdopa Part A

Study | Any study withdrawals n/N (%) | | Withdrawals due to adverse effects n/N (%) | | Patients with ≥ 1 adverse event n/N (%) | | Patients with ≥ 1 severe adverse effects n/N (%) | | Patients with ≥ 1serious adverse effects n/N (%)
Study | Treatment | Control | Treatment | Control | Treatment | Control | Treatment | Control | Treatment | Control
Trenkwalder 2007^27^ | 74/178 (41.6) | 83/183 (45.4) | 47/178 (26.4) | 47/183 (25.7) | 148/178 (83.1) | 142/183 (77.6) | | | 12/178 (6.7) | 9/183 (4.9)

Appendix G. Table 8 Adverse effects for the dopamine agonist trials Part B

Study | Fatigue n/N (%) | | Nausea n/N (%) | | Vomiting n/N (%) | | Headache n/N (%) | | Somnolence n/N (%)
Study | Treatment | Control | Treatment | Control | Treatment | Control | Treatment | Control | Treatment | Control
Trenkwalder, 2007^27^ | 22/178 (12.4) | 8/183 (4.4) | 55/178 (30.9) | 19/183 (10.4) | | | 24/178 (13.5) | 17/183 (9.3) | 19/178 (10.7) | 7/183 (3.8)

Appendix G. Table 9 Specific adverse effects for the dopamine agonist versus levodopa Part C

Study | Application site reactions n/N (%) | | Dizziness n/N (%) | | Augmentation n/N (%) | | Augmentation leading to study withdrawal n/N (%) | | Withdrawal due to insufficient effect n/N (%)
Study | Treatment | Control | Treatment | Treatment | Treatment | Control | Treatment | Control | Treatment | Control
Trenkwalder, 2007^27^ | | | 11/178 (6.2) | 5/183 (2.7) | 11/178 (6.2) | 32/183 (17.5) | 7/178 (3.9) | 18/183 (9.8) | 14/178 (7.9) | 26/183 (14.2)

Appendix G. Table 10 Withdrawals and adverse effects for the iron trials (secondary RLS)

Study | Any study withdrawals n/N (%) | | Withdrawals due to adverse effects n/N (%) | | Withdrawals due to lack of efficacy n/N (%) | | Patients with ≥ 1 adverse event n/N (%) | | Adverse effects n/N (%)
Study | Treatment | Placebo | Treatment | Placebo | Treatment | Placebo | Treatment | Placebo | Treatment | Placebo
Grote, 2009^30^ | 9/29 (31.0) | 21/31 (67.7) | 3/29 (10.3) | 1/31 (3.2) | 5/29 (17.2) | 19/31 (61.3) | 11/29 (37.9) | 11/31 (35.5) | headache 4 effects^*^ injection site rxn 1/29 (2.4) | headache 5 effects^*^ injection site rxn 1/31 (3.2)
Wang, 2009^31^ | 0/11 | 0/7 | 0/11 | 0/7 | 0/11 | 0/7 | NR | NR | NR | NR

* Not reported for unique patients