# Outcomes Tables

Appendix F. Table 1 IRLS responders (≥ 50% score reduction) at end of treatment for the dopamine agonist studies

Study, year | Duration (weeks) | Drug and daily dosage/control | Positive response % (n/N) | Risk ratio [95% CI]
Montagna, 2011^4^ | 12 | Pramipexole 0.125–0.75 mg | 75.9 (154/203) | 1.32 [1.15 to 1.53]
Montagna, 2011^4^ | 12 | Placebo | 57.3 (114/199)
Oertel, 2007^11^ | 6 | Pramipexole 0.125–0.75 mg | 52.2 (117/224) | 1.80 [1.32 to 2.47]
Oertel, 2007^11^ | 6 | Placebo | 28.9 (33/114)
Winkelman, 2006^15^ | 12 | Pramipexole 0.125–0.75 mg | 61.8 (157/254) | 1.46 [1.12 to 1.90]
Winkelman, 2006^15^ | 12 | Placebo | 42.4 (36/85)
Hening, 2010^5^ | 26 | Rotigotine 1,2,3 mg | 60.0 (177/297) | 1.59 [1.22 to 2.09]
Hening, 2010^5^ | 26 | Placebo | 37.4 (37/99)
Oertel, 2010^35^ | 7 | Rotigotine 1–3 mg | 76.1 (35/46) | 2.17 [1.17 to 4.04]
Oertel, 2010^35^ | 7 | Placebo | 35.0 (7/20)
Oertel, 2008^9^ | 6 | Rotigotine 1,2,3 mg | 63.2 (112/177) | 1.52 [1.09 to 2.14]
Oertel, 2008^9^ | 6 | Placebo | 41.5 (22/53)
Trenkwalder, 2008^10^ | 27 | Rotigotine 1,2,3 mg | 55.0 (183/333) | 2.16 [1.55 to 3.00]
Trenkwalder, 2008^10^ | 27 | Placebo | 25.4 (29/114)

CI = confidence intervals; IRLS = International Restless Legs Study Group Rating Scale.

Appendix F. Table 2 International Restless Legs Study Group Rating Scale (IRLS) scores for the dopamine agonist studies

Author year | Study Duration (weeks) | Intervention/Comparator (daily dose) (n) | IRLS score (SD) Baseline | IRLS score (SD), After treatment | Before/After Difference (SE) | Treatment versus Control, Difference [95% CI] | p-value
Bassetti, 2011^1^ | 4×2 (crossover) | Pramipexole (0.25–0.75 mg) (39) | 20.8 (8.2) | 13.6 (8.0) | −7.2 (9.5) | −3.0 | 0.054
Bassetti, 2011^1^ | 4×2 (crossover) | Levodopa/benserazide 100 | 21.1 (6.9) | 17.1 (7.8) | −4.2 (7.5) | −3.0 | 0.054
Benes, 2011^2^ | 12 | Ropinirole (0.25–4.0 mg) (171) | 28.5 (4.5) | – | −14.7 (9.0) | −4.8 [−7.5 to −2.1] | < 0.001
Benes, 2011^2^ | 12 | Placebo (60) | 29.0 (4.6) | – | −9.9 (8.9) | −4.8 [−7.5 to −2.1] | < 0.001
Högl, 2011^3^ | 26 | Pramipexole (0.125–0.75 mg) (166) | 23.9 (5.3) | 10.2 | −13.7 (0.8) | −3.7 | 0.0077
Högl, 2011^3^ | 26 | Placebo (163) | 23.5 (5.4) | 12.4 | −11.1 (0.8) | −3.7 | 0.0077
Montagna, 2011^4^ | 12 | Pramipexole (0.125–0.75 mg) (203) | 25.9 (5.2) | 11.4 (9.2) | −14.2 (0.7) | −6.1 [−4.3 to −7.9] | < 0.0001
Montagna, 2011^4^ | 12 | Placebo (200) | 25.9 (5.5) | 17.4 (10.4) | −8.1 (0.7) | −6.1 [−4.3 to −7.9] | < 0.0001
Hening, 2010^5^ | 28 | Rotigotine (0.5 mg) (98) | 23.1 (5.0) | 12.2 (8.2) | −10.9 (8.9) | −2.2 (1.2) | 0.068
Hening, 2010^5^ | 28 | Rotigotine (1 mg) (99) | 23.2 (5.3) | 12.1 (8.7) | −11.1 (9.3) | −2.3 (1.2) | 0.054
Hening, 2010^5^ | 28 | Rotigotine (2 mg) (95) | 23.3 (4.6) | 9.9 (8.8) | −13.4 (9.2) | −4.5 (1.2) | 0.0002
Hening, 2010^5^ | 28 | Rotigotine (3 mg) (103) | 23.6 (5.0) | 9.3 (8.5) | −14.3 (9.4) | −5.2 (1.2) | <0.0001
Hening, 2010^5^ | 28 | Placebo (99) | 23.5 (5.1) | 14.5 (8.0) | −9.0 (7.7)
Oertel, 2010^35^ | 6 | Rotigotine (1–3 mg) (46) | 26.3 (6.4) | 9.7 (9.1) | −16.5 (9.3) | −6.09 [−10.71 to 1.47] | 0.0107
Oertel, 2010^35^ | 6 | Placebo (21) | 25.4 (6.3) | – | −9.9 (9.9) | −6.09 [−10.71 to 1.47] | 0.0107
Ferini-Stambi, 2008^7^ | 12 | Pramipexole (0.25–0.75 mg) (182) | 24.3 (5.1) | 10.8 (9.1) | −13.4 (0.7) | −3.8 | < 0.0001
Ferini-Stambi, 2008^7^ | 12 | Placebo (187) | 24.6 (5.8) | 15.0 (10.9) | −9.6 (0.7) | −3.8 | < 0.0001
Oertel, 2008^9^ | 6 | Rotigotine (0.5 mg) (50) | 27.8 (6.0) | 17.3 (9.7) | −10.5 (9.2) | −1.3 (1.8) | 0.23
Oertel, 2008^9^ | 6 | Rotigotine (1 mg) (64) | 28.2 (5.4) | 13.0 (10.1) | −15.3 (10.0) | −5.8 (1.7) | 0.0004
Oertel, 2008^9^ | 6 | Rotigotine (2 mg) (49) | 28.0 (5.4) | 12.2 (9.1) | −15.7 (9.5) | −6.5 (1.9) | 0.0003
Oertel, 2008^9^ | 6 | Rotigotine (3 mg) (64) | 27.4 (6.1) | 10.1 (8.6) | −17.3 (10.5) | −8.3 (1.7) | <0.0001
Oertel, 2008^9^ | 6 | Rotigotine (4 mg) (53) | 28.2 (6.6) | 13.3 (10.1) | −14.9 (10.3) | −5.5 (1.8) | 0.0013
Oertel, 2008^9^ | 6 | Placebo (53) | 28.0(6.3) | 18.7 (10.6) | −9.3 (9.6)
Kushida, 2008^8^ | 12 | Ropinirole (0.5–6.0 mg) (176) | – | – | ~ −11 (3)^*^ | −4.11 [−6.08 to −2.14] | 0.001
Kushida, 2008^8^ | 12 | Placebo (186) | – | – | ~ −15.5 (3)^*^ | −4.11 [−6.08 to −2.14] | 0.001
Trenkwalder, 2008^10^ | 27 | Rotigotine (1 mg) (115) | 28.1 (6.3) | – | −13.7 (0.9) | −5.1 [−7.6 to −2.7] | < 0.0001
Trenkwalder, 2008^10^ | 27 | Rotigotine (2 mg) (112) | 28.2 (6.1) | – | −16.2 (0.9) | −7.5 [−10.0 to −5.1] | < 0.0001
Trenkwalder, 2008^10^ | 27 | Rotigotine (3 mg) (114) | 28.0 (5.9) | – | −16.8 (0.9) | −8.2 [−10.6 to −5.7] | < 0.0001
Trenkwalder, 2008^10^ | 27 | Placebo (117) | 28.1 (6.3) | – | −8.6 (0.9)
Oertel, 2007^11^ | 6 | Pramipexole (0.125–0.750 mg) (230) | 24.7 (5.2) | 12.3 (9.3) | −12.3 (0.6) | −6.6 [−8.6 to −4.5] | < 0.0001
Oertel, 2007^11^ | 6 | Placebo (115) | 24.9 (5.4) | 18.8 (10.0) | −5.7 (0.9) | −6.6 [−8.6 to −4.5] | < 0.0001
Bogan, 2006^13^ | 12 | Ropinirole (0.25–4.00 mg) (187) | 22.0 (4.99) | 8.4 (7.32) | −13.5 (1.2) | −3.7 [−5.4 to −2.0] | < 0.001
Bogan, 2006^13^ | 12 | Placebo (194) | 21.6 (4.79) | 11.9 (9.20) | −9.8 (1.2) | −3.7 [−5.4 to −2.0] | < 0.001
Montplaisir, 2006^14^ | 12 | Ropinirole (mean 2.05 mg) (45) | 8.9 (7.41)^**^ | – | 4.1 | −4.6 [−8.6 to −0.6] | 0.0246
Montplaisir, 2006^14^ | 12 | Placebo (47) | 10.4 (7.30)^**^ | – | 8.2 | −4.6 [−8.6 to −0.6] | 0.0246
Winkelman, 2006^15^ | 12 | Pramipexole (0.25 mg) (88) | 23.4 (4.9) | – | −12.8 (1.0) | – | 0.0086
Winkelman, 2006^15^ | 12 | Pramipexole (0.50 mg) (80) | 22.9 (5.1) | – | −13.8 (1.0) | – | 0.0011
Winkelman, 2006^15^ | 12 | Pramipexole (0.75 mg) (90) | 24.1 (5.2) | – | −14.0 (1.0) | – | 0.0005
Winkelman, 2006^15^ | 12 | Placebo (86) | 23.5 (5.2) | – | −9.3 (1.0)
Adler, 2004^12^ | 5 | Ropinirole (0.5–6.0 mg) (11) | (overall) 25.0 (7.0) | 13.0 (12.0) | −12.0 (12.0) | −12.0 [−17.0 to −6.3] | < 0.001
Adler, 2004^12^ | 5 | Placebo (11) | | 24.7 (7.2) | – | −12.0 [−17.0 to −6.3] | < 0.001
Trenkwalder, 2004^16^ | 12 | Ropinirole (0.25–4.00 mg) (147) | 24.4 (5.75) | 13.5 (9.3) | −11.04 (0.72) | −3.01 [−5.03 to −0.99] | 0.0036
Trenkwalder, 2004^16^ | 12 | Placebo (139) | 25.2 (5.63) | 17.1 (9.4) | −8.03 (0.74) | −3.01 [−5.03 to −0.99] | 0.0036
Walters, 2004^17^ | 12 | Ropinirole (0.25–4.0 mg) (131) | 23.6 (5.9) | – | −11.2 (0.76) | −2.5 [−4.6 to −0.4] | 0.0197
Walters, 2004^17^ | 12 | Placebo (136) | 24.8 (5.4) | – | −8.7 (0.75) | −2.5 [−4.6 to −0.4] | 0.0197

CI = confidence interval; SE = standard error; SD = standard deviation; mg = milligrams.

* estimated from table;

** Double-blind phase, trial consisted of 24-week single blind phase during which all patients received ropinirole followed by 12 week double blind, placebo controlled phase for treatment responders

Appendix F. Table 3 International Restless Legs Study Group Rating Scale (IRLS) scores for alpha-2-delta ligands studies

Author year | Study Duration (weeks) | Intervention/Comparator, daily dose (n) | IRLS score (SD), Baseline | IRLS score (SD), After treatment | Before/After Difference (SD) | Treatment versus Control, Difference [95% CI] | p-value vs. control
Lee, 2011^18^ | 12 | Gabapentin enacarbil 1200 mg (111) | 23.2 (5.3) | 10.2 (8.3) | −13.0 (9.1) | −3.5 [−5.6 to −1.3]^*^ | 0.0015
Lee, 2011^18^ | 12 | Gabapentin enacarbil 600 mg (114) | 23.1 (4.9) | 9.3 (7.7) | −13.8 (8.1) | −4.3 [−6.4 to −2.3]^*^ | <0.0001
Lee, 2011^18^ | 12 | Placebo (96) | 23.8 (4.6) | 14.0 (7.9) | −9.8 (7.7)
Winkelman, 2011^19^ | 4×2 | Gabapentin enacarbil 1200 mg (123) | 25.4 (all subjects) (crossover study) | - | −14.99 (SE 0.73) | −6.57 [−8.58 to −4.57] | <0.0001
Winkelman, 2011^19^ | 4×2 | Placebo (127) | | - | −8.42 (SE 0.71)
Allen, 2010^20^ | 6 | Pregabalin 50 mg (22) | 24.6 (6.7) | - | −11.9 (10.9) | −4.20 [−9.75 to 1.35] | NS^**^
Allen, 2010^20^ | 6 | Pregabalin 100 mg (23) | 25.3 (6.4) | - | −12.3 (9.0) | −4.60 [−9.30 to 0.10] | NS^**^
Allen, 2010^20^ | 6 | Pregabalin 150 mg (22) | 26.2 (7.4) | - | −17.2 (10.3) | −9.50 [−15.03 to −3.79] | <0.05^**^
Allen, 2010^20^ | 6 | Pregabalin 300 mg (24) | 25.0 (7.4) | - | −12.6 (8.6) | −4.90 [−9.41 to −0.39] | <0.05^**^
Allen, 2010^20^ | 6 | Pregabalin 450 mg (23) | 24.1 (7.8) | - | −15.6 (9.0) | −7.90 [−12.75 to −3.05] | <0.05^**^
Allen, 2010^20^ | 6 | Placebo (23) | 23.8 (7.2) | - | −7.7 (6.6) | | -
Bogan, 2010^21,†^ | 12 | Gabapentin enacarbil 1200 mg (96) | 24.7 (5.5) | | −1.9 (7.0) †† | −2.1 | 0.03
Bogan, 2010^21,†^ | 12 | Placebo (98) | Single-blind phase | | −3.9 (6.5) ††
Garcia-Borreguero, 2010^22^ | 12 | Pregabalin 150–450 mg (30) | 19.80 (4.16) | 6.85 (6.87) | | −4.92 [0.73 to 9.12]^*^ | 0.005
Garcia-Borreguero, 2010^22^ | 12 | Placebo (28) | 21.46 (3.81) | 11.2 (8.60) | | | -
Kushida, 2009^23^ | 12 | Gabapentin enacarbil (XP13512/GSK1838262) 1200 mg (114) | 23.1 (4.9) | - | −13.2 (9.2) | −4.0 [−6.2 to −1.9]^*^ | 0.0003
Kushida, 2009^23^ | 12 | Placebo (108) | 22.6 (4.9) | - | −8.8 (8.6)
Garcia-Borreguero, 2002^24^ | 6 | Gabapentin 600–2400 mg (22) | 20.0 (all subjects) (crossover study) | 9.5 (1.35) | - | −8.40 [−12.06 to −4.74] | < 0.001
Garcia-Borreguero, 2002^24^ | 6 | Placebo (22) | | 17.9 (1.35) | -

CI = confidence intervals; SE = standard error; SD = standard deviation.

* adjusted;

** Based on confidence intervals;

† Double-blind phase, trial consisted of 24-week single blind phase during which all patients received gabapentin enacarbil followed by 12 week double blind, placebo controlled phase for treatment responders;

†† mean change in scores after randomization following single blind phase during which all patients received gabapentin enacarbil.

Appendix F. Table 4 International Restless Legs Study Group Rating Scale (IRLS) scores for the cabergoline studies

Author year | Study Duration (weeks) | Intervention/Comparator (daily dose) (n) | IRLS score (SD) Baseline | IRLS score (SD), After treatment | Before/After Difference (SD/SE) | Treatment versus Control, Difference [95% CI] | p-value
Trenkwalder, 2007^27^ | 30 | Cabergoline (2/3 mg) (178) | 25.6 (7.2) | – | −15.6 (10.8) | −7.0 [−9.1 to −4.9] | <0.001
Trenkwalder, 2007^27^ | 30 | Levodopa (200/300 mg) (183) | 25.8 (6.2) | – | −8.8 (10.7) | −7.0 [−9.1 to −4.9] | <0.001
Oertel, 2006^28^ | 5 | Cabergoline (2 mg) (20) | 31.2 (5.4) | – | −23.7 (11.2) | −15.8 [−22.68 to −8.92] | <0.001
Oertel, 2006^28^ | 5 | Placebo (20) | 31.8 (4.0) | – | −7.9 (11.0) | −15.8 [−22.68 to −8.92] | <0.001
Stiasny-Kolster, 2004^29^ | 47 | Cabergoline (0.5 mg) (21) | 27.2 (5.1) | – | −13.1 (10.3) | −9.8 [−15.33 to 4.27] | <0.001
Stiasny-Kolster, 2004^29^ | 47 | Cabergoline (1.0 mg) (20) | 25.2 (4.5) | – | −13.5 (9.9) | −10.2 [−15.77 to 4.63] | <0.001
Stiasny-Kolster, 2004^29^ | 47 | Cabergoline (2.0 mg) (22) | 27.7 (5.7) | – | −15.7 (11.9) | −12.4 [−18.39 to 6.41] | <0.001
Stiasny-Kolster, 2004^29^ | 47 | Placebo (22) | 26.0 (5.5) | – | −3.3 (8.0)

CI = confidence interval; SE = standard error; SD = standard deviation; mg = milligrams;

* estimated from table.

Appendix F. Table 5 International Restless Legs Study Group Rating (IRLS) scores for miscellaneous pharmacologic studies

Author, year | Study Duration (weeks) | Intervention/Comparator (daily dose) (n) | IRLS score (SD) Baseline | IRLS score (SD), After treatment | Before/After Difference (SD/SE) | Treatment versus Control, Difference [95% CI] | p-value
Allen, 2011^26^ | 4 | Iron (ferric carboxy-maltose) 1000 mg (n=24) | 25.0 (5.8) | - | −8.9 (8.5) | −4.90 [−9.27 to −0.53] | 0.049 (non-parametric)
Allen, 2011^26^ | 4 | Placebo | 24.2 (5.5) | - | −4.0 (6.1) | −4.90 [−9.27 to −0.53] | 0.049 (non-parametric)
Bayard, 2011^25^ | 6 | Bupropion 150 mg (29) | 26.3 (5.4) | 15.9 (9.1) | −10.4 (10.1) | −2.80 [−7.25 to 1.65] | 0.22
Bayard, 2011^25^ | 6 | Placebo (31) | 25.9 (5.3) | 18.3 (8.7) | −7.6 (7.1) | −2.80 [−7.25 to 1.65] | 0.22

Appendix F. Table 6 International Restless Legs Study Group Rating (IRLS) scores for nonpharmacologic studies

Author, year | Study Duration (weeks) | Intervention/Comparator (daily dose) (n) | IRLS score (SD) Baseline | IRLS score (SD), After treatment | Before/After Difference (SD/SE) | Treatment versus Control, Difference [95% CI] | p-value
Mitchell, 2011^36^ | 4 | Near-infrared (17) | 24.5 (5.3) | -- | −13.4 (8.1) | −9.00 [−13.21 to −4.79] | 0.001
Mitchell, 2011^36^ | 4 | Sham (17) | 23.6 (6.9) | -- | −4.4 (3.6) | −9.00 [−13.21 to −4.79] | 0.001
Cuellar, 2009^37^ | 8 | Valerian (800 mg) (24) | 23.0 (5.9) | -- | 3.4 (9.4) | −1.30 [−7.68, 5.08] | 0.69
Cuellar, 2009^37^ | 8 | Placebo (NR) (24) | 24.0 (8.0) | -- | 4.7 (10.4) | −1.30 [−7.68, 5.08] | 0.69
Lettieri, 2008^33^ | 4 | Compression (21) | 20.3 (5.9) | 8.4 (3.4) | -- | −5.70 [−8.21, −3.19] | < 0.05
Lettieri, 2008^33^ | 4 | Sham (14) | 19.0 (5.2) | 14.1 (3.9) | -- | −5.70 [−8.21, −3.19] | < 0.05
Aukerman, 2006^34^ | 12 | Exercise (11) | 20.6 (6.4) | 12.1 (5.6) | -- | −9.40 [−13.86, −4.94] | < 0.05
Aukerman, 2006^34^ | 12 | Control (17) | 22.5 (6.4) | 21.5 (6.3) | -- | −9.40 [−13.86, −4.94] | < 0.05

Appendix F. Table 7 International Restless Legs Study Group Rating Scale (IRLS) scores for iron studies

Author year | Study Duration (weeks) | Intervention (n)/Comparator (n) | IRLS score (SD), Baseline | IRLS score (SD), After treatment | Before/After Difference (SE) | Treatment versus Control, Difference [95% CI] | p-value vs. control
Grote, 2009^30^ | 52 | Iron sucrose 200 mg × 5 times over three months I.V. (29) | 23.2 (6.6) | 14.6 (10.6) | −8.7 (9.4) | −1.80 [−6.63 to 3.03] | 0.47
Grote, 2009^30^ | 52 | Placebo (31) | 25.9 (5.6) | 19.0 (9.4) | −6.9 (9.7)
Wang, 2009^31^ | 12 | Oral iron 650 mg (7) | 24.8 (5.72) | – | −10.3 (7.40) | −9.16 [−15.21 to −3.11] | 0.01
Wang, 2009^31^ | 12 | Placebo (11) | 23.0 (5.03) | - | −1.14 (5.64)

CI = confidence intervals; IV = intravenously; SE = standard error; SD = standard deviation; mU = mouse units;

* 10-item IRLS.

Appendix F. Table 8 IRLS Remitters (score = 0): Absolute effect per 100 patients

Study | Number of studies | Dopamine Agonist % (n/N) | Placebo % (n/N) | RR [95% CI] | Absolute effect [95% CI]
Rotigotine | 3 | 23.6 (183/774) | 9.9 (23/233) | 2.24 [1.49 to 3.35] | 12 more per 100 [5 more to 23 more]
Gabapentin enacarbil | 1 | 24.4 (55/225) | 11.5 (11/96) | 2.13 [1.17 to 3.89] | 13 more per 100 [2 more to 33 more]

CI = confidence intervals.

Appendix F. Figure 1 IRLS Remitters analyses

Appendix F. Figure 2 Efficacy and Harms data for double-blind dopamine agonist trials

Appendix. F. Figure 3 Efficacy and Harms data for double-blind alpha-2-delta ligands trials

Appendix F. Figure 4 Efficacy and Harms data for double-blind Cabergoline trials

Appendix F. Figure 5 Efficacy and Harms data for double-blind Iron therapy trials

Appendix F. Figure 6 Efficacy and Harms data for double-blind Cabergoline (dopamine agonists) vs. levodopa

Appendix F. Figure 7 Fixed-dose analyses of harms: Dopamine agonists

Appendix F. Table 9a Self-rated quality of sleep for dopamine agonist trials: Medical Outcomes Scale- Sleep Problems Index II

Study/Duration (wks) | Treatment/control | Baseline Score (±SD)^*^ | Mean change from baseline (±SD)^*^ | SMD [95%CI] between placebo
Hening, 2010^5^ (26) | Rotigotine (2 mg ** n=95) | NR | −21.5 (20.0) | 0.35 [0.07 to 0.57]
Hening, 2010^5^ (26) | Placebo (n=99) | NR | −14.8 (18.1) | 0.35 [0.07 to 0.57]
Oertel, 2010^35^ (7) | Rotigotine (n=46) | 53.3 (19.9) | −20.5 (21.4) | 0.30 [−0.22 to 0.82]
Oertel, 2010^35^ (7) | Placebo (n=21) | 49.5 (20.8) | −14.1 (21.0) | 0.30 [−0.22 to 0.82]
Trenkwalder, 2008^10^ (29) | Rotigotine (2 mg ** n=99) | NR | −20.1 (20.5) | 0.54 [0.25 to 0.82]
Trenkwalder, 2008^10^ (29) | Placebo (n=99) | NR | −10.0 (16.7) | 0.54 [0.25 to 0.82]
Ferini-Strambi, 2008^†,7^ (12) | Pramipexole(n=178) | NR | −19.5 (19.2) | 0.36 [0.15 to 0.57]
Ferini-Strambi, 2008^†,7^ (12) | Placebo (n=178) | NR | −12.9 (17.8) | 0.36 [0.15 to 0.57]
Kushida, 2008^†,8^ (12) | Ropinirole (n=174) | NR | −22.4 (23.5) | 0.24 [0.04 to 0.45]
Kushida, 2008^†,8^ (12) | Placebo (n=183) | NR | −16.8 (22.4) | 0.24 [0.04 to 0.45]
Bogan, 2006^13^ (12) | Ropinirole (n=176) | 52.0 (16.6) | −22.8 (18.0) | 0.45 [0.24 to 0.66]
Bogan, 2006^13^ (12) | Placebo (n=182) | 50.4 (15.6) | −14.6 (18.0) | 0.45 [0.24 to 0.66]
Trenkwalder, 2004^†,16^ (12) | Ropinirole (n=140) | NR | −14.8 (22.0) | 0.29 [0.05 to 0.53]
Trenkwalder, 2004^†,16^ (12) | Placebo (n=130) | NR | −9.0 (18.2) | 0.29 [0.05 to 0.53]
Walters, 2004^†,17^ (12) | Ropinirole (n=123) | NR | −16.5 (20.0) | 0.50 [0.25 to 0.75]
Walters, 2004^†,17^ (12) | Placebo (n=129) | NR | −7.0 (18.1) | 0.50 [0.25 to 0.75]

SD = standard deviation; SMD = standardized mean difference

* If provided.

** Fixed-dose study (range 0.5–3mg), 2 mg dose used for analysis.

† Data not reported in publication but was obtained from a prior systematic review (Scholz H,Trenkwalder C,Kohnen R,Kriston L, Riemann D,Hornyak M. Dopamine agonists for the treatment of restless legs syndrome. Cochrane Database of Systematic Reviews 2011, Issue 3. Art. No.: CD006009. DOI: 10.1002/14651858.CD006009.pub2).

Appendix F. Table 9b Self-rated quality of daytime sleepiness for dopamine agonist trials: Epworth Sleepiness Scale

Study/Duration (wks) | Treatment/control | Baseline Score (±SD)^*^ | Mean change from baseline (±SD)^*^ | Mean difference [95%CI] between control
Bassetti 2011{Bassetti, 2011 #4} (4 × 2)^**^ | Pramipexole (n=39) | 8.2 (4.0) | 7.9 (3.4) † | No statistical significance reported
Bassetti 2011{Bassetti, 2011 #4} (4 × 2)^**^ | Levopdopa/benserazide (n=39)_ | 8.7 (3.7) | 8.2 (3.7) † | No statistical significance reported
Winkelman, 2006^15^ (12) | Pramipexole (n=253) | 7.5 (4.5) | −1.8 (0.2) | P=0.30^††^
Winkelman, 2006^15^ (12) | Placebo (n=85) | 8.1 (4.4) | −1.4 (0.4) | P=0.30^††^
Adler, 2004^12^ (4 × 2)^**^ | Ropinirole (n=22) | NR | 6.9 (7.2) †† | −1.2 [−3.7 to 1.2] ^‡^
Adler, 2004^12^ (4 × 2)^**^ | Placebo (n=22) | NR | 8.1 (6.3) †† | −1.2 [−3.7 to 1.2] ^‡^

SD = standard deviation; SMD = standardized mean difference

* If provided.

** Crossover trial, two 4 week treatment periods

† Scores at end of treatment

†† MD not calculated, unclear if mean reduction represents all fixed doses of pramipexole combined.

Appendix F. Table 10a Self-rated quality of sleep for alpha-2-delta ligands trials: Medical Outcomes Scale- Sleep Problems Index II or Pittsburgh Sleep Quality Index

Study/Duration (wks) | Treatment/control | Instrument | Baseline Score (±SD)^*^ | Mean change from baseline (±SD)^*^ | SMD [95%CI] or P-value between placebo
Lee, 2011^18^ | Gabapentin enacarbil 600 mg (n=115) | MOS-sleep adequacy | 30.5 (24.08) | 29.1 (29.91) | 0.0003 <0.0001
Lee, 2011^18^ | Gabapentin enacarbil 1200 mg (n=111) | MOS-sleep adequacy | 34.7 (24.86) | 27.7 (29.1) | 0.0003 <0.0001
Lee, 2011^18^ | Placebo (n=96) | MOS-sleep adequacy | 34.8 (24.62) | 13.6 (24.59) | 0.0003 <0.0001
Allen, 2011^38^ (6) | Pregabalin (300 mg ** n=24) | MOS-SPI-II, | NR | −22.3 (19.1) | −0.29 [−0.29 to 0.86]
Allen, 2011^38^ (6) | Placebo (n=23) | 9-item | NR | −16.8 (18.2) | −0.29 [−0.29 to 0.86]
Garcia- Borreguero, 2010^22^ (12) | Pregabalin (n=30) | MOS-sleep adequacy | NR | NR | NR, P=0.001
Garcia- Borreguero, 2010^22^ (12) | Placebo (n=23) | MOS-sleep adequacy | NR | NR | NR, P=0.001
Kushida, 2009^23^ (12) | Gabapentin enacarbil (XP13515)(n=112) | MOS-sleep adequacy | NR | 27.7 (29.9) | 0.50 [0.23 to 0.76]
Kushida, 2009^23^ (12) | Placebo (n=108) | MOS-sleep adequacy | NR | 13.4 (27.4) | 0.50 [0.23 to 0.76]
Kushida, 2009^23^ (12) | Gabapentin enacarbil (XP13515)(n=112) | PSQI | NR | NR | NR, “all PSQ outcomes significantly improved with XP13515 at week 12”
Kushida, 2009^23^ (12) | Placebo (n=108) | PSQI | NR | NR | NR, “all PSQ outcomes significantly improved with XP13515 at week 12”
Garcia- Borreguero, 2002^24^ (6 × 2) † | Gabapentin (n=22) | PSQI | 9.7 (all patients) | 6.4 (1.9) †† | P<0.001
Garcia- Borreguero, 2002^24^ (6 × 2) † | Placebo (n=22) | PSQI | 9.7 (all patients) | 9.4 (1.9) †† | P<0.001

Medical Outcomes Scale- Sleep Problems Index II; PSQI = Pittsburgh Sleep Quality Index; SD = standard deviation; SMD = standardized mean difference

* If provided.

** Fixed dose study (range 50–400 mg), 300 mg dose used for analysis.

† Crossover trial, two 6 week treatment periods

†† Scores at end of treatment

Appendix F. Table 10b Self-rated quality of daytime sleepiness for alpha-2-delta ligands trials: Epworth Sleepiness

Study/Duration (wks) | Treatment/control | Baseline Score (±SD)^*^ | Mean change from baseline (±SD)^*^ | SMD [95%CI] between placebo
Kushida, 2009^23^ (12) | Gabapentin enacarbil (XP13515)(n=112) | 9.8 (4.9) | 6.1 (4.1) ** | −0.21 [−0.47 to 0.06]
Kushida, 2009^23^ (12) | Placebo (n=108) | 9.2 (4.5) | 7.0 (4.6) ** | −0.21 [−0.47 to 0.06]

SD = standard deviation; SMD = standardized mean difference

* If provided.

** Scores at end of treatment

Appendix F. Table 11 Self-rated quality of life and of quality sleep for the miscellaneous pharmacologic trials

Study/Duration (wks) | Treatment/control | Instrument | Baseline Score (±SD)^*^ | Mean change from baseline (±SD)^*^ | P-value between placebo
Allen, 2011{Allen, 2011 #756} | Iron (ferric carboxymaltose) 1000 mg (n=24) | RLS-QoL | NR | 56.5 (49.1) | 0.024
Allen, 2011{Allen, 2011 #756} | Placebo (n=19) | | NR | 19.5 (51.7)
| Iron (ferric carboxymaltose) 1000 mg (n=24) | MOS total | NR | 75.8 (79.0) | 0.094
| Placebo (n=19) | | NR | 35.1 (75.2)

Medical Outcomes Sleep Scale; SD = standard deviation; SMD = standardized mean difference.

Appendix F. Table 12 Self-rated quality of sleep for the non-pharmacologic trials

Study/Duration (wks) | Treatment/control | Instrument | Baseline Score (±SD)^*^ | Mean change from baseline (±SD)^*^ | P-value between placebo
Cuellar, 2009^32^ (8) | Valerian (n = 17) | PSQ | 14.4 (3.7) | 4.5 (5.3) | 0.94
Cuellar, 2009^32^ (8) | Placebo (n = 20) | | 12.4 (5.0) | 4.4 (4.8)
Cuellar, 2009^32^ (8) | Valerian (n = 17) | ESS | 11.7 (5.4) | 3.4 (4.4) | 0.64
Cuellar, 2009^32^ (8) | Placebo (n = 20) | | 10.4 (6.1) | 2.8 (3.7)
Lettieri, 2009^33^ (4) | Compression device (n = 21) | ESS | 11.2 (4.4) | 6.5 (4.0) | 0.04
Lettieri, 2009^33^ (4) | Sham device (n = 14) | | 11.3 ( 3.9) | 10.6 (3.8)

ESS = Epworth Sleepiness Scale; PSQ = Pittsburgh Sleep Quality Index; SD = standard deviation.

Appendix F. Table 13 Self-rated quality of life and of sleep for iron trials

Study/Duration (wks) | Treatment/control | Instrument | Baseline Score | Mean change from baseline | P-value between placebo
Grote, 2009^30^ (52) | Intravenous iron 200 mg × 5 occasions (1000 mg) (n=29) | ESS | Median 9.0 (2–18) | NR | NR “no statistical difference between treatment groups at any point of the study”
Grote, 2009^30^ (52) | Placebo (n=31) | ESS | Median 9.5 (1–18) | NR | NR “no statistical difference between treatment groups at any point of the study”
Wang, 2009^31^ (12) | Oral iron 650 mg daily (n=11) | Overall Quality of life | | Improved 7 (64%) | P=0.07
Wang, 2009^31^ (12) | Placebo (n=7) | Overall Quality of life | | Improved 1 (14%) | P=0.07

ESS = Epworth Sleepiness Scale. SD = standard deviation

* Proportion of participants reporting “Improved” versus “stayed the same or worsened.”

Appendix F. Figure 8 Funnel plot for Mean change in IRLS total score from baseline

Appendix F. Table 14 Patient global impressions responders (PGI) at end of treatment for dopamine agonist studies

Study, year | Duration (weeks) | Drug and daily dosage/control | Positive response % (n/N) | Risk ratio [95% CI]
Högl, 2011^3^ | 26 | Pramipexole 0.125–0.75 mg | 62.3 (101/162) | 1.42 [1.15 to 1.75]
| | Placebo | 44.0 (70/159)
Montagna, 2011^4^ | 12 | Pramipexole 0.125–0.75 mg | 62.9 (112/178) | 1.66 [1.33 to 2.06]
| | Placebo | 38.0 (68/179)
Ferini-Strambi, 2008^7^ | 12 | Pramipexole 0.125–0.75 mg | 62.9 (112/178) | 1.66 [1.33 to 2.06]
| | Placebo | 38.0 (68/179)
Oertel, 2007^11^ | 6 | Pramipexole 0.125–0.75 mg | 61.6 (138/224) | 1.95 [1.46 to 2.61]
| | Placebo | 31.6 (36/114)
Winkelman, 2006^15^ | 12 | Pramipexole 0.125–0.75 mg | 42.5 (108/224) | 3.01 [1.75 to 5.19]
| | Placebo | 14.1 (12/85) | 3.01 [1.75 to 5.19]
Kushida, 2008^8^ | 12 | Ropinirole 0.5–6 mg | 78.2 (136/174) | 1.52 [1.29 to 1.79]
| | Placebo | 51.4 (94/183)

CI = confidence intervals

Appendix F. Table 15 Clinical global impressions (CGI) responders (much-very much improved) at end of treatment for the dopamine agonist studies

Study, year | Duration (weeks) | Drug and daily dosage/control | Positive response % (n/N) | Risk ratio [95% CI]
Ferini-Strambi, 2008^7^ | 12 | Pramipexole 0.125–0.75 mg | 66.3 (118/178) | 1.65 [1.34 to 2.03]
Ferini-Strambi, 2008^7^ | 12 | Placebo | 40.2 (72/179)
Högl, 2011^3^ | 26 | Pramipexole 0.125–0.75 mg | 68.5 (111/162) | 1.36 [1.13 to 1.64]
Högl, 2011^3^ | 26 | Placebo | 50.3 (80/159)
Montagna, 2011^4^ | 12 | Pramipexole 0.125–0.75 mg | 69.3 (140/202) | 1.88 [1.53 to 2.30]
Montagna, 2011^4^ | 12 | Placebo | 36.9 (72/195)
Oertel, 2007^11^ | 6 | Pramipexole 0.125–0.75 mg | 62.9 (141/224) | 1.94 [1.46 to 2.57]
Oertel, 2007^11^ | 6 | Placebo | 32.5 (37/114)
Winkelman, 2006^15^ | 12 | Pramipexole 0.125–0.75 mg | 72.0 (180/250) | 1.41 [1.13 to 1.76]
Winkelman, 2006^15^ | 12 | Placebo | 51.2 (43/84)
Benes, 2011^2^ | 12 | Ropinirole 0.25–4 mg | 64.3 (110/171) | 1.38 [1.03 to 1.85]
Benes, 2011^2^ | 12 | Placebo | 46.7 (28/60)
Bogan, 2006^13^ | 12 | Ropinirole 0.25–4 mg | 73.3 (137/187) | 1.30 [1.12 to 1.51]
Bogan, 2006^13^ | 12 | Placebo | 56.5 (109/193)
Kushida, 2008^8^ | 12 | Ropinirole 0.5–6 mg | 70.9 (124/175) | 1.42 [1.19 to 1.68]
Kushida, 2008^8^ | 12 | Placebo | 50.0 (92/184)
Montplaisir, 2006^14^- | 12 | Ropinirole 2.05 mg (mean) | 68.9 (31/45) | 1.48 [1.02 to 2.13]
Montplaisir, 2006^14^- | 12 | Placebo | 46.7 (21/45)
Trenkwalder, 2004^16^ | 12 | Ropinirole 0.25–4 mg | 53.4 (78/146) | 1.31 [1.02 to 1.68]
Trenkwalder, 2004^16^ | 12 | Placebo | 40.9 (56/137)
Walters, 2004^17^ | 12 | Ropinirole 0.25–4 mg | 59.5 (78/131) | 1.51 [1.17 to 1.94]
Walters, 2004^17^ | 12 | Placebo | 39.6 (53/134)
Hening, 2010^5^ | 26 | Rotigotine 1,2,3 mg | 69.5 (264/380) | 1.26 [1.05 to 1.52]
Hening, 2010^5^ | 26 | Placebo | 57.1 (56/98)
Oertel, 2010^35^ | 7 | Rotigotine 1–3 mg | 84.1 (37/44) | 1.40 [0.96 to 2.05]
Oertel, 2010^35^ | 7 | Placebo | 60.0 (12/20)
Oertel, 2008^9^ | 6 | Rotigotine 1,2,3 mg | 75.7 (134/177) | 1.38 [1.07 to 1.79]
Oertel, 2008^9^ | 6 | Placebo | 54.7 (29/53)
Trenkwalder, 2008^10^ | 29 | Rotigotine 1–3 mg | 69.4 (213/307) | 1.52 [1.22 to 1.91]
Trenkwalder, 2008^10^ | 29 | Placebo | 45.5 (46/101)