# Evidence Tables

Appendix E. Table 1 Evidence Table for primary RLS: dopamine agonist trials

Appendix E. Table 2 Evidence Table for primary RLS: alpha-2-delta ligands trials

Appendix E. Table 3 Evidence Table for primary RLS: Bupropion

Appendix E. Table 4 Evidence Table for primary RLS: iron trials

Appendix E. Table 5 Evidence Table for primary RLS: Cabergoline trials

Appendix E. Table 6 Evidence Table for secondary RLS: iron trials

Appendix E. Table 7 Evidence Table for the nonpharmacologic studies