# Study Quality/Risk of Bias Tables

Appendix D. Table 1 Individual Study Quality for the Dopamine agonist trials

Study | Allocation concealment | Blinding | Intention-to treat analyses | Withdrawals adequately described | Quality
Bassetti, 2011^1^ | Unclear | Double | No, patients required to complete both treatment periods (28 excluded, 42%) | Yes | Fair
Benes, 2011^2^ | Adequate | Double | No, treatment and post-baseline data required (35 excluded, 13%) | Yes | Fair
Högl, 2011^3^ | Unclear | Double^*^ | No, treatment and post-baseline data^**^ required (10 excluded, 3%) | No, only due to adverse effects | Fair
Montagna, 2011^4^ | Unclear^†^ | Double^*^ | No, treatment and post-baseline data required (2 excluded, <1%) | Yes | Good
Hening, 2010^5^ | Adequate | Double | No, post-baseline data^**^ required (11 excluded, 2%) | Yes | Good
Oertel, 2010^35^ | Adequate | Double | No, 1 excluded | Yes | Good
Ferini-Stambi, 2008^7^ | Adequate | Double^*^ | No, treatment and post-baseline data required (12 excluded, 3%) | Yes | Good
Kushida, 2008^8^ | Unclear | Double | No, post-baseline data^**^ required (3 excluded, <1%) | No, only due to adverse effects | Fair
Trenkwalder, 2008^10^ | Adequate | Double | No, post-baseline data^**^ required (11 excluded, 2%) | Yes | Good
Oertel, 2008^9^ | Adequate | Double | No, treatment required (8 excluded, 2%) | Yes | Good
Oertel, 2007^11^ | Unclear^†^ | Double | No, treatment and post-baseline data required (7 excluded, 2%) | Yes | Good
Bogan, 2006^13^ | Adequate | Double^*^ | No, treatment required (1 excluded, <1%) | Yes | Good
Montplaisir, 2006^14^ | Adequate | Double^*^ | Yes | Yes | Good
Winkelman, 2006^15^ | Adequate | Double | No, post-baseline data required (5 excluded, 1%) | Yes | Good
Adler, 2004^12^ | Adequate | Double | Yes | Yes | Good
Trenkwalder, 2004^16^ | Adequate | Double^*^ | No, treatment required (2 excluded, <1%) | Yes | Good
Walters, 2004^17^ | Adequate^*^ | Double | Yes | Yes | Good

Double blinding denotes participants and investigators

* plus study team personnel and/or end points adjudicated by blinded committee

** primary efficacy outcome

† noted as adequate based on information in a Cochrane systematic review (Scholz H, Trenkwalder C, Kohnen R, Kriston L, Riemann D, Hornyak M. Dopamine agonists for the treatment of restless legs syndrome. Cochrane Database of Systematic Reviews 2011, Issue 3. Art. No.: CD006009. DOI: 10.1002/14651858.CD006009.pub2). This information was not evident in the trial publication but is presumed to have been obtained directly from the study sponsor.

Appendix D. Table 2 Individual Study Quality for the alpha-2-delta ligands trials

Study | Allocation concealment | Blinding | Intention-to treat analyses | Withdrawals adequately described | Quality
Bogan, 2010^21^ | Unclear | Double | No, one subject withdrew consent (<1%) | Yes | Fair
Lee, 2011^18^ | Adequate | Double^*^ | No, IRLS score at baseline and at least once during treatment required (4 excluded, 1%) | Yes | Good
Winkelman, 2011^19^ | Adequate | Double^*^ | No, post-baseline data required | Yes | Good
Allen, 2010^20^ | Adequate | Double | Yes | Yes | Good
Garcia-Borreguero^**^, 2010^22^ | Adequate | Double | Yes | Yes | Good
Kushida, 2009^23^ | Unclear | Double | No, treatment and post-baseline data required (2 excluded, <1%) | Yes | Fair
Garcia-Borreguero, 2002^24^ | Adequate | Double | No, treatment required (2 excluded from each phase^*^ 8.3%) | Yes | Good

* Double blinding denotes participants and investigators;

** crossover trial.

Appendix D. Table 3 Individual Study Quality for the iron and miscellaneous trials

Study/Intervention | Allocation concealment | Blinding | Intention-to treat analyses | Withdrawals adequately described | Quality
Allen, 2011^26^ Iron | Adequate | Double | No, 3 patients (7%) did not take or complete treatments | Yes | Good
Bayard, 2011^25^ Bupropion | Adequate | Double | Yes | Partially | Good
Mitchell, 2011^36^ Near infra-red light | Unclear, possibly inadequate (drawing “1” or “2” out of a bag | Single | Yes | Yes (none withdrew) | Fair
Grote, 2009^30^ Iron | Adequate | Double | Yes | Yes | Good
Wang, 2009^31^ Iron | Adequate | Double | Yes | Yes (none withdrew) | Good
Cuellar, 2009^32^ Valerian | Adequate | Double^*^ | No, study completers only (11 excluded, 23%) | Yes | Fair
Lettieri, 2009^33^ Compression device | Adequate | Double^*^ | Yes | Yes | Good
Aukerman, 2006^34^ Exercise | Unclear | NR | No, 13 patients (32%) were unable to participate | Partially | Fair

Double blinding denotes participants and investigators

* Plus additional study personnel

CI = confidence intervals