# Baseline Characteristics Tables

Appendix C. Table 1 Summary of study baseline characteristics for placebo-controlled, dopamine agonist trials (n=16)

Characteristic | Mean (range) Unless otherwise note | Number of trials reporting
Total number of patients evaluated | 4861 (22 to 505) | 16
Age of subjects, years | 55.1 (50.9 to 60.0) | 16
Women, % | 65 (55 to 74) | 16
Race/ethnicity, white % | 96 (86 to 100) | 7 h,j–o
RLS disease duration, years | 8.9 (2.1 to 22.8) | 13 a,b,d–m,o
Baseline IRLS total score (range 0 to 40)^*^ | 25.1 (22.0 to 28.6) | 16
Patients with very severe disease, % (number of patients) | 17.2 (3.3 to 37.1) | 3 m,n,p
Studies with a mean IRLS score >30, indicating severe disease^*^ | none | -
Previous RLS therapy, % | 41.0 (21.8 to 80.8) | 11 a,d,h–p
Patients who failed (experienced augmentation or rebound) with previous treatment, % (number of patients) | NR | NR^**^
Trials evaluating pramipexole, % (number of patients) | 37 (1794) | 5 h–l
Trials evaluating ropinirole, % (number of patients) | 35 (1696) | 7 a–g
Trials evaluating rotigotine (transdermal patch),% (number of patients) | 28 (1371) | 4 m–p
Crossover trials, % (number of patients) | 0.5 (22) | 1 a
Trial duration (double-blind phase), weeks | 15 (6 to 28) | 16
# of trials with a duration ≥6 months (%, number of patients) | 3 i,m,n (37, n=1655)
# of trials conducted in the Europe (%, number of patients) | 9 f,g,i–l, n–p (59, n=2867)
# of trials conducted in the US (%, number of patients) | 5 a–c,g,l (33, n=1615)
# of trials conducted in the Australia, Europe and North America, (%, number of patients) | 2 d,e (8, n=379)

* IRLS = International Restless Legs Scale: Scoring criteria are: Mild (score 1–10); Moderate (score 11–20); Severe (score 21–30); Very severe (score 31–40).

** 2 pramipexole trials (Högl, Winkelman) and 5 ropinirole trials (Bogan, Kushida, Montplaisir, Trenkwalder 2004, Walters) reported augmentation/end-of-dose rebound during previous RLS treatment as an exclusion criterion.

a Adler;

b Bogan;

c Kushida;

d Waters;

e Montplasir;

f Trenkwalder 2004a;

g Benes Ropinirole

h Winkelman;

i Högl;

j Montagna;

k Ferini-Strambi;

l Oertel 2007; Pramipexole

m Hening;

n Trenkwalder 2008;

o Oertel 2010;

p Oertel 2008;Rotigotine

Appendix C. Table 2 Summary of study baseline characteristics for pramipexole trials

Characteristic | Mean (range) Unless otherwise note | Number of trials reporting
Total number of patients evaluated | 1794 (331 to 404) | 5
Age of subjects, years | 55.2 (51.4 to 56.9) | 5
Women, % | 65 (60 to 70) | 5
Race/ethnicity, white % | 95.2 (86.4 to 99.5) | 4 a,c–e
RLS disease duration, years | 4.9 (3.4 to 5.7) | 5
Baseline IRLS total score (range 0 to 40)^*^ | 24.5 (23.5 to 25.9) | 5
Studies with a mean IRLS score >30, indicating severe disease^*^ | none | -
Previous RLS therapy, % | 26.0 (21.8 to 30.8) | 5
Trial duration (double-blind phase), weeks | 13.4 (6 to 26) | 5
Trials with a duration ≥6 months, % (number of patients) | 18 (331) | 1 b
Trials conducted in the Europe, % (number of patients) | 81 (1449) | 4 b–e
Trials conducted in the US, % (number of patients) | 19 (345) | 1 a
Trials conducted in the Australia, Europe and North America, % (number of patients) | none | -

IRLS = International Restless Legs Scale

a Winkelman;

b Högl;

c Montagna;

d Ferini-Strambi;

e Oertel 2007.

* Scoring criteria are: Mild (score 1–10); Moderate (score 11–20); Severe (score 21–30); Very severe (score 31–40)

Appendix C. Table 3 Summary of study baseline characteristics for ropinirole trials

Characteristic | Mean (range) Unless otherwise note | Number of trials reporting
Total number of patients evaluated | 1696 (22 to 381) | 7
Age of subjects, years | 54.1 (50.9 to 60) | 7
Women, % | 62 (55 to 73) | 7
Race/ethnicity, white % | NR | 0
RLS disease duration, years | 17.4 (10.5 to 22.8) | 6 a,b,d,e,f,g
Baseline IRLS total score (range 0 to 40)^*^ | 25.0 (22 to 28.6) | 7
Studies with a mean IRLS score >30, indicating severe disease^*^ | none | -
Previous RLS therapy, % | 44.3 (40.9 to 44.6) | 2 a,d
Trial duration (double-blind phase), weeks | 11.9 (8 to 12) | 7
Trials with a duration ≥6 months | none | -
Trials conducted in the Europe, % (number of patients) | 33 (522) | 2 f,g
Trials conducted in the US, % (number of patients) | 45 (765) | 3 a-c
Trials conducted in the Australia, Europe and North America, % (number of patients) | 22 (379) | 2 d,e

IRLS = International Restless Legs Scale

a Adler;

b Bogan;

c Kushida;

d Waters;

e Montplaisir;

f Trenkwalder 2004a;

g Benes 2011.

* Scoring criteria are: Mild (score 1–10); Moderate (score 11–20); Severe (score 21–30); Very severe (score 31–40)

Appendix C. Table 4 Summary of study baseline characteristics for rotigotine trials

Characteristic | Mean (range) Unless otherwise note | Number of trials reporting
Total number of patients evaluated | 1371 (67 to 505) | 4
Age of subjects, years | 56.0 (52.4 to 59.4) | 4
Women, % | 65 (58 to 74) | 4
Race/ethnicity, white % | 97 (94 to 100) | 3
RLS disease duration, years | 2.1 (2.1 to 2.2) | 2 a,c
Baseline IRLS total score (range 0 to 40)^*^ | 26.2 (23.3 to 28.1) | 4
Studies with a mean IRLS score >30, indicating severe disease^*^ | none | -
Previous RLS therapy, % | 60.1 (35.8 to 80.8) | 4
Trial duration (double-blind phase), weeks | 21.2 (7 to 29) | 4
Trials with a duration ≥6 months, % (number of patients) | 70 (963) | 2 a,b
Trials conducted in the Europe, % (number of patients) | 63 (866) | 3 b–d
Trials conducted in the US, % (number of patients) | 49 (505) | 1 a
Trials conducted in the Australia, Europe and North America, % (number of patients) | none | -

IRLS = International Restless Legs Scale

a Hening;

b Trenkwalder 2008;

c Oertel 2010;

d Oertel 2008.

* Scoring criteria are: Mild (score 1–10); Moderate (score 11–20); Severe (score 21–30); Very severe (score 31–40)