# Excluded Studies

1 Bliwise DL, Freeman A, Ingram CD, et al. Randomized, double-blind, placebo-controlled, short-term trial of ropinirole in restless legs syndrome. Sleep Medicine. Mar. 2005;6(2):141-7. duration<4wks. [pmid: 15716217].
2 Saletu M, Anderer P, Saletu-Zyhlarz GM, et al. Comparative placebo-controlled polysomnographic and psychometric studies on the acute effects of gabapentin versus ropinirole in restless legs syndrome. Journal of Neural Transmission. Apr. 2010;117(4):463-73. duration<4wks. [pmid: 20049491].
3 Saletu M, Anderer P, Saletu-Zyhlarz G, et al. Restless legs syndrome (RLS) and periodic limb movement disorder (PLMD): acute placebo-controlled sleep laboratory studies with clonazepam. European Neuropsychopharmacology. Apr. 2001;11(2):153-61. duration<4wks. [pmid: 11313161].
4 Saletu M, Anderer P, Saletu-Zyhlarz G, et al. Acute placebo-controlled sleep laboratory studies and clinical follow-up with pramipexole in restless legs syndrome. European Archives of Psychiatry & Clinical Neuroscience. Aug. 2002;252(4):185-94. duration<4wks. [pmid: 12242580].
5 Collado-Seidel V, Kazenwadel J, Wetter TC, et al. A controlled study of additional sr-L-dopa in L-dopa-responsive restless legs syndrome with late-night symptoms. Neurology. Jan. 15. 1999;52(2):285-90. no primary outcome. [pmid: 9932945].
6 Davis BJ, Rajput A, Rajput ML, et al. A randomized, double-blind placebo-controlled trial of iron in restless legs syndrome. European Neurology. 2000;43(2):70-5. no primary outcome. [pmid: 10686463].
7 Earley CJ, Horska A, Mohamed MA, et al. A randomized, double-blind, placebo-controlled trial of intravenous iron sucrose in restless legs syndrome. Sleep Medicine. Feb. 2009;10(2):206-11. no primary outcome. [pmid: 18280205].
8 Happe S, Klosch G, Saletu B, et al. Treatment of idiopathic restless legs syndrome (RLS) with gabapentin. Neurology. Nov. 13. 2001;57(9):1717-9. no primary outcome. [pmid: 11706121].
9 Inoue Y, Hirata K, Kuroda K, et al. Efficacy and safety of pramipexole in Japanese patients with primary restless legs syndrome: A polysomnographic randomized, double-blind, placebo-controlled study. Sleep Medicine. Jan. 2010;11(1):11-6. no primary outcome. [pmid: 19962941].
10 Kutukcu Y, Dogruer E, Yetkin S, et al. Evaluation of periodic leg movements and associated transcranial magnetic stimulation parameters in restless legs syndrome. Muscle & Nerve. Jan. 2006;33(1):133-7. no primary outcome. [pmid: 16175624].
11 Zucconi M, Oldani A, Castronovo C, et al. Cabergoline is an effective single-drug treatment for restless legs syndrome: clinical and actigraphic evaluation. Sleep. Nov. 1. 2003;26(7):815-8. no primary outcome. [pmid: 14655913].
12 Brodeur C, Montplaisir J, Godbout R, et al. Treatment of restless legs syndrome and periodic movements during sleep with L-dopa: a double-blind, controlled study. Neurology. Dec. 1988;38(12):1845-8. no primary outcome. [pmid: 3057399].
13 Walters AS, Wagner ML, Hening WA, et al. Successful treatment of the idiopathic restless legs syndrome in a randomized double-blind trial of oxycodone versus placebo. Sleep. Jun. 1993;16(4):327-32. no primary outcome. [pmid: 8341893].
14 Giannaki CD, Sakkas GK, Hadjigeorgiou GM, et al. Non-pharmacological management of periodic limb movements during hemodialysis session in patients with uremic restless legs syndrome. ASAIO Journal. Nov–Dec. 2010;56(6):538-42. no primary outcome. [pmid: 21245801].
15 Benes H, Kurella B, Kummer J, et al. Rapid onset of action of levodopa in restless legs syndrome: a double-blind, randomized, multicenter, crossover trial. Sleep. Dec. 15. 1999;22(8):1073-81. no primary outcome. [pmid: 10617168].
16 Allen R, Becker PM, Bogan R, et al. Ropinirole decreases periodic leg movements and improves sleep parameters in patients with restless legs syndrome. Sleep. Aug. 1. 2004;27(5):907-14. no primary outcome. [pmid: 15453549].
17 Trenkwalder C, Stiasny K, Pollmacher T, et al. L-dopa therapy of uremic and idiopathic restless legs syndrome: a double-blind, crossover trial. Sleep. Oct. 1995;18(8):681-8. no primary outcome. [pmid: 8560135].
18 Boghen D, Lamothe L, Elie R, et al. The treatment of the restless legs syndrome with clonazepam: a prospective controlled study. Canadian Journal of Neurological Sciences. Aug. 1986;13(3):245-7. no primary outcome. [pmid: 3527387].
19 Wagner ML, Walters AS, Coleman RG, et al. Randomized, double-blind, placebo-controlled study of clonidine in restless legs syndrome. Sleep. Jan. 1996;19(1):52-8. no primary outcome. [pmid: 8650464].
20 Sloand JA, Shelly MA, Feigin A, et al. A double-blind, placebo-controlled trial of intravenous iron dextran therapy in patients with ESRD and restless legs syndrome. American Journal of Kidney Diseases. Apr. 2004;43(4):663-70. no primary outcome. [pmid: 15042543].
21 Thorp ML, Morris CD, Bagby SP. A crossover study of gabapentin in treatment of restless legs syndrome among hemodialysis patients. American Journal of Kidney Diseases. Jul. 2001;38(1):104-8. no primary outcome. [pmid: 11431189].
22 von Scheele C. Levodopa in restless legs. Lancet. Aug. 23. 1986;2(8504):426-7. non-randomized study design. [pmid: 2874415].
23 Adler CH. Treatment of restless legs syndrome with gabapentin. Clinical Neuropharmacology. Apr. 1997;20(2):148-51. non-randomized study design. [pmid: 9099467].
24 Akpinar S. Restless legs syndrome treatment with dopaminergic drugs. Clinical Neuropharmacology. 1987;10(1):69-79. non-randomized study design. [pmid: 3545461].
25 Hornyak M, Grossmann C, Kohnen R, et al. Cognitive behavioural group therapy to improve patients’ strategies for coping with restless legs syndrome: a proof-of-concept trial. Journal of Neurology, Neurosurgery & Psychiatry. Jul. 2008;79(7):823-5. non-randomized study design. [pmid: 18303103].
26 Micozkadioglu H, Ozdemir FN, Kut A, et al. Gabapentin versus levodopa for the treatment of Restless Legs Syndrome in hemodialysis patients: an open-label study. Renal Failure. Jul. 2004;26(4):393-7. non-randomized study design. [pmid: 15462107].
27 Pellecchia MT, Vitale C, Sabatini M, et al. Ropinirole as a treatment of restless legs syndrome in patients on chronic hemodialysis: an open randomized crossover trial versus levodopa sustained release. Clinical Neuropharmacology. Jul–Aug. 2004;27(4):178-81. non-randomized study design. [pmid: 15319704].
28 Sakkas GK, Hadjigeorgiou GM, Karatzaferi C, et al. Intradialytic aerobic exercise training ameliorates symptoms of restless legs syndrome and improves functional capacity in patients on hemodialysis: a pilot study. ASAIO Journal. Mar–Apr. 2008;54(2):185-90. [pmid: 18356653].
29 Lauerma H, Markkula J. Treatment of restless legs syndrome with tramadol: an open study. Journal of Clinical Psychiatry. Apr. 1999;60(4):241-4. non-randomized study design. [pmid: 10221285].
30 Shinno H, Oka Y, Otsuki M, et al. Proposed dose equivalence between clonazepam and pramipexole in patients with restless legs syndrome. Progress in Neuro-Psychopharmacology & Biological Psychiatry. Apr. 16. 2010;34(3):522-6. non-randomized study design. [pmid: 20156514].
31 Earley CJ, Yaffee JB, Allen RP. Randomized, double-blind, placebo-controlled trial of pergolide in restless legs syndrome. Neurology. Dec. 1998;51(6):1599-602. not an intervention of interest. [pmid: 9855508].
32 Garcia-Borreguero D, Winkelman J, Adams A, et al. Efficacy and tolerability of sumanirole in restless legs syndrome: a phase II, randomized, double-blind, placebo-controlled, dose-response study. Sleep Medicine. Mar. 2007;8(2):119-27. not an intervention of interest. [pmid: 17239657].
33 Hayes CA, Kingsley JR, Hamby KR, et al. The effect of endovenous laser ablation on restless legs syndrome. Phlebology. 2008;23(3):112-7. not an intervention of interest. [pmid: 18467618].
34 Hornyak M, Rupp A, Riemann D, et al. Low-dose hydrocortisone in the evening modulates symptom severity in restless legs syndrome. Neurology. Apr. 29. 2008;70(18):1620-2. not an intervention of interest. [pmid: 18443313].
35 Jaber BL, Schiller B, Burkart JM, et al. Impact of short daily hemodialysis on restless legs symptoms and sleep disturbances. Clinical Journal of The American Society of Nephrology: CJASN. May. 2011;6(5):1049-56. not an intervention of interest. [pmid: 21415315].
36 Kushida CA, Walters AS, Becker P, et al. A randomized, double-blind, placebo-controlled, crossover study of XP13512/GSK1838262 in the treatment of patients with primary restless legs syndrome. Sleep. Feb. 1. 2009;32(2):159-68. not an intervention of interest. [pmid: 19238802].
39 Nahab FB, Peckham EL, Hallett M. Double-blind, placebo-controlled, pilot trial of botulinum toxin A in restless legs syndrome. Neurology. Sep. 16. 2008;71(12):950-1. not an intervention of interest. [pmid: 18794499].
40 Pieta J, Millar T, Zacharias J, et al. Effect of pergolide on restless legs and leg movements in sleep in uremic patients. Sleep. Sep. 15. 1998;21(6):617-22. not an intervention of interest. [pmid: 9779521].
41 Larsen S, Telstad W, Sorensen O, et al. Carbamazepine therapy in restless legs. Discrimination between responders and non-responders. Acta Medica Scandinavica. 1985;218(2):223-7. not an intervention of interest. [pmid: 3904337].
42 Sonka K, Pretl M, Kranda K. Management of restless legs syndrome by the partial D2-agonist terguride. Sleep Medicine. Sep. 2003;4(5):455-7. not an intervention of interest. [pmid: 14592288].
43 Staedt J, Wassmuth F, Ziemann U, et al. Pergolide: treatment of choice in restless legs syndrome (RLS) and nocturnal myoclonus syndrome (NMS). A double-blind randomized crossover trial of pergolide versus L-Dopa. Journal of Neural Transmission. 1997;104(4–5):461-8. not an intervention of interest. [pmid: 9295178].
44 Telstad W, Sorensen O, Larsen S, et al. Treatment of the restless legs syndrome with carbamazepine: a double blind study. British Medical Journal Clinical Research Ed. Feb. 11. 1984;288(6415):444-6. not an intervention of interest. [pmid: 6419958].
45 Trenkwalder C, Hundemer HP, Lledo A, et al. Efficacy of pergolide in treatment of restless legs syndrome: the PEARLS Study. Neurology. Apr. 27. 2004;62(8):1391-7. not an intervention of interest. [pmid: 15111679].
46 Walters AS, Hening WA, Kavey N, et al. A double-blind randomized crossover trial of bromocriptine and placebo in restless legs syndrome. Annals of Neurology. Sep. 1988;24(3):455-8. not an intervention of interest. [pmid: 3067654].
47 Wetter TC, Stiasny K, Winkelmann J, et al. A randomized controlled study of pergolide in patients with restless legs syndrome. Neurology. Mar. 23. 1999;52(5):944-50. not an intervention of interest. [pmid: 10102410].
48 Giorgi L, Ritchie SY, Kirsch JM. Efficacy and tolerability of ropinirole in patients with restless legs syndrome and a baseline IRLS total score > or = 24 points--data from the ropinirole clinical trial programme. Current Medical Research & Opinion. Oct. 2006;22(10):1867-77. not a primary study. [pmid: 17022844].