# Acronyms and Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CER: comparative effectiveness review
CGI: clinician-assessed global impressions
CI: confidence interval
FDA: Food and Drug Administration
ICTRP: International Controlled Trials Registry Platform
IRLS: International Restless Legs Syndrome Study Group Rating Scale
MD: Mean difference
MOS: Medical Outcomes Study Sleep Problem Index
MOS-SPI-II: Medical Outcome Study sleep problem indexes (SPI-I, SPI-II)
NIH: National Institutes of Health
PGI: patient-assessed global impressions
PLM: periodic limb movements
RCT: randomized controlled trials
RLS: Restless legs syndrome
RR: risk ratios
SMD: standardized mean difference
TEP: technical expert panel
WMD: weighted mean difference