# Results

## Organization of Results

In the result chapter, we first describe the literature identification process along with the inclusion and exclusion of studies. The characteristics of the included studies follows and is organized into four sections that correspond to the comparisons of interest: systemic biologics versus systemic nonbiolgics, systemic biologics versus phototherapy, studies providing only class level comparisons, and included network meta-analyses. After the general characteristics are presented, we organize the remainder of the results by Key Question. A complete list of abbreviations can be found in the list of acronyms and abbreviations list at the end of this report and in Appendix J, and a glossary of useful terms can be found in Appendix I.

## Study Identification

Two literature searches were conducted as described in the Methods section. The first literature search was conducted to identify relevant literature to answer Key Questions 1, 2 and 3. As delineated in Figure 2, there were 472 citations identified through the database searches and four citations identified manually. One of the manual citations was from the Scientific Information Packets obtained by the Scientific Resource Center while three were from public clinical trial registries. Upon updating the search in June 2012, a total of 89 citations were retrieved. After the removal of duplicates, 508 articles remained. During title and abstract review, 328 citations were excluded. Of the 180 citations remaining, 147 were excluded at the full-text level. A total of 33 citations, representing 14 unique studies, met our inclusion criteria for Key Questions 1, 2 and 3. The number of included citations exceeds the number of included studies because some publications evaluated the same population. In such cases we only considered the population once and did not double count data. Citations excluded at the full text level are listed in Appendix C along with the reasons for exclusion.

Figure 2 Inclusion and exclusion of citations in search one

Figure 2 shows the flow of study identification and selection for the literature search corresponding to part one of this project. The initial database search resulted in 468 citations from Medline, The Cochrane Central Register of Controlled trials, and Web of Science. An additional 4 citations were identified from other sources. After duplicates were removed, there were 419 unique citations eligible for title and abstract screening. The first phase of screening excluded 250 citations for the following reasons: 136 citations were not systematic reviews or clinical studies, 9 citations were not conducted in human adults, 32 citations did not include patients with psoriasis or psoriasis vulgaris, and 73 citations did not compare biologic systemic agents to non-biologic systemic agents or phototherapy. This process left 169 citations to be assessed for eligibility by screening the full-text articles. The second phase of screening excluded 139 records for the following reasons: 63 were not systematic reviews or clinical studies, 2 were not conducted in human adults, 14 did not include patients with psoriasis or psoriasis vulgaris, 8 were not active controlled, 45 did not compare biologic systemic agents to non-biologic systemic agents or phototherapy, and 7 did not report any outcome(s) of interest. The full text screening left 30 records representing 11 unique studies to be included for qualitative evaluations.

The second literature search was used to specifically identify systematic reviews with meta-analysis that implemented methods to indirectly compare systemic biologic agents with systemic nonbiologic agents or phototherapy. The original literature search identified 19 citations and upon updating the literature search in June 2012, five additional citations were retrieved. A total of 15 citations were excluded at the abstract level and seven citations were excluded at the full text level. One unique analysis, which was represented by two citations, was finally included (Figure 3).

Figure 3 Inclusion and exclusion of citations in search two

CDSR = Cochrane Database of Systematic Reviews; DARE = Database of Abstracts of Reviews of Effects; HTA = health technology assessment

Figure 3 shows the flow of study identification and selection for the literature search corresponding to part two of this project. The initial database search resulted in 19 citations from Medline, Cochrane Database of Systematic Reviews, the database of abstracts of reviews of effects, and the Health Technology Assessment database. After duplicates were removed, there were 19 unique citations eligible for title and abstract screening. The first phase of screening excluded 13 citations for the following reasons: 6 citations were not systematic reviews, and 7 citations did not perform meta-analysis of comparisons of interest in patients with chronic plaque psoriasis. This process left 6 citations to be assessed for eligibility by screening the full-text articles. The second phase of screening excluded 4 records for not including indirect comparison methods. The full text screening left 2 citations representing 1 unique analysis to be included in the report.

## Study Characteristics

Five randomized controlled trials (RCTs) (n=1,227)17, 21–24 and four observational studies (n=1,066)25–28 directly compared a systemic biologic agent with either a systemic nonbiologic agent or phototherapy and reported at least one outcome of interest. Of the five RCTs, one was poor, 24 two were fair, 21, 22 and two were good in quality.17, 23 Of the four observational studies, three were fair in quality25, 26, 28 and one was poor in quality. 27 Additionally, three more observational studies (n=85) evaluated the transition of patients between therapies within the biologic, nonbiologic, and phototherapy treatments. One of these studies were poor in quality 29 while the others were fair in quality.30,31 Two of the RCTs also provided data regarding transitions of therapy.17,21 Two observational studies directly compared therapies of interest but at the class level, and both were fair in quality.32,33 Finally, we identified one network meta-analysis that used methods for indirect comparison across various therapies included in this review.34 All included studies were available as full text publications except for one whose results were only available from www.clinicaltrials.gov.24 The baseline characteristics of included studies can be found in Appendix D and the individual study quality assessments can be found in Appendix E.

### Studies Comparing Systemic Biologic Agents With Systemic Nonbiologic Agents

All five RCTs directly compared individual biologic agents with individual nonbiolgic agents. The unique comparisons included infliximab versus methotrexate,21 etanercept versus acitretin,22–24 and adalimumab versus methotrexate.17 The shortest followup was 12 weeks22 while the longest followup was 26 weeks.17,21 The earliest trial was published in 2008^17,23^ while the most recent was published in 2012.^24^ Three trials received industry funding17,21, 24 while two trials did not report the funding source.22,23 The mean age of enrolled patients ranged from 38.57 to 55.3 years. Females represented between 16.7 and 63.3 percent of the enrolled populations. Only two trials reported race/ethnicity of the enrolled population, in which Caucasians represented more than 95 percent of the populations in both trials, with other groups representing a minority of the studied populations (Appendix D, Table 3).17,21 The mean weight ranged from 78.4 to 84.5 kg while the mean BMI ranged from 27.2 to 28.0 kg/m^2^. The mean baseline Psoriasis Area and Severity Index (PASI) ranged from 10.4 to 26.31 while the mean disease duration ranged from 17.0 to 23.5 years. The mean body surface area (BSA) ranged from 11.1 to 39.75 percent. The percentage of participants with concomitant psoriatic arthritis ranged from 0 to 21.3 percent.

Two of the four observational studies directly compared individual biologic agents with individual nonbiologic agents.26, 28 The comparisons made included etanercept or infliximab with methotrexate26 and adalimumab, etanercept, or ustekinumab with methotrexate. 28 The longest followup period was 24 weeks.26 The earliest study was published in 2008^26^ while the most recent was published in 2012.^28^ One study received funding from the government 28 while the other study did not report the funding source.26 The mean age of the enrolled patients ranged from 46.8 to 53.1 years. Females represented between 30.0 and 49.4 percent of the enrolled populations. Race or ethnicity was reported only in one study where Caucasians represented 85 percent of the population. 28 Mean weight and body mass index (BMI) ranged from 79.2 to 81.0 kg and 26.5 to 28.8 kg/m^2^, respectively. The mean baseline PASI was reported in only one study that ranged from 8.2 to 18.8.^26^ The mean disease duration ranged from 17.5 to 22.0 years. Only one study reported concomitant psoriatic arthritis as 22.6 percent of the population and the same study also reported 25.8 percent of the population at baseline to be naïve to psoriasis therapy. 28 Mean BSA range was not reported.

Three observational studies29–31 along with data from two RCTs17,21 evaluated the transition of patients between biologic agents and nonbiologic agents. The transitions evaluated included methotrexate to adalimumab,17,21 cyclosporine to etanercept,29 cyclosporine to alefacept,31 methotrexate to infliximab,21 and infliximab to methotrexate.21 The shortest followup period was 26 weeks17,21,30 while the longest followup was 2 years.29 The earliest study was published in 2007^31^ while the most recent was published in 2011.^21, 30^ Four studies received industry funding17,21,30,31 and one study did not report the funding source.29 Baseline characteristics specific to the population of patients transitioned to different therapies within the two RCTs were not reported. According to the baseline characteristics of the three observational studies, the mean age of the enrolled patients ranged from 45.0 to 58.3 years. Females represented between 25.0 and 31.7 percent of the enrolled populations. One study reported 95.1 percent of patients were Caucasian.30 No other race/ethnicity percentages were reported. One study reported the mean weight as 89.5 kg while BMI data were not reported.30 The mean baseline PASI was reported as 10.2 in one study.30 The mean disease duration ranged from 17.0 to 22.0 years. One study reported the mean BSA as 10.9 percent.30 The percentage of participants with concomitant psoriatic arthritis ranged from 25.0 to 41.5 percent. None of the studies reported how psoriatic arthritis was diagnosed.17,21,29–31

### Studies Comparing Systemic Biologic Agents With Phototherapy

There were no RCTs identified that compared systemic biologic agents with phototherapy. Three observational studies directly compared individual biologic agents with phototherapies.25, 27,28 The comparisons made included adalimumab, alefacept, etanercept, infliximab or ustekinumab versus psoralen plus ultraviolet A (PUVA); 25 adalimumab, etanercept, or ustekinumab versus narrowband-ultraviolet B (NB-UVB);28 and infliximab or etanercept versus PUVA or NB-UVB.27 The duration of followup period was 10.3 weeks to 12 weeks. The earliest study was published in 2011^25^ while the most recent were published in 2012.^28^ One study received funding from the industry25, one from the government, 28 and one study did not report the funding source. 27 The mean age of the enrolled patients ranged from 46.2 to 55.1 years. The percentage of females ranged from 35.5 to 49.4 percent. The mean baseline PASI ranged from 15.0 to 22.3 and the mean disease duration ranged from 2 to 37 years. Race or ethnicity was reported in only one study where Caucasians represented 85 percent of the population. 28 Mean weight and BSA was not reported in any of the studies. The mean BMI was only reported in one study as 28.8 kg/m^2^.28 One study reported concomitant psoriatic arthritis as 22.6 percent of the population and also reported that 25.8 percent of the population at baseline was naïve to psoriasis therapy. 28

One observational study (n=70) evaluated the transition of patients between biologic agents and phototherapy, evaluating the transition from NB-UVB to adalimumab.30 The study was published in 2011 and received funding from industry. The followup period was 26 weeks. The mean age of enrolled patients was 45.7 years. Females and Caucasians represented 44.8 and 86.2 percent of the enrolled population, respectively. The mean weight was 86.0 kg while the mean BMI was not reported. The mean baseline PASI was 12.8 while the mean disease duration was 23.0 years. The mean BSA was reported as 14.5 percent. The percentage of participants with concomitant psoriatic arthritis was 24.1.

### Studies With Class-Level Comparisons

Two observational studies compared classes of therapy and both evaluated transitions of therapy.32,33 The transitions evaluated included systemic nonbiologic agents to etanercept33 and systemic nonbiologic agents or phototherapy to etanercept.32 The followup period was 24 weeks for both studies. The earliest study was published in 2005^33^ while the most recent was published in 2009.^32^ One study was unfunded32 and the other study did not report the funding source.33 The mean age of the enrolled patients and percent of females was only reported in one study as 41.2 years and 36.4 percent, respectively.33 Race/ethnic groups, weight, and BMI were not reported in either study. The mean baseline PASI ranged from 15.6 to 16.1. Only one study reported disease duration and mean BSA as 15.5 years and 21.7 percent, respectively.33 The percentage of participants with concomitant psoriatic arthritis was reported only in one study as 34.1.^33^

### Network Meta-Analyses

One systematic review by Bansback et al. evaluated the comparative efficacy of various treatments for chronic plaque psoriasis using a Bayesian model to conduct a mixed-treatment comparison.34 RCTs evaluating systemic biologic and systemic nonbiologic therapy or phototherapy in patients with moderate to severe psoriasis were included. Additionally, for a therapy to be included, either a direct or indirect link to placebo was required. Because of this, acitretin and phototherapy were excluded because no link to placebo was identified in the literature.

## Key Question 1

In patients with chronic plaque psoriasis, what is the comparative effectiveness of systemic biologic agents and systemic nonbiologic agents (between-class comparisons) or phototherapy when evaluating intermediate [plaque BSA measurement, PASI, Patient’s Assessment of Global Improvement, Physician’s Global Assessment (PGA), and individual symptom improvement] and final health outcomes {mortality, health-related quality of life [HRQoL] [e.g., dermatology life quality index (DLQI), Health Assessment Questionnaire Disability Index (HAQ-DI), EuroQol 5-Dimension™ (EQ-5D)] and other patient-reported outcomes, major adverse cardiovascular events [MACE], diabetes, and psychological comorbidities [e.g., depression, suicide]}?

### Key Points

- Five RCTs (two good, two fair, and one poor in quality) and two fair quality observational studies evaluated the comparative effectiveness of systemic biologic agents and systemic nonbiologic agents.
  ○ The comparisons made included: adalimumab, etanercept, infliximab, and ustekinumab versus methotrexate and etanercept versus acitretin.
  ○ When comparing adalimumab with methotrexate:
    – HRQoL was improved in patients taking adalimumab compared with methotrexate, based on one RCT and one observation study (low strength of evidence).
    – There was insufficient evidence to grade death and no other final health outcomes were reported.
    – PASI was improved in patients treated with adalimumab compared with methotrexate, based on one RCT and one observational study (low strength of evidence).
    – PGA was improved in patients treated with adalimumab compared with methotrexate, based on one RCT and one observational study (low strength of evidence).
    – Patient Assessment of Disease Severity, pain, and pruritus were each improved in patients treated with adalimumab compared with methotrexate, each based on a single RCT (low strength of evidence).
    – There was insufficient evidence to determine the impact of adalimumab versus methotrexate on BSA and no other intermediate outcomes were reported.
  ○ When comparing infliximab with methotrexate:
    – HRQoL was improved in patients taking infliximab compared with methotrexate, based on a single RCT (low strength of evidence).
    – There was insufficient evidence to evaluate myocardial infarction and diabetes mellitus and no other final health outcomes were reported.
    – PASI was improved in patients treated with infliximab compared with methotrexate, based on one RCT and one observational study (low strength of evidence).
    – PGA improved in patients treated with infliximab compared with methotrexate, based on a single RCT (low strength of evidence).
    – No other intermediate outcomes were reported.
  ○ When comparing ustekinumab with methotrexate:
    – There was insufficient evidence to evaluate HRQoL and no other final health outcomes were reported.
    – PGA improved in patients treated with ustekinumab compared with methotrexate, based on a single observational study (low strength of evidence).
    – There was insufficient evidence to evaluate BSA and PASI and no other intermediate health outcomes were reported.
  ○ When comparing etanercept with acitretin:
    – There was insufficient evidence to evaluate psychological comorbidities and patient reported outcomes and no other final health outcomes were reported.
    – PASI was improved in patients treated with etanercept compared with acitretin, based on three RCTs (moderate strength of evidence).
    – There was insufficient evidence to evaluate BSA, PGA, joint pain, and itching and no other intermediate outcomes were reported.
- One mixed-treatment comparison that evaluated PASI 50, PASI 75, and PASI 90 suggested that the probability of achieving any of the three PASIs was highest for infliximab, followed by adalimumab, etanercept, methotrexate, cyclosporine, efalizumab, alefacept, and finally supportive care.
- No RCTs and three observational studies (one fair and two poor in quality) evaluated the comparative effectiveness of systemic biologic agents and phototherapy.
  ○ The comparisons made included: adalimumab, etanercept, infliximab, and ustekinumab versus NB-UVB and etanercept and infliximab versus PUVA.
  ○ There was insufficient evidence to evaluate HRQoL and no other final health outcomes were reported.
  ○ There was insufficient evidence to evaluate BSA, PASI, PGA, psoriatic arthritis pain, and pruritus and no other intermediate outcomes were reported.

### Detailed Analysis

Key Question 1 is organized by the comparisons of interest. Systemic biologic agents versus systemic nonbiologic agents are presented first followed by the comparison of systemic biologic agents versus phototherapy. Within each comparison of interest, we present data from direct comparisons first and describe data for final health outcomes followed by intermediate outcomes. Data from RCTs are presented first followed by observational study data. If data describing the transition from one therapy to another were identified, a subsection describing transition data follows the direct comparative data. At the end of the Key Question, data based class comparisons and indirect comparisons are summarized.

The individual study characteristics for all studies included in this Key Question along with their quality assessments can be found in Appendix E, Tables 3 and 4. Tables that display the outcomes reported within this Key Question can be found in Appendix F, Tables 5 to 11. Strength of evidence ratings as well as description of the applicability of each study can be found in Appendix G and Appendix H, Tables 12 to 48.

#### Outcome Evaluation

##### Systemic Biologic Agents Versus Systemic Nonbiologic Agents

###### Adalimumab Versus Methotrexate

One RCT and one observational study compared the biologic agent adalimumab versus the nonbiologic agent methotrexate. 17, 28 The efficacy and safety results from the randomized controlled comparative study of adalimumab versus methotrexate versus placebo in patients with psoriasis (CHAMPION) trial was the only source of data from a RCT for this comparison.17 This trial was rated with good quality and all patients were naïve to both tumor necrosis factor (TNF)-antagonists and methotrexate. A secondary analysis of the CHAMPION population by Revicki et al. was published with additional outcomes and supplemented data from the CHAMPION trial itself. The following final health outcomes were reported: mortality and HRQoL (e.g., DLQI, EQ-5D).17,35 No additional final health outcomes were reported for the comparison of adalimumab with methotrexate.

In the CHAMPION trial, there were no deaths in either group at 70 days after the last treatment. Two measures of HRQoL were evaluated in the study by Revicki et al., the DLQI and the EQ-5D [both the index score and the visual analogue scale (VAS)]. At week 16, the DLQI and the EQ-5D VAS demonstrated a favorable result in the adalimumab group compared with methotrexate. The mean change in DLQI from baseline was significantly greater in the adalimumab group compared with methotrexate group at week 16 [−9.1 (95% CI, −10.4 to −7.8) versus −5.7 (95% CI, −6.8 to −4.5); p<0.001].35 There was significant difference in the mean change in the EQ-5D VAS from baseline to 16 weeks in the adalimumab group compared with methotrexate [21.4 (95% CI, 16.6 to 26.3) versus 11.5 (95% CI, 6.5 to 16.5); p<0.001]. However, there was no significant difference in the mean change in EQ-5D index score from baseline to week 16 in the adalimumab group compared with methotrexate [0.2 (95% CI, 0.2 to 0.3) versus 0.1 (95% CI, 0.1 to 0.2); p=0.09]. At 12 weeks, adalimumab treatment resulted in greater improvement in the DLQI [−9.1 (95% CI, −10.4 to −7.8) versus −4.9 (95% CI, −5.9 to −3.8); p=not reported (NR)], the EQ-5D VAS [20.4 (95% CI, 15.3 to 25.4) versus 10.2 (95%CI, 5.3 to 15.2); p=NR], and the EQ-5D index score [0.2 (95% CI, 0.1 to 0.2) versus 0.1 (95% CI, 0.1 to 0.2); p=NR] compared with methotrexate.

CHAMPION and the secondary analysis by Revicki et al. evaluated the following intermediate health outcomes: PASI, PGA, Patient’s Global Assessment of disease Severity, and individual symptom improvement (i.e., VAS for plaque psoriasis and psoriatic arthritis pain, psoriasis-related pruritus assessment).17,35 When compared with methotrexate, more patients who received adalimumab achieved PASI 50 (88.0 percent versus 61.8 percent, p<0.001), PASI 75 (risk difference 43.7 percent (95% CI, 30.8 to 56.7, p<0.001); 79.6 percent versus 35.5 percent, p<0.001), PASI 90 (51.9 percent versus 13.6 percent, p<0.001), and PASI 100 (16.7 percent versus 7.3 percent, p<0.04) at week 16. The median time to PAS I75 was significantly shorter in the adalimumab group compared with methotrexate (56 days versus 113 days, p<0.001) as was the median time to PASI 50 (28 days versus 84 days, p<0.001).36 Investigators also evaluated PASI outcomes at weeks 4, 8, and 12. More patients treated with adalimumab achieved PASI 50, PASI 75, PASI 90 at all time periods evaluated (p<0.05) with significant effects observed as early as week 4, except for PASI 100. (Appendix F, Table 8) As for PASI 100, significant differences between treatment groups (p<0.05) were observed as early as 8 weeks and were maintained subsequently. (Appendix F, Table 8) The mean change in PASI from baseline was significantly greater in the adalimumab group compared with the methotrexate group at week 16 (−16.7±8.8 versus −10.9±8.3, p<0.001).

There was a significantly greater number of patients with a score of “clear” or “minimal” using the PGA tool in the adalimumab group compared with methotrexate at 16 weeks (73.1 percent versus 30.0 percent, p<0.001) as well as earlier time points (weeks 4, 8, and 12).35 (Appendix F, Table 7) At week 16, the adalimumab group demonstrated significant improvements from baseline compared with methotrexate in the Patient’s Global Assessment of disease severity and in the individual symptoms of pain and pruritus.35 The mean change in Patient’s Global Assessment of disease severity from baseline was significantly greater in the adalimumab group compared with methotrexate at week 16 (−1.6 versus −1.2, p<0.001). The mean change in VAS for plaque psoriasis and psoriatic arthritis pain from baseline was significantly greater in the adalimumab group compared with methotrexate at week 16 (−24.2 versus −11.1, p<0.001). The mean change in psoriasis-related pruritus from baseline was significantly greater in the adalimumab group compared with the methotrexate at week 16 (−5.0 versus −3.5, p<0.001).35

The observational study by Gelfand et. al. evaluated one final health outcome: HRQoL. The study was rated with fair quality and 187 out of 713 (25.8 percent) patients were naïve to any psoriasis treatment. 28 The median DLQI score in patients treated with adalimumab was 2 (interquartile range of 0 to 5) and in patients treated with methotrexate was 3 (interquartile range of 1 to 5) (p=NR). When the DLQI score was analyzed as a dichotomous outcome (i.e., number of patients with response defined as no effect or a small effect of psoriasis on quality of life indicated by the DLQI score less than equal to 5), a similar proportion of patients treated with adalimumab achieved the response (78 percent; 95% CI, 70.5 to 84.3) compared with methotrexate (77.4 percent; 95% CI, 70.6 to 83.4; p=NR). 28

This observational study also evaluated the following intermediate outcomes: BSA, PASI and PGA. 28 The median PASI in patients treated with adalimumab was 2.5 (interquartile range of 1.2 to 4.8) and in patients treated with methotrexate was 3.8 (interquartile range of 1.8 to 6.6) (p=NR). The same study also reported a median BSA percentage of 2.0 (interquartile range of 0.7 to 5.0) for patients treated with adalimumab and 3.0 (interquartile range of 1.0 to 6.0) for patients treated with methotrexate (p=NR). 28 The median PGA was 1.3 (interquartile range of 1.0 to 1.7) in patients treated with adalimumab and 1.7 (interquartile range of 1.3 to 2.0) in patients treated with methotrexate (p=NR). When the PGA was analyzed as a dichotomous outcome (i.e., number of patients with response defined as “clear” or “minimal” indicated by the PGA less than equal to 1), a significantly higher proportion of patients treated with adalimumab achieved response compared with methotrexate (adjusted relative rate of 2.15; 95% CI, 1.60 to 2.90).28

###### Transitions Between Adalimumab and Methotrexate

Two studies evaluated the transition between the biologic agent adalimumab and the nonbiologic agent methotrexate.30,37

The first study was a nonrandomized open-label study by Strober et al. Patients who had a suboptimal response to methotrexate, defined as a PGA of “mild” or worse after at least four months of methotrexate therapy were evaluated. Patients stopped methotrexate four to 10 days prior to transitioning to adalimumab treatment.30 This study was rated as having fair quality and all patients were naïve to adalimumab and natalizumab although being naïve to other therapies was not reported. The following final health outcomes were reported: mortality, HRQoL (e.g., DLQI), and impact on activities of daily living (e.g., work time missed, overall work impairment, impairment while working, and activity impairment due to psoriasis). No additional final health outcomes were reported for patients who transitioned from methotrexate to adalimumab.

In this study by Strober et al., there were no deaths reported through week 16. The mean DLQI improved from baseline to weeks 4 and 16 [(−7.0±7.45, p=NR) and (−4.8±5.89, p=NR), respectively]. Corresponding standard deviations were not reported in the original publication but were reported separately in the results available on www.clinicaltrials.gov. Measures of the impact of psoriasis on activities of daily living were also reported in the results available on www.clinicaltrials.gov.30,38 At week 16, patients showed improvement in the mean percent change of overall work impairment due to psoriasis (−4.0±28.1 percent, p=NR), impairment while working due to psoriasis (−5.5±30.3 percent, p=NR), and activity impairment due to psoriasis (−13.3±33.1 percent, p=NR). However, there was no improvement in the mean percent change in work time missed due to psoriasis (0.7 ± 3.43 percent, p=NR).38

Two studies evaluated intermediate outcomes. The first being the study by Strober et al. and the second was an open-label extension of the CHAMPION trial. In the open-label extension, methotrexate treated patients who completed the original 16-week trial were allowed to transition to treatment with adalimumab.37 Results from this population of 95 patients were reported based on an interim analysis and included PASI. In these two studies, the following intermediate health outcomes were evaluated: PASI, PGA, and individual symptom improvement (i.e., VAS for plaque psoriasis and psoriatic arthritis pain and psoriasis-related pruritus assessment).30,37 No additional intermediate health outcomes were reported for patients who transitioned from methotrexate to adalimumab.

In the study by Strober et al., the mean PASI improved for patients at week 16 compared with week zero (2.3 versus 10.8, p=NR), with improvements observed as early as week 2 (Appendix F, Table 8) Engauge Digitizer, Version 2.0 was used to read the reported figure to obtain mean PASIs at all reported time periods (weeks 0, 2, 4, 8, and 16).30 In the CHAMPION extension, PASI improved after patients transitioned to adalimumab for 24 weeks of treatment (PASI 75: 73 percent, PASI 90: 53 percent, PASI 100: 32 percent) compared with PASIs prior to treatment with adalimumab (PASI 75: 28 percent, PASI 90: 14 percent, PASI 100: 5, p=NR).37

In the study by Strober et al., at week 16, 61 percent of patients (95% CI, 45 to 76 percent) who switched from methotrexate to adalimumab had a PGA of “clear” or “minimal”. PGA results for earlier time points (week 0, 2, 4, and 8) are available in Appendix F, Table 7.^30^ Two measures of individual symptom improvement (i.e., VAS for plaque psoriasis and psoriatic arthritis pain and psoriasis-related pruritus assessment) were assessed through week 16. Both symptoms, pain and pruritus, improved at week 16 from baseline [(−14.7±24.4, p=NR) and (−2.9±3.9, p=NR), respectively].30,38

###### Alefacept Versus Cyclosporine

No RCTs or observational studies directly compared the biologic agent alefacept with the nonbiologic agent cyclosporine.

###### Transitions from Cyclosporine to Alefacept

One study by Magliocco et al. evaluated patients who were well-controlled on cyclosporine therapy with a need or desire to switch to alefacept therapy.31 Possible reasons in which a patient necessitated a switch from cyclosporine may have included adverse events, cumulative toxicity, or dose limits for cyclosporine. Well-controlled was defined as a PGA of “mild (5)”, “almost clear (6)” or “clear (7)”. This study was rated as having fair quality and data about whether patients were naïve to treatment were not reported. The study consisted of three phases over 48 weeks to determine if psoriasis control could be maintained while transitioning patients from cyclosporine to alefacept. In phase I (12 weeks), patients received alefacept for 12 weeks and were being tapered off of cyclosporine in weeks 5 through 12. In phase 2 (12 weeks), patients did not receive alefacept or cyclosporine but were allowed to use topical agents and UVB phototherapy. In phase III (24 weeks), patients were treated with alefacept for 12 weeks followed by additional 12 weeks of observation, in which topical and UVB therapy was permitted. Topical therapy was used by three patients (25 percent) in phase II and in phase III. UVB therapy was used by one patient (8 percent) in phase III. Twelve patients began this study and completed phase I, three patients dropped out during phase II, and 2 patients dropped out during phase III. Therefore, six patients (50 percent) completed the 48 week study.

One measure of HRQoL, the DLQI, was evaluated throughout the course of this study.31 The mean DLQI score was lower after phase I in comparison with the baseline mean (1.09 versus 3.18, p=NR) and increased to a value higher than baseline at the end of phase II (4.88 versus 3.18, p=NR). After the second treatment course administered during phase III, the mean DLQI value was 3.14 (p=NR), and then increased slightly to 3.83 at the end of the observation period during phase III (48 weeks). Authors concluded that the quality of life was improved or maintained in all patients during phase I and that no significant changes in quality of life were observed in patients who completed the study. No additional final health outcomes were reported.

One intermediate outcome, the PGA, was measured in this study.31 At baseline, 11 of 12 patients had a PGA of “mild (5)” and one patient had a PGA of “moderate to severe (2)”. After phase I, the majority of patients maintained the same PGA (7 of 11, 64 percent) and all patients remained within one category of their baseline PGA. After phase II (Week 25), the mean PGA was 4.75. During phase III, the mean PGA was 4.33 at the end of the second treatment course and maintained through week 48 (mean PGA of 4.33). Authors concluded that the PGA remained stable during phase I and response to alefacept was maintained during the observation period in the majority of patients. No additional intermediate health outcomes were reported.

###### Etanercept Versus Acitretin

Three RCTs compared the biologic agent etanercept with the nonbiologic agent acitretin.22–24

The first RCT by Caproni et al. was rated as having fair quality while the second trial by Gisondi et al. was rated as having good quality. The third RCT (herein clinical trial 5) that was rated as having poor quality has not been published as a manuscript and the data were extracted from www.clinicaltrials.gov. 24 In the trial by Caproni et al. the percent of treatment naïve patients was not reported and individuals were allowed into the trial as long as treatment with either topical or systemic therapy was greater than one month prior to enrollment. In the trial by Gisondi et al. all patients were naïve to biologic therapy as prior use was an exclusion criterion. Patients were allowed into the trial as long as treatment with either topical, systemic, or phototherapy was greater than four weeks prior to enrollment. In clinical trial 5, all patients were naïve to TNF inhibitors, efalizumab, and alefacept. The following final health outcomes were reported: psychological comorbidities (e.g. depression) and other patient-reported outcomes [i.e., Psoriasis Subject Satisfaction Questionnaire (PSSQ)].24 In clinical trial 5, one in eighteen patients (5.6 percent) on acitretin reported depression versus none in 21 patients taking etanercept (p=NR) at 24 weeks. Although clinical trial 5 evaluated the PSSQ, the overall score was not reported.

Within the three RCTs, the following intermediate outcomes were reported: BSA, PASI, PGA, and symptom improvement [e.g. Subject Global Assessment (SGA) of psoriasis, SGA of joint pain, SGA of itching].22–24 Two trials evaluated the affected BSA at 24 weeks. Gisondi et al. found that patients treated with etanercept had a greater percentage of BSA improvement (80 percent) compared with patients treated with acitretin (45.8 percent, p=NR).23 In clinical trial 5, patients treated with etanercept had a greater mean change from baseline in BSA (−17.52 ± 14.91 versus −10.30 ± 18.86, p=NR) compared with patients treated with acitretin at week 24 as well as other shorter periods of follow-up (Appendix F, Table 7). All three trials evaluated PASI 50 and PASI 75. In the trial by Gisondi et al. a significantly higher proportion of patients treated with etanercept achieved PASI 50 (68 percent versus 50 percent, p=0.001) and PASI 75 (45 percent versus 30 percent, p=0.001) compared with acitretin at week 24, the longest duration of followup for this outcome.23 Statistically significant differences between etanercept and acitretin were seen as early as 12 weeks (p=0.001) for both PASI 50 and PASI 75 and remained significant at week 18 (p=0.001) for both outcomes (Appendix F, Table 8). In the trial by Caproni et al. the proportion of patients in the etanercept group achieving PASI 50 (87 percent versus 67 percent, p=NR) and PASI 75 (57 percent versus 27 percent, p=NR) was higher compared with acitretin.22 The mean PASI was significantly reduced at week 12 when compared with baseline in both treatment groups.22 The mean baseline PASI in the etanercept group was 21.54±9.09 compared with the mean PASI at week 12 of 4.61±2.75, p<0.001. The mean baseline PASI in the acitretin group was 22.25± 5.73 compared with the mean PASI at week 12 of 9.62±4.64, p<0.001. The mean PASI was significantly lower in the etanercept group compared with acitretin at week 12 (p=0.005). In clinical trial 5, the proportion of patients in the etanercept group achieving PASI 50 (71.43 percent versus 44.44 percent, p=NR) and PASI 75 (52.38 percent versus 22.22 percent, p=NR) was higher compared with acitretin at week 24 as well as other shorter periods of followup (Appendix F, Table 8). 24 The mean PASI was reduced in both treatment groups from baseline at 24 weeks as well as shorter periods of followup (Appendix F, Table 8). The mean baseline PASI in the etanercept group was 20.83 ± 14.02 and was reduced by 12.16 ± 12.15 at week 24 (p=NR). In the acitretin group, the mean baseline PASI of 26.31 ± 13.63 was reduced by 9.62 ± 10.10 at week 24 (p=NR).

One RCT 24 evaluated the proportion of patients achieving a PGA of clear or almost clear, mean SGA of joint paint and mean SGA of itching. A higher percent of patients in the etanercept group (52.38 percent versus 44.44 percent, p=NR) achieved a PGA of clear or almost clear compared with acitretin at week 24, as well as shorter periods of followup (Appendix F, Table 7). The mean PGA was reduced from baseline in both groups. In the etanercept group, the mean baseline PGA was 3.40 ± 0.82 and decreased by 1.67 ± 1.47 at week 24 (p=NR). In the acitretin group, the mean baseline PGA of 3.50 ± 0.92 was reduced by 0.71 ± 1.37 at week 24 (p=NR). The mean PGA decreased to a greater extent in the etanercept group compared with the acitretin group at shorter periods of followup as well (Appendix F, Table 7). The change from baseline in mean SGA of psoriasis at week 24 was −1.81± 2.20 in the etanercept group versus −1.72 ± 1.93 in the acitretin group (p=NR).The mean SGA of joint pain increased in the etanercept group and decreased in the acitretin group from baseline, increasing by 0.29 ± 1.06 at week 24, from a baseline of 0.67 ± 1.43 (p=NR) in the etanercept group and decreasing by 0.61 ± 2.03 at week 24, from a baseline of 0.94 ± 1.73 (p=NR) in the acitretin group. The last intermediate outcome evaluated in clinical trial 5 was SGA of itching. In the etanercept group, the mean SGA of itching decreased by 1.19 ± 2.23 at week 24 from a baseline score of 3.33 ± 1.35 (p=NR). In the acitretin group, the mean SGA of itching decreased by 1.06 ± 1.89 at week 24, from a baseline of 3.72 ± 1.45 (p=NR)

###### Etanercept Versus Cyclosporine

There were no RCTs or observational studies that directly compared the biologic agent etanercept with the nonbiologic agent cyclosporine.

###### Transitions From Cyclosporine to Etanercept

One observational study by Garavaglia et al. evaluated patients with hepatitis C virus who had been previously treated with cyclosporine and were currently receiving etanercept treatment.29 This study was rated as having poor quality and data about whether patients were naïve to treatment or not were not reported. PASI was the only intermediate health outcome reported at baseline, 3, 6, 12, 18, and 24 months and no final health outcomes were reported. All four patients who switched from cyclosporine to etanercept therapy showed an improvement in mean PASIs at week 52 (22.5, 23.8, 22.4, and 27.3 at baseline versus 5.6, 3.7, 0, and 8.4 at week 52, p=NR). Two of the four patients had PASIs reported at 104 weeks and continued to show comparable mean PASIs as in week 52 (0 and 8.3 at week 104 versus 5.6 and 8.4 at week 52, p=NR).

###### Etanercept Versus Methotrexate

There were no RCTs that directly compared the biologic agent etanercept with the nonbiologic agent methotrexate.

Two observational studies compared the biologic etanercept with the nonbiologic methotrexate.26, 28 In the study by Gisondi et al., rated with fair quality, patients treated with etanercept were naïve to biologic therapy.26 The second study by Gelfand et al., was rated with fair quality and 187 out of 713 (25.8 percent) patients were naïve to any psoriasis treatment. 28 The following final health outcome was evaluated in these studies: HRQoL (i.e. DLQI).28

In the study by Gelfand et al. the median DLQI score was 2 (interquartile range of 1 to 5) in patients treated with etanercept and 3 (interquartile range of 1 to 5) in patients treated with methotrexate (p=NR). When the DLQI score was analyzed as a dichotomous outcome (i.e., number of patients with response defined as no effect or a small effect of psoriasis on quality of life indicated by the DLQI score less than equal to 5), a similar proportion of patients treated with etanercept achieved the response (75.5 percent; 95% CI, 68.7 to 81.5) compared with methotrexate (77.4 percent; 95% CI, 70.6 to 83.4; p=NR).28

The intermediate outcomes evaluated in these observational studies include: BSA, PASI and PGA. Both studies evaluated PASI. In first study by Gisondi, the mean PASI significantly decreased from baseline to 6 months in the etanercept (18.8±7.4 versus 4.8±4.7, p=0.0001) and in the methotrexate groups (8.2±3.1 versus 4.3±6, p=0.0002), although between group comparisons were not made. The mean percent reduction in PASI was statistically significant within each group: 74.5 percent in the etanercept group (p=0.0001 versus baseline) and 47.1 percent in the methotrexate group (p=0.0002 versus baseline). 26 In the second study by Gelfand et al., the median PASI was 2.9 (interquartile range of 1.8 to 4.9) in patients treated with etanercept and 3.8 (interquartile range of 1.8 to 6.6) in patients treated with methotrexate (p=NR).28

The study by Gelfand et al. also evaluated BSA and PGA.28 The median BSA percentage was 2.0 (interquartile range of 0.5 to 4.5) in patients treated with etanercept and 3.0 (interquartile range of 1.0 to 6.0) in patients treated with methotrexate (p=NR). 28 The median PGA was 1.7 (interquartile range of 1.0 to 2.0) in patients treated with etanercept and 1.7 (interquartile range of 1.3 to 2.0) for patients treated with methotrexate (p=NR). When the PGA was analyzed as a dichotomous outcome (i.e., number of patients with response defined as “clear” or “minimal” indicated by the PGA less than equal to 1), a significantly higher proportion of patients treated with etanercept achieved the response compared with methotrexate (adjusted relative rate of 1.45; 95% CI, 1.06 to 1.97).28

###### Infliximab Versus Methotrexate

One RCT and one observational study directly compared the biologic agent infliximab with the nonbiologic agent methotrexate.21,26

The RCT by Barker et al., rated with fair quality, compared the biologic agent infliximab with the nonbiologic agent methotrexate.21 Patients enrolled in this trial were naïve to methotrexate therapy and were not treated with any systemic biologic agents within 3months of baseline. Therapy with topical agents or systemic therapies that could affect PASI were discontinued two and four weeks, respectively, prior to the start of the study.

In this RCT, patients were followed for 26 weeks, although at week 16, patients who did not achieve PASI 50 or who were intolerant to assigned therapy could switch from assigned therapy to the other intervention.21 After week 16, patients were evaluated in the groups in which they were taking therapy, not in the groups in which they were originally randomized. Additionally, patients who switched therapy were considered PASI nonresponders at week 26. A total of 29 percent of patients originally randomized to receive methotrexate switched to infliximab at week 16 whereas only one percent of patients randomized to infliximab switched to methotrexate at week 16. Therefore, for all final and intermediate health outcomes, we report the 16 week followup as the maximal duration of followup when possible. When alternate time periods are reported, an explanation accompanies the results.

This trial evaluated the following final health outcomes: HRQoL, myocardial infarction (a component of MACE), and diabetes mellitus.21 No additional final health outcomes were reported for the comparison of infliximab with methotrexate and no observational data were available for final health outcomes. Three measures of HRQoL were evaluated, the DLQI, the EQ-5D, and the mental (MCS) and physical (PCS) components of the SF-36.^21^ At 16 weeks, all scales demonstrated a favorable result in the infliximab treated patients compared with methotrexate. The mean change in DLQI at 16 weeks from baseline was significantly greater in the infliximab group compared with methotrexate (−11.6 versus −8.95, p<0.001). The mean EQ-5D score was significantly greater in the infliximab group compared with methotrexate (0.86 versus 0.84, p<0.05). Differences between infliximab and methotrexate were statistically significant in the change in DLQI (−11.4 versus −7.9, p<0.001) and in the mean EQ-5D score (0.86 versus 0.81, p<0.05) as early as 10 weeks, the first time period in which these outcomes were evaluated. The mean change in the PCS of the SF-36 was significantly greater in the infliximab group compared with the methotrexate group (5.53 versus 3.76, p<0.002) at 16 weeks. The mean change in the PCS was also significantly greater in the infliximab group at 10 weeks compared with methotrexate (5.15 versus 3.00, p<0.001). The mean change in the MCS was significantly greater in the infliximab group at week 10 compared with methotrexate (7.94 versus 5.63, p<0.041), while results at week 16 were not reported.

Myocardial infarction and diabetes mellitus were not reported in the original publication21 although data were reported on www.clinicaltrials.gov for all patients who did not switch therapy through week 26 including data through week 16 for patients who did switch therapy.39 One case of myocardial infarction was reported in the methotrexate group (0.47 percent) while no cases occurred in the infliximab group (p=NR). One case of diabetes was reported in the infliximab group (0.15 percent) while no cases occurred in the methotrexate group (p=NR).

The RCT by Barker et al. evaluated the following intermediate health outcomes: PASI and PGA.21 No other intermediate health outcomes were evaluated for the comparison of infliximab with methotrexate. When compared with methotrexate, more patients who received infliximab achieved PASI 50 (86.8 percent versus 60.5 percent, p<0.001), PASI 75 (77.8 percent versus 41.9 percent, p<0.001), and PASI 90 (54.4 percent versus 19.1 percent, p<0.001) at 16 weeks. Investigators also evaluated these PASI outcomes at weeks 2, 6, 10 and 14. (Appendix F, Table 8) More patients treated with infliximab achieved PASI 50 and PASI 75 at all time periods (p<0.001) compared with methotrexate with significant effects observed as soon as 2 weeks. As for PASI 90, significant differences between treatment groups (p<0.001) were observed as early as 6 weeks and were maintained subsequently. The median time to PASI 75 was shorter in infliximab treated patients compared with methotrexate [46 days (95% CI, 45 to 50) versus 127 days (95% CI, 113 to 154); p<0.0001]. Authors reported that the mean change in PASI from baseline was significantly greater (p<0.001) in the infliximab group compared with methotrexate at all time periods evaluated (weeks 2, 6, 10, 14, p<0.001) although the magnitude of effect was not reported. PGA was evaluated at 16 weeks and there was a significantly greater number of patients with PGAs of “cleared” or “minimal” in the infliximab treated group compared with methotrexate (76 percent versus 38 percent, p<0.001). No other intermediate outcomes were reported in patients as randomized.

In this RCT, patients were followed for 26 weeks, although outcomes reported at weeks 18, 22, and 26 consider patients who switched therapy at week 16 nonresponders.21 At week 26, the mean change in DLQI from baseline was significantly greater in the infliximab group compared with methotrexate (−11.3 versus −9.14, p<0.004. At week 26, the mean EQ-5D score was significantly greater in the infliximab group compared with methotrexate (0.86 versus 0.81, p<0.05). At week 26, a greater number of patients in the infliximab group achieved PASI 50 (81 percent versus 47.9 percent, p<0.001), PASI 75 (76.8 percent versus 30.7 percent, p<0.001), and PASI 90 (51 percent versus 14.9 percent, p<0.001). Findings were similar for these outcomes at weeks 18 and 22, where infliximab had a significantly greater number of patients achieving PASI improvement compared with methotrexate (Appendix F, Table 8). The mean percent change in PASI from baseline to week 26 was also greater in the infliximab group compared with methotrexate (85 percent versus 54 percent, p<0.001). Authors reported that the mean change in PASI from baseline was significantly greater (p<0.001) in the infliximab group compared with methotrexate at weeks 18 and 22 as well, although the magnitude of effect was not reported.

One observational study compared the biologic infliximab with the nonbiologic methotrexate.26 In this study by Gisondi et al., rated with fair quality, patients treated with infliximab were naïve to biologic therapy.26 The only intermediate outcome reported was PASI. The mean PASI significantly decreased from baseline to 6 months in the infliximab (17.7±7.3 versus 2.1±3.2, p=0.0001) and in the methotrexate groups (8.2±3.1 versus 4.3±6, p=0.0002), although between group comparisons were not made. The percent reduction of mean PASIs was statistically significant within each group: 88.8 percent in the infliximab group (p=0.0001 versus baseline) and 47.1 percent in the methotrexate group (p=0.0002 versus baseline).

###### Transitions Between Infliximab and Methotrexate

In the trial by Barker et al, patients who did not respond to or were intolerant to randomized therapy were given the option of switching therapies from infliximab to methotrexate and vice-a-versa after week 16.^21^ A total of 9 patients (1 percent) randomized to infliximab switched to methotrexate and 63 patients (29 percent) randomized to methotrexate switched in infliximab.21

In terms of final health outcomes, no myocardial infarctions or cases of diabetes mellitus occurred in any of the patients that switched therapy at 16 weeks.39

PASI and PGA were intermediate outcomes evaluated in the transition populations.21 At week 26, a greater proportion of patients that switched to infliximab from methotrexate achieved PASI 75 (46 of 63 patients, 73 percent) or PASI 90 (47.6 percent) compared with patient who switched to methotrexate (1 of 9 patients, 11.1 percent; no patients achieved PASI 90, p=NR). Findings were similar for PASI 75 and PASI 90 at weeks 18 and 22 as well (Appendix F, Table 8). Similarly, a greater proportion of patients achieved “clear” or “minimal” on the PGA in the infliximab group (47 of 63, 75 percent) compared with the methotrexate group (2 of 9, 22 percent, p=NR) at week 26. Weeks 18 and 22 demonstrated a similar trend (Appendix F, Table 7).

###### Ustekinumab Versus Methotrexate

There were no RCTs that directly compared the biologic agent ustekinumab with the nonbiologic agent methotrexate.

One observational study compared the biologic ustekinumab with the nonbiologic methotrexate.28 In this study by Gelfand et al., rated with fair quality, 187 out of 713 (25.8 percent) patients were naïve to any psoriasis treatment.28 This study evaluated the following final health outcome: HRQoL (i.e. DLQI).28

The median DLQI was 3 (interquartile range of 1 to 6) in patients treated with ustekinumab and 3 (interquartile range of 1 to 5) for patients treated with methotrexate (p=NR). When the DLQI was analyzed as a dichotomous outcome (i.e., number of patients with response defined as no effect or a small effect of psoriasis on quality of life indicated by the DLQI less than equal to 5), a similar proportion of patients treated with ustekinumab achieved response (71.2 percent; 95% CI, 59.2 to 81.4) compared with methotrexate (77.4 percent; 95% CI, 70.6 to 83.4; p=NR).28

This study also evaluated the following intermediate outcomes: BSA, PASI and PGA.28 A similar median BSA percentage of 3.0 (interquartile range of 0.6 to 9.1) and 3.0 (interquartile range of 1.0 to 6.0) was reported for patients treated with ustekinumab and methotrexate, respectively (p=NR).28 The median PASI was 4.0 (interquartile range of 1.0 to 7.9) in patients treated with ustekinumab and 3.8 (interquartile range of 1.8 to 6.6) in patients treated with methotrexate (p=NR). In addition, a similar median PGA of 1.7 (interquartile range of 1.0 to 2.1) and 1.7 (interquartile range of 1.3 to 2.0) was reported for patients treated with ustekinumab and methotrexate, respectively (p=NR). When the PGA was analyzed as a dichotomous outcome (i.e., number of patients with response defined as “clear” or “minimal” indicated by the PGA less than equal to 1), a significantly higher proportion of patients treated with ustekinumab achieved the response compared with methotrexate (adjusted relative rate of 1.57; 95% CI, 1.06 to 2.32).28

###### Indirect Comparisons

One systematic review by Bansback et al. evaluated the comparative efficacy of various treatments for chronic plaque psoriasis using a Bayesian mixed-treatment comparison.34 RCTs evaluating adalimumab, alefacept, efalizumab, etanercept, infliximab, retinoids, methotrexate, cyclosporine, phototherapy, and combination therapy in patients with moderate to severe psoriasis were included. Additionally, for a therapy to be included, either a direct or indirect link to placebo was required. Because of this, acitretin and phototherapy were excluded because no link to placebo was identified in the literature. Overall, the quality of this analysis was good.

A total of 22 trials (n=9,917) were included in the analysis. The authors reported a mean Jadad score of 4.3 and considered the quality of included studies high. The outcomes evaluated in this analysis were PASI 50, PASI 75, and PASI 90 and the probability of a given therapy achieving each outcome was reported (Table 6). Although relative risks were also reported, they were relative to placebo treatment and estimates of direct drug comparisons were not reported. Regardless of the PASI outcome evaluated, infliximab had the highest probability of achieving the outcome followed by adalimumab, etanercept, methotrexate, cyclosporine, efalizumab, alefacept, and finally supportive care. Of note, efalizumab data are not included in our report as they do not carry a current FDA indication. Overall, the three biologic agents that comprise the TNF-alpha blocker class (i.e., infliximab, adalimumab, and etanercept) individually had higher probabilities of achieving a given PASI than either of the nonbiologic systemic agents (i.e., methotrexate and cyclosporine) included in the analysis. The nonbiologics individually had higher probabilities of achieving a given PASI than the biologic agent alefacept.

Table 6 Results from Bansback et al.

Therapy | Probability of Response PASI 50 %, (95% CI) | Probability of Response PASI 75 %, (95% CI) | Probability of Response PASI 90 %, (95% CI)
Supportive care | 14 (12–16) | 4 (4–5) | 1 (1–1)
Etanercept 50 mg twice/wk | 74 (67–80) | 50 (43–58) | 22 (17–28)
Efalizumab 1 mg/kg^*^ | 53 (48–59) | 28 (24–34) | 9 (7–12)
Infliximab 5 mg/kg | 93 (91–96) | 81 (75–86) | 54 (47–63)
MTX 15–22.5 mg/wk | 66 (51–77) | 42 (27–54) | 17 (9–26)
Cyclosporine 3 mg/kg/d | 57 (37–73) | 33 (17–49) | 11 (4–21)
Adalimumab 40 mg every other wk | 88 (83–93) | 71 (63–79) | 42 (33–52)
Alefacept 15mg IM 1/wk | 34 (25–43) | 15 (9–21) | 4 (2–6)

CI = confidence interval; d = day(s); IM = intramuscular; kg = kilogram(s); mg = milligram(s); MTX = methotrexate; PASI = Psoriasis Area and Severity Index; wk = week(s)

* Efalizumab (not our comparison of interest) administered every 8 weeks following doses at 0, 2, and 6 weeks.

###### Class-Level Comparisons

Three observational studies reported data comparing biologic agents with nonbiologic agents at the class level.26,32,33 One study directly compared classes26 while two studies observed transitions of therapy from nonbiolgics to biologics.32,33

One observational study by Gisondi et al., rated with fair quality, compared treatment with biologics (etanercept or infliximab) with treatment with the nonbiologic methotrexate.26 Patients treated with biologics were naïve to biologic therapy. No final health outcomes were evaluated in this study and the only intermediate outcome reported was PASI. The mean improvement in PASIat 6 months was significantly lower in the methotrexate (47.6 percent) group compared with etanercept (74.5 percent) or infliximab (88.8 percent) collectively (p-value for comparison of methotrexate versus etanercept or infliximab=0.0004).

###### Transitions Between Biologics and Nonbiologics

Two observational studies evaluated the transition between biologics and nonbiologics.32,33 No studies evaluated final health outcomes in this comparison of interest. The first study by Costanzo et al., rated with fair quality, was an open-label compassionate use study in which patients who failed or had adverse events to at least one nonbiologic systemic agent (systemic corticosteroids, cyclosporine, methotrexate, and/or retinoids) in the past were treated with etanercept.33 The majority of patients had also been previously treated with topical steroids (75 percent, 33 out of 44 patients) The interim results of this study were reported where all patients (44 patients) had data at week 12 and 15 patients (34.1 percent) had data at week 24. No final health outcomes were evaluated.

One intermediate outcome, PASI, was measured in this study.33 PASI was reported at weeks 0, 12, and 24. The mean PASI at baseline was 15.6 and decreased to 7.5 and 4.3 at weeks 12 and 24, respectively (p=NR). Corresponding percent improvement in the mean PASI from baseline to week 12 was 52 percent and to week 24 was 72 percent. At week 24, the number of patients with PASI 50 (12 of 15 patients, 80 percent) or PASI 75 (10 of 15 patients, 67 percent) was significantly greater compared with the number with PASI 50 (28 of 44 patients, 64 percent) or PASI 75 (19 of 44 patients, 43 percent) at 12 weeks (p<0.05 for both comparisons). The number of patients achieving PASI 90 was higher at 24 weeks (6 of 15 patients, 40 percent) compared with 12 weeks (4 of 44 patients, 9 percent, p=NR).

The second study by Mazzotta et al., rated with fair quality, also observed treatment of patients with etanercept who had previously been treated with nonbiologic systemic agents or phototherapy (cyclosporine, corticosteroids, fumaric acid esters, methotrexate, retinoids, and PUVA).32 Patients were included if they failed nonbiologic therapy (according to PASI and pain scores), had an adverse event to nonbiologic therapy, or were noncompliant with nonbiologic treatment. The percentage of patients in each of these categories was not reported by the study. Most patients (98 of 124, 79 percent) were naïve to systemic biologics. No final health outcomes were evaluated.

One intermediate outcome, PASI, was measured in this study.32 The mean PASI was significantly lower at 24 weeks compared with baseline (2.8±3.4 versus 16.1±7.1, p<0.0001) and compared with 12 weeks (2.8±3.4 versus 4.9±4.0, p<0.0001). At 24 weeks, 88 of 98 patients (89.9 percent) and 74 of 98 (75.3 percent) patients achieved PASI 50 and PASI 75, respectively. At 12 weeks, 79 of 98 patients (80.2 percent) and 43 of 98 (43.7 percent) patients achieved PASI 50 and PASI 75, respectively.

##### Systemic Biologic Agents Versus Phototherapy

###### Adalimumab Versus NB-UVB

There were no RCTs that directly compared the biological agent adalimumab with NB-UVB.

One observational study compared the biologic adalimumab with NB-UVB.28 In this study by Gelfand et al., rated with fair quality, 187 out of 713 (25.8 percent) patients were naïve to any psoriasis treatment.28 This study evaluated the following final health outcome: HRQoL (i.e. DLQI).28

The median DLQI was 2 (interquartile range of 0 to 5) for patients treated with adalimumab and 3 (interquartile range of 1 to 7) for patients treated with NB-UVB (p=NR). When the DLQI score was analyzed as a dichotomous outcome (i.e., number of patients with response defined as no effect or a small effect of psoriasis on quality of life indicated by the DLQI score less than equal to 5), a similar proportion of patients treated with adalimumab achieved the response (78.0 percent; 95% CI, 70.5 to 84.3) compared with NB-UVB (68.3 percent; 95% CI, 59.2 to 76.5; p=NR).28

This study also evaluated the following intermediate outcomes: BSA, PASI and PGA.28 A lower median BSA percentage of 2.0 (interquartile range of 0.7 to 5.0) was reported in patients receiving adalimumab compared with a median BSA percentage of 3.3 (interquartile range of 1.0 to 6.5) in patients receiving NB-UVB (p=NR).28 The median PASI was 2.5 (interquartile range of 1.2 to 4.8) in patients receiving adalimumab and 3.5 (interquartile range of 2.0 to 5.5) in patients treated with NB-UVB (p=NR). In addition, a similar median PGA of 1.3 (interquartile range of 1.0 to 1.7) and 1.7 (interquartile range of 1.0 to 2.0) was reported for patients treated with adalimumab and NB-UVB, respectively (p=NR). When the PGA was analyzed as a dichotomous outcome (i.e., number of patients with response defined as “clear” or “minimal” indicated by the PGA less than equal to 1), a higher proportion of patients treated with adalimumab achieved the response (47.7 percent; 95% CI, 39.5 to 56.0) compared with NB-UVB (27.6 percent; 95% CI, 20.0 to 36.4; p=NR).28

###### Transitions Between Adalimumab and NB-UVB Phototherapy

One nonrandomized open-label study by Strober et al. evaluated patients who had a suboptimal response to NB-UVB phototherapy, defined as a PGA of “moderate” or worse after at least two months of therapy.30 Patients stopped NB-UVB phototherapy four to 10 days prior to transitioning to adalimumab treatment. This study was rated as having fair quality. All patients were naïve to adalimumab and natalizumab, and whether patients were naïve to other therapies was not reported. The following final health outcomes were evaluated: mortality, HRQoL (e.g., DLQI), and impact of psoriasis on activities of daily living (e.g., work time missed, overall work impairment, impairment while working, and activity impairment due to psoriasis). No additional final health outcomes were reported for patients who transitioned from NB-UVB to adalimumab.

In this study, there were no deaths reported through week 16. The mean change in DLQI from baseline to weeks 4 and 16 improved [(−5.2±5.45, p=NR) and (−6.5±6.44, p=NR), respectively].30,38 Corresponding standard deviations were not reported in the original publication but were reported separately in the results available on www.clinicaltrials.gov. Measures of the impact of psoriasis on activities of daily living were reported in the results available on www.clinicaltrials.gov.30,38 At week 16, patients showed improvement in the mean percent change of overall work impairment due to psoriasis (−6.4±19.8 percent, p=NR), impairment while working due to psoriasis (−8.0±19.4 percent, p=NR), and activity impairment due to psoriasis (−12.2± 25.6 percent, p=NR). However, there was no improvement in the mean percent work time missed due to psoriasis (1.3 ± 4.8 percent, p=NR).38

This study also evaluated the following intermediate health outcomes: PASI, PGA, and individual symptom improvement (i.e., VAS for plaque psoriasis and psoriatic arthritis pain and psoriasis-related pruritus assessment).30 No additional intermediate health outcomes were reported for patients who transitioned from NB-UVB phototherapy to adalimumab.

The mean PASI improved at week 16 compared with week 0 in patients who switched from NB-UVB phototherapy to adalimumab (3.6 versus 12.4, p=NR) with improvements observed as early as week 2 (Appendix F, Table 8). Engauge Digitizer, Version 2.0 was used to read the reported figure to obtain values for mean PASI at all reported time periods (week 0, 2, 4, 8, and 16). At week 16, 48 percent of patients (95% CI, 29 percent to 67 percent) who transitioned from NB-UVB phototherapy to adalimumab had a PGA of “clear” or “minimal”. PGA results for earlier time periods (week 0, 2, 4, and 8) are available in Appendix F, Table 7.

Two measures of individual symptom improvement (i.e., VAS for plaque psoriasis and psoriatic arthritis pain and psoriasis-related pruritus assessment) were assessed through week 16. Both symptoms, pain and pruritus, improved at week 16 from baseline [(−21.4±30.0, p=NR) and (−3.0±2.96 p=NR), respectively].30,38

###### Etanercept Versus NB-UVB

There were no RCTs that directly compared the biologic agent etanercept with NB-UVB. Two observational studies compared the biologic etanercept with NB-UVB.27,28 In the first study by Gelfand et al., rated with fair quality, 187 out of 713 (25.8 percent) patients were naïve to any psoriasis treatment.28 This study evaluated the following final and intermediate health outcomes: HRQoL (i.e. DLQI), BSA, PASI and PGA. 28 The second study by Emerit et al., was rated with poor quality and subjects in the NB-UVB group were naïve to phototherapy and systemic nonbiologics.27 The only outcome of interest reported was the intermediate outcome PASI at week 12, though subjects in the phototherapy group were also followed up at week 32.^27^

The median DLQI was 2 (interquartile range of 1 to 5) for patients treated with etanercept and 3 (interquartile range of 1 to 7) for patients treated with NB-UVB (p=NR).28 When the DLQI score was analyzed as a dichotomous outcome (i.e., number of patients with response defined as no effect or a small effect of psoriasis on quality of life indicated by the DLQI score less than equal to 5), a higher proportion of patients treated with etanercept achieved the response (78.0 percent; 95% CI, 70.5 to 84.3) compared with NB-UVB (68.3 percent; 95% CI, 59.2 to 76.5; p=NR).28

The following intermediate outcomes were evaluated: BSA, PASI and PGA.27,28 A lower median BSA percentage of 2.0 (interquartile range of 0.5 to 4.5) was reported in patients receiving etanercept compared with a median BSA percentage of 3.3 (interquartile range of 1.0 to 6.5) in patients receiving NB-UVB (p=NR).28 The median PASI was 2.9 (interquartile range of 1.8 to 4.9) in patients treated with etanercept and 3.5 (interquartile range of 2.0 to 5.5) in patients treated with NB-UVB (p=NR).28 In the second study by Emerit et al., there was a significant reduction in mean PASI for both groups at week 12 although there was no comparison made of the change in PASI observed between etanercept and NB-UVB.27 In the etanercept group, PASI was reduced from 21.4 ± 6.1 at baseline to 3.7 ± 1.2 (p<0.05) at week 12. In the NB-UVB group, PASI was reduced from 21.3 ± 5.2 at baseline to 3.7 ± 1.2 (p<0.05) at week 12. 27 Subjects in the PUVA group were also examined at week 32, after discontinuation of the treatment at week 12, and the mean PASI increased to 10.8 ± 2.2 (p<0.05 versus week 12). 27 In addition, a similar median PGA of 1.7 (interquartile range of 1.0 to 2.0) and 1.7 (interquartile range of 1.0 to 2.0) was reported for patients treated with etanercept and NB-UVB, respectively (p=NR). When the PGA was analyzed as a dichotomous outcome (i.e., number of patients with response defined as “clear” or “minimal” indicated by the PGA less than equal to 1), a higher proportion of patients treated with etanercept achieved the response (34.2 percent; 95% CI, 27.5 to 41.4) compared with NB-UVB (27.6 percent; 95% CI, 20.0 to 36.4; p=NR).28

###### Ustekinumab Versus NB-UVB

There were no RCTs that directly compared the biologic agent ustekinumab with NB-UVB.

One observational study compared the biologic ustekinumab with NB-UVB.28 In this study by Gelfand et al., rated with fair quality, 187 out of 713 (25.8 percent) patients were naïve to any psoriasis treatment.28 This study evaluated the following final and intermediate health outcomes: HRQoL (i.e. DLQI), BSA, PASI and PGA.28

The median DLQI was 3 (interquartile range of 1 to 6) in patients treated with ustekinumab and 3 (interquartile range of 1 to 7) in patients treated with NB-UVB (p=NR). When the DLQI score was analyzed as a dichotomous outcome (i.e., number of patients with response defined as no effect or a small effect of psoriasis on quality of life indicated by the DLQI score less than equal to 5), a higher proportion of patients treated with ustekinumab achieved the response (71.2 percent; 95% CI, 59.2 to 81.4) compared with NB-UVB (68.3 percent; 95% CI, 59.2 to 76.5; p=NR).28

This study also evaluated the following intermediate outcomes: BSA, PASI and PGA.28 A similar median BSA percentage of 3.0 (interquartile range of 0.6 to 9.1) and 3.3 (interquartile range of 1.0 to 6.5) were reported for patients treated with ustekinumab and NB-UVB, respectively (p=NR).28 The median PASI was 4.0 (interquartile range of 1.0 to 7.9) in patients treated with ustekinumab and 3.5 (interquartile range of 2.0 to 5.5) in patients treated with NB-UVB (p=NR). In addition, a similar median PGA of 1.7 (interquartile range of 1.0 to 2.1) and 1.7 (interquartile range of 1.0 to 2.0) was reported for patients treated with ustekinumab and NB-UVB, respectively (p=NR). When the PGA was analyzed as a dichotomous outcome (i.e., number of patients with response defined as “clear” or “minimal” indicated by the PGA less than equal to 1), a higher proportion of patients treated with ustekinumab achieved the response (36.1 percent; 95% CI, 25.1 to 48.3) compared with patients receiving NB-UVB (27.6 percent; 95% CI, 20.0 to 36.4; p=NR).28

###### Infliximab Versus NB-UVB

There were no RCTs identified for this comparison of interest. One observational study by Emerit et al. evaluated the comparison of the biologic agent etanercept versus NB-UVB.27 This study was rated with poor quality and subjects in the NB-UVB group were naïve to phototherapy and systemic nonbiologics.27 The only outcome of interest reported was the intermediate outcome PASI at week 12, though subjects in the phototherapy group were also followed up at week 32.There was a significant reduction in mean PASI for both groups at week 12, although there was no comparison made of the change in PASI observed between etanercept and NB-UVB. In the infliximab group, PASI was reduced from 22.3 ± 6.5 at baseline to 2.1 ± 0.7 (p<0.05) at week 12. In the NB-UVB group, PASI was reduced from 21.3 ± 5.2 at baseline to 3.7 ± 1.2 (p<0.05) at week 12. Subjects in the NB-UVB group were also examined at week 32, after discontinuation of the treatment at week 12, and the mean PASI increased to 10.8 ± 2.2 (p<0.05 versus week 12).

###### Adalimumab Versus PUVA

There were no RCTs identified for this comparison of interest. One observational study evaluated the comparison of the biologic agent adalimumab versus PUVA.25 No studies evaluated final health outcomes in this comparison of interest.

The study by Inzinger et al. compared a variety of biologics to PUVA but reported results by individual drug.25 In this study, the oral portion of PUVA was either with 8-methoxypsoralen (MOP) or 5-MOP. Only the 8-MOP data were considered since 5-MOP is not FDA approved. This study was rated with fair quality and patients were not naïve to treatment since inclusion was based on having treatment with oral PUVA and/or at least one course of biologics. Some patients in this study also received treatment with the nonbiologic acitretin although data excluding these patients were reported in the trial and are presented here. Additionally, results of this study were reported in terms of treatment course, not patients. The only outcome reported in this trial was the intermediate outcome PASI, at week 12 for biologics and at the end of PUVA therapy (median 10.3 weeks) for the PUVA group. A lower proportion of adalimumab treatment courses resulted in complete clearance (6 percent versus 21 percent, p=NR), PASI 90 (22 percent versus 70 percent, p=NR), PASI 75 (56 percent versus 89 percent, p=NR), and PASI 50 (72 percent versus 92 percent, p=NR) when compared with PUVA therapy.

###### Alefacept Versus PUVA

There were no RCTs identified for this comparison of interest. No studies evaluated final health outcomes in this comparison of interest. One observational study by Inzinger et al. compared a variety of biologics with PUVA but reported results by individual drug.25 In this study, the oral portion of PUVA was either with 8-MOP or 5-MOP and only the 8-MOP data were considered since 5-MOP is not FDA approved. This study was rated with fair quality and patients were not naïve to treatment since inclusion was based on having treatment with oral PUVA and/or at least one course of biologics. Some patients in this study also received treatment with the nonbiologic acitretin. Data were reported excluding those patients and are presented here. Additionally, results were reported in terms of treatment course, not patients. One outcome was reported in this study, the intermediate outcome PASI, at week 12 for biologics and at the end of PUVA therapy that was a median duration of 10.3 weeks for the PUVA group. A lower proportion of alefacept treatment courses results in complete clearance (3 percent versus 21 percent, p=NR), PASI 90 (3 percent versus 70 percent, p=NR), PASI 75 (25 percent versus 89 percent, p=NR), and PASI 50 (63 percent versus 92 percent, p=NR) compared with PUVA therapy.

###### Etanercept Versus PUVA

There were no RCTs identified for this comparison of interest. No studies evaluated final health outcomes in this comparison of interest. Two observational studies evaluated the comparison of the biologic agent adalimumab versus PUVA.25,27

The first study by Inzinger et al. compared a variety of biologics with PUVA but reported results by individual drug.25 In this study, the oral portion of PUVA was either with 8-MOP or 5-MOP and only the 8-MOP data were considered since 5-MOP is not FDA approved. This study was rated with fair quality and patients were not naïve to treatment since inclusion was based on having treatment with oral PUVA and/or at least one course of biologics. Some patients in this study also received treatment with the nonbiologic acitretin. Data were reported excluding those patients and are presented here. Additionally, results were reported in terms of treatment course, not patients. One outcome was reported in this study, the intermediate outcome PASI, at week 12 for biologics and at the end of PUVA therapy which was a median duration of 10.3 weeks for the PUVA group. A lower proportion of treatment courses with etanercept resulted in complete clearance (6 percent versus 21 percent, p=NR), PASI 90 (29 percent versus 70 percent, p=NR), PASI 75 (39 percent versus 89 percent, p=NR), and PASI 50 (84 percent versus 92 percent, p=NR) compared with PUVA therapy.

The second study by Emerit et al. was rated with poor quality and subjects in the PUVA group were naïve to phototherapy and systemic nonbiologics.27 The only outcome of interest reported was the intermediate outcome PASI at week 12, though subjects in the phototherapy group were also followed up at week 32. There was a significant reduction in mean PASI for both groups at week 12 although there was no comparison made of the change in PASI observed between etanercept and NB-UVB. In the etanercept group, PASI was reduced from 21.4 ± 6.1 at baseline to 3.7 ± 1.2 (p<0.05) at week 12. In the PUVA group, PASI was reduced from 21.9 ± 6.3 at baseline to 2.2 ± 1.1 (p<0.05) at week 12. Subjects in the PUVA group were also examined at week 32, after discontinuation of the treatment at week 12, and the mean PASI increased to 7.3 ± 1.8 (p<0.05 versus week 12).

###### Infliximab Versus PUVA

There were no RCTs identified for this comparison of interest. Two observational studies evaluated the intermediate health outcome in this comparison of the biologic agent infliximab with PUVA.25, 27 No data were reported for final health outcomes.

The first study by Inzinger et al. compared a variety of biologics with PUVA but reported results by individual drug.25 In this study, the oral portion of PUVA was either with 8-MOP or 5-MOP and only the 8-MOP data were considered since 5-MOP is not FDA approved. This study was rated with fair quality and patients were not naïve to treatment since inclusion was based on having treatment with oral PUVA and/or at least one course of biologics. Some patients in this study also received treatment with the nonbiologic acitretin. Data were reported excluding those patients and are presented here. Additionally, results were reported in terms of treatment course, not patients. One outcome was reported in this study, the intermediate outcome PASI, at week 12 for biologics and at the end of PUVA therapy which was a median duration of 10.3 weeks for the PUVA group. A higher proportion of treatment courses resulted in complete clearance (29 percent versus 21 percent, p=NR), PASI 90 (71 percent versus 70 percent, p=NR), PASI 75 (100 percent versus 89 percent, p=NR), and PASI 50 (100 percent versus 92 percent, p=NR) compared with PUVA therapy.

The second study by Emerit et al. was rated with poor quality and subjects in the PUVA group were naïve to phototherapy and systemic nonbiologics.27 The only outcome of interest reported was the intermediate outcome PASI at week 12, though subjects in the phototherapy group were also followed up at week 32. There was a significant reduction in mean PASI for both groups at week 12 although there was no comparison made of the change in PASI observed between etanercept and NB-UVB. In the infliximab group, PASI was reduced from 22.3 ± 6.5 at baseline to 2.1 ± 0.7 (p<0.05) at week 12. In the PUVA group, PASI was reduced from 21.9 ± 6.3 at baseline to 2.2 ± 1.1 (p<0.05) at week 12. Subjects in the PUVA group were also examined at week 32, after discontinuation of the treatment at week 12, and the mean PASI increased to 7.3 ± 1.8 (p<0.05 versus week 12).

###### Ustekinumab Versus PUVA

There were no RCTs identified for this comparison of interest. No studies evaluated final health outcomes in this comparison of interest. One observational study by Inzinger et al. compared a variety of biologics to PUVA but reported results by individual drug.25 In this study, the oral portion of PUVA was either with 8-MOP or 5-MOP and only the 8-MOP data were considered since 5-MOP is not FDA approved. This study was rated with fair quality and patients were not naïve to treatment since inclusion was based on having treatment with oral PUVA and/or at least one course of biologics. Some patients in this study also received treatment with the nonbiologic acitretin. Data were reported excluding those patients and are presented here. Additionally, results were reported in terms of treatment course, not patients. One outcome was reported in this study, the intermediate outcome PASI, at week 12 for biologics and at the end of PUVA therapy which was a median duration of 10.3 weeks for the PUVA group. A lower proportion of ustekinumab treatment courses resulted in complete clearance (6 percent versus 21 percent, p=NR), PASI 90 (39 percent versus 70 percent, p=NR), PASI 75 (67 percent versus 89 percent, p=NR), and PASI 50 (89 percent versus 92 percent, p=NR) compared with PUVA therapy.

## Key Question 2

In patients with chronic plaque psoriasis, what is the comparative safety of systemic biologic agents and systemic nonbiologic agents (between-class comparisons) or phototherapy (hepatotoxicity [e.g., AST, ALT], nephrotoxicity [e.g., SCr, GFR], hematologic toxicity [e.g., thrombocytopenia (TCP), anemia, neutropenia], hypertension, alteration in metabolic parameters [e.g., glucose, lipids, weight, BMI, thyroid function], injection site reaction, malignancy, infection, and study withdrawal)?

### Key Points

- The literature base for the comparative safety of systemic biologic agents and systemic nonbiologic agents or phototherapy is sparse.
  ○ Overall five RCTs (two good, two fair, and one poor in quality) and two observational studies (both fair in quality) directly compared biologics with nonbiolgics and reported at least one adverse outcome of interest.
  ○ No trials or observational studies directly compared biologics with phototherapy.
- Infection rate did not differ between adalimumab and methotrexate (low strength of evidence). These data were from a single RCT conducted outside of the United States in patients with moderate to severe chronic plaque psoriasis naïve to TNF-alpha antagonists or methotrexate.
- There was insufficient evidence for other reported outcomes.

### Detailed Analysis

Key Question 2 is organized by the comparisons of interest. Biologics versus nonbiologics are presented first followed by the comparison of biologics versus phototherapy. Within each comparison of interest, we present data from direct comparisons first. Data from RCTs are presented first followed by observational study data. If data describing the transition from one therapy to another were identified, a subsection describing transition data follows the direct comparative data. At the end of the Key Question, data based on class level comparisons are summarized. There were no data based on indirect comparison meta-analyses identified for this Key Question.

The individual study characteristics for all studies included in this Key Question along with their quality assessments can be found in Appendix E, Tables 3 and 4. Tables that display the outcomes reported within this Key Question can be found in Appendix F, Tables 5 to 11. Strength of evidence ratings as well as description of the applicability of each study can be found in Appendix G and Appendix H, Tables 12 to 48.

#### Outcome Evaluation

##### Systemic Biologic Agents Versus Systemic Nonbiologic Agents

###### Adalimumab Versus Methotrexate

The CHAMPION trial was the only source of data directly comparing the biologic agent adalimumab with the nonbiologic agent methotrexate.17 This trial was rated with good quality and all patients were naïve to both TNF-antagonists and methotrexate. Harms were reported up to 70 days after the last treatment.17 The harms reported in this trial include aspartate aminotransferase (AST), alanine aminotransferase (ALT), infection, and study withdrawal. No additional harm outcomes were reported for the comparison of adalimumab with methotrexate.

More patients in the methotrexate group compared with adalimumab had AST elevation [2 (1.8 percent) versus 0 (0 percent), p=NR] or ALT elevation [4 (3.6 percent) versus 0 (0 percent), p=NR], with elevation defined as > 2.5 times the upper limit of normal (ULN). The difference in infection rate was reported to be not significant and infection was observed in 51 patients (47.7 percent) receiving adalimumab and 46 patients (41.8 percent) receiving methotrexate. No infections were considered serious. Four patients (3.7 percent) and six patients (5.5 percent) withdrew from the adalimumab treated group and the methotrexate treated group, respectively (p=NR).

###### Transitions Between Adalimumab and Methotrexate

Two studies evaluated the transition of patients between the biologic agent adalimumab and the nonbiologic agent methotrexate.30,37 The CHAMPION trial included an open-label extension study in which methotrexate treated patients who completed a 16-week study period were allowed to switch to treatment with adalimumab.37 Results from this population of 95 patients were reported based on an interim analysis and no serious infections occurred during the 24 weeks of adalimumab treatment.37

One nonrandomized open-label study by Strober et al. evaluated patients who had a suboptimal response to methotrexate, defined as a PGA of “mild” or worse after a minimum of four weeks of therapy.30 Patients stopped methotrexate for four to 10 days and then transitioned to adalimumab treatment. The following harm outcomes were evaluated: injection site reaction, malignancy, infection, and study withdrawal. No additional harm outcomes were reported for patients who transitioned from methotrexate to adalimumab. Throughout week 26, there were no malignancies reported.30 Thirteen patients (31.7 percent) had an infectious adverse event, none of which were classified as serious infections. Two patients (4.8 percent) experienced injection site reaction, as reported in the results found on www.clinicaltrials.gov.38 Two patients (4.9 percent) withdrew from the study.

###### Alefacept Versus Cyclosporine

No RCTs or observational studies directly compared the biologic agent alefacept with the nonbiologic agent cyclosporine.

###### Transitions From Cyclosporine to Alefacept

There were no RCTs identified for this comparison of interest. One open-label study by Magliocco et al. evaluated patients who were well controlled on cyclosporine therapy with a need or desire to switch to alefacept therapy.31 Well controlled was defined as a PGA of “mild”, “almost clear” or “clear”. This study was rated as having fair quality and data about whether patients were naïve to treatment were not reported. The study consisted of three phases over 48 weeks to determine if psoriasis control could be maintained while transitioning patients from cyclosporine to alefacept. In phase I (12 weeks) patients received alefacept for 12 weeks and were tapered off of cyclosporine in weeks 5 through 12. In phase 2 (12 weeks), patients did not receive alefacept or cyclosporine but were allowed to use topical agents and UVB phototherapy. In phase III (24 weeks), patients were treated with alefacept for 12 weeks followed by 12 weeks of observation, with topical and UVB therapy permitted during the 12 week observation period. Topical therapy was used by 3 patients (37 percent) in phase II and in phase III. UVB therapy was used by one patient (8 percent) in phase III. Twelve patients began this study and completed phase I, three patients dropped out during phase II, and 2 patients dropped out during phase III. Therefore, six patients completed the 48 week study.

During this study31, authors report that there were no cases of serious infection, opportunistic infection, or malignancies, and that no remarkable changes were observed in renal or hepatic function. However, data to represent the direction or magnitude of changes in these laboratory parameters were not reported.. Although neutropenia was not reported in this study, the mean CD4+ count (a subset of white blood cells) was provided. At baseline, the mean cell count was 856 cells/mm^3^ which decreased to 706 cells/mm^3^ after phase I. After phase II, the mean cell count increased to 804 cells/mm^3^. After the second course of treatment during phase II, the mean CD4+ T cell count was at the lowest value of 464 cells/mm^3^ but increased after the observation period in phase III to a mean of 872 cells/mm^3^. One patient had two doses of alefacept withheld during phase III due to CD4+ T cell counts lower than 250 cells/mm^3^. In both instances CD4+ counts resolved and therapy resumed the following week. Three patients (27.3 percent) dropped out during phase II, and 2 patients dropped out during phase III (18.2 percent), leaving six patients (50 percent) who completed the 48 week study.

###### Etanercept Versus Acitretin

Three RCTs compared the biologic agent etanercept with the nonbiologic agent acitretin and reported data regarding harms.22–24 The trial by Caproni et al. was rated as having fair quality while the trial by Gisondi et al. was rated as having good quality. The third RCT (herein clinical trial 5) which was rated as having poor quality has not been published as a manuscript and the data were extracted from www.clinicaltrials.gov. 24 In the trial by Caproni et al. the percent of treatment naïve patients was not reported and individuals were allowed into the trial as long as treatment with either topical or systemic therapy was greater than one month prior to enrollment. In the trial by Gisondi et al. all patients were naïve to biologic therapy as prior use was an exclusion criterion. Patients were allowed into the trial as long as treatment with either topical, systemic, or phototherapy was greater than four weeks prior to enrollment. In clinical trial 5, all patients were naïve to TNF inhibitors, efalizumab, and alefacept.

The trial by Gisondi et al. evaluated AST, ALT, and total cholesterol at weeks 6, 12, and 24 and reported that there were no significant alterations in any of these laboratory parameters found at any of the time points evaluated.23 No other data were reported in the trial, such as the direction or magnitude of any observed changes. There were no reports of AST toxicity in clinical trial 5, however, one patient (4.76 percent) in the etanercept group did report ALT toxicity compared with none in the acitretin group (p=NR). 24 There were no study withdrawals in the trial by Caproni et al. although in the trial by Gisondi et al., four subjects (20 percent) withdrew from the acitretin group, while all subjects in the etanercept group completed the trial (p=NR).22,23 In clinical trial 5, four subjects (19.0 percent) withdrew from the etanercept group, while six subjects (33.3 percent) withdrew from the acitretin group (p=NR).24 One patient in the etanercept group also reported an injection site reaction (4.76 percent) compared with none in the acitretin group (p=NR). There were no reports of hypertension or infection in either etanercept or acitretin groups in clinical trial 5 (p=NR).

###### Etanercept Versus Cyclosporine

No RCTs or observational studies directly compared the biologic agent etanercept with the nonbiologic agent cyclosporine.

###### Transitions From Cyclosporine to Etanercept

One observational study by Garavaglia et al. evaluated patients with hepatitis C virus who had been previously treated with cyclosporine and were currently receiving etanercept treatment.29 This study was rated as having poor quality and data about whether patients were naïve to treatment were not reported. AST and ALT values were the only adverse outcomes reported, at baseline, 3, 6, 12, 18, and 24 months. Authors concluded that in all four patients who had previously been treated with cyclosporine, AST (65 units per L [U/L], 36 U/L, 47 U/L, and 38 U/L at baseline versus 35 U/L, 36 U/L, 32 U/L, and 52 U/L at week 52, p=NR) and ALT remained unchanged at week 52 (63 U/L, 49 U/L, 54 U/L, and 44 U/L at baseline versus 29 U/L, 41 U/L, 42 U/L, and 73 U/L at week 52, p=NR). Two of the four patients had measured AST and ALT levels up to 104 weeks. Levels remained unchanged in one patient but increased in the second patient compared with baseline (38 U/L at baseline versus 73 U/L at week 104 for AST and 44 U/L at baseline versus 75 U/L at week 104, p=NR).

###### Etanercept Versus Methotrexate

One observational study by Gisondi et al., rated with fair quality, compared patients treated with etanercept with patients treated with methotrexate.26 Patients treated with etanercept were naïve to biologic therapy. The harms reported in this study included total cholesterol, weight, and BMI. There was no statistically significant difference in mean total cholesterol comparing baseline with 6 month values in the etanercept (233±15.1 versus 235±17.3, p=0.5) or methotrexate (234±16.8 versus 236±18.1, p=0.4) groups. Patients treated with etanercept gained an average of 1.5±2.7 kg over 6 months, which was a significant change from baseline (p=0.0002). Patients treated with methotrexate did not experience a significant change in mean body weight from baseline (−0.6±1.4, p=0.4). However, statistical comparisons of weight between etanercept and methotrexate were not made. The amount of weight loss or gain was also categorized for each treatment group as the number of patient who lost weight, did not vary in weight, gained 1 to 3 kg, or gained 4 to 10 kg. In the etanercept group, six patients (10.3 percent) lost weight, 15 (25.8 percent) did not vary in weight, 24 (41.3 percent) gained 1 to 3 kg, and 13 (22.4 percent) gained 4 to 10 kg. In the methotrexate group, eight patients (18.6 percent) lost weight, 32 (74.4 percent) did not vary in weight, three (6.9 percent) gained 1 to 3 kg, and no patients gained 4 to 10 kg. Statistical comparisons between treatment groups were not made. Lastly, the mean BMI increased significantly in the etanercept group (0.5±0.5, p=0.01) and did not change significantly in the methotrexate group (−0.2±0.5, p=0.06) over 6 months.

###### Infliximab Versus Methotrexate

One RCT and one observational study directly compared the biologic agent infliximab with the nonbiologic agent methotrexate.21,26 One RCT, rated with fair quality, compared the biologic agent infliximab with the nonbiologic agent methotrexate.21 Patients enrolled in this trial were naïve to methotrexate therapy and were allowed in the trial if treatment with biologics was greater than three months prior. Therapy with topical agents or systemic therapies that could affect PASI were discontinued two and four weeks, respectively, prior to the start of the study.

All harms outcomes evaluated in the original trial were reported at week 26 including all patients who received at least one dose of study drug and excluding all events that occurred on or after treatment switch at week 16.^21^ Data were available on www.clinicaltrials.gov for patients who switched therapy at week 16 and we present results separately for this transition population below.39

Hepatic enzymes increased in two patients receiving infliximab (0.31 percent) and one patient receiving methotrexate (0.47 percent, p=NR).21 TCP was reported in one patient receiving infliximab (0.15 percent) and none receiving methotrexate (p=NR).21 Hypertension did not occur in either group. Infusion related reactions occurred in 2.6 percent of infliximab treated patients. Under the category of lymphoproliferative disorders or malignancy, one case, specifically basal cell carcinoma, occurred in a patient treated with infliximab (0.2 percent) and no cases were observed in the methotrexate group (P=NR).21 Serious infections were reported and defined as tuberculosis, opportunistic infections such as pneumocystis jiroveci pneumonia, listeriosis, atypical mycobacteria, histoplasmosis, salmonellosis and serious viral infections. Ten cases occurred in the infliximab group (1.5 percent) while 4 cases occurred in the methotrexate group (1.9 percent, p=NR). Study withdrawals were higher in the methotrexate group (40.9 percent) compared with the infliximab group (17.2 percent, p=NR).21

Additional infectious outcomes through week 26 were reported in the results posted on www.clinicaltrials.gov.39 A variety of infections were reported including bacterial arthritis, febrile infection, Lyme disease, streptococcal pharyngitis, pneumonia, pulmonary tuberculosis, staphylococcal infection, and viral infection. Of these infections the following cases occurred in the infliximab group: one case of Lyme disease (0.15 percent), one case of streptococcal pharyngitis (0.15 percent), two cases of pneumonia (0.31 percent), one case of pulmonary tuberculosis (0.15 percent), and one viral infection (0.15 percent). The following cases occurred in the methotrexate group: one case of febrile infection (0.47 percent). Hepatic enzyme elevation (not further defined) was also reported in the results on www.clinicaltrials.gov. Two patients in the infliximab group (0.31 percent) and one patient in the methotrexate group (0.47 percent) had hepatic enzyme elevation (p=NR).39

One observational study by Gisondi et al., rated with fair quality, compared patients treated with the biologic agent infliximab with patients treated with the nonbiologic agent methotrexate.26 Patients treated with infliximab were naïve to biologic therapy. The harms reported in this study included total cholesterol, weight, and BMI. There was no statistically significant difference in mean total cholesterol levels comparing baseline with 6 month values in the infliximab (235.5±14.2 versus 237±16.9, p=0.6) or methotrexate (234±16.8 versus 236±18.1, p=0.4) groups. Patients treated with infliximab gained an average of 2.5±3.3 kg over 6 months, which was a significant change from baseline (p=0.0004). Patients treated with methotrexate did not experience a significant change in mean body weight from baseline (−0.6±1.4, p=0.4). The amount of weight loss or gain was also categorized for each treatment group as the number of patient who lost weight, did not vary in weight, gained 1 to 3 kg, or gained 4 to 10 kg. In the infliximab group, three patients (7.5 percent) lost weight, seven (17.5 percent) did not vary in weight, 19 (47.5 percent) gained 1 to 3 kg, and 11 (27.5 percent) gained 4 to 10 kg. In the methotrexate group, eight patients (18.6 percent) lost weight, 32 (74.4 percent) did not vary in weight, three (6.9 percent) gained 1 to 3 kg, and no patients gained 4 to 10 kg. Statistical comparisons between treatment groups were not made. Lastly, the mean BMI increased significantly in the infliximab group (0.8±1, p=0.003) but did not change significantly in the methotrexate group (−0.2±0.5, p=0.06) over 6 months.

###### Transitions Between Infliximab and Methotrexate

The trial by Barker allowed patients to switch therapy at 16 weeks, as previously described. Adverse events for this population were reported in the results posted on www.clinicaltrials.gov for the period of time after the therapy switch (weeks 16 to 26).39 No patients experienced hepatic enzyme elevation or TCP after the switch.39 One patient (1.59 percent) was reported to have hypertension in 63 patients who transitioned from methotrexate to infliximab while no cases occurred in 9 patients who transitioned from infliximab to methotrexate (p=NR).39 Five patients (8 percent) experienced infusion-related reactions in 63 patients who transitioned from methotrexate to infliximab. A variety of infections were reported including bacterial arthritis, febrile infection, Lyme disease, streptococcal pharyngitis, pneumonia, pulmonary tuberculosis, staphylococcal infection, and viral infection. Of all of these infections, one case of bacterial arthritis (1.59 percent) and one case of staphylococcal infection (1 percent) occurred in 63 patients who transitioned from methotrexate to infliximab while no events occurred in 9 patients who transitioned from infliximab to methotrexate (p=NR).39

###### Class Level Comparisons

Two observational studies reported data comparing biologic agents and nonbiologic agents at the class level.26,33 One study directly compared classes26 while the other study observed transitions of therapy from nonbiolgics to biologics.33

The first study by Gisondi et al., rated with fair quality, compared treatment with biologic agents (etanercept or infliximab) with the nonbiologic agent methotrexate.26 Patients treated with biologics were naïve to biologic therapy. Authors concluded that in patients exposed to infliximab or etanercept, the risk of weight gain of greater than 5 kg was 4.3 times higher compared with patients exposed to methotrexate, with differences in body weight variations reaching statistical significance.

###### Transitions Between Biologics and Nonbiologics

The study by Costanzo et al., rated with fair quality, was an open-label compassionate use study in, which patients who failed or had adverse events to at least one nonbiologic systemic agent (systemic corticosteroids, cyclosporine, methotrexate, and/or retinoids) in the past were treated with etanercept.33 The majority of patients had also been previously treated with topical steroids (75 percent, 33 out of 44 patients) The interim results of this study were reported where all patients (44 patients) had data at week 12 and 15 patients (34.1 percent) had data at week 24. No final health outcomes were evaluated. One patient (2.3 percent) developed TCP at week 8 of therapy. There were no cases of tuberculosis, opportunistic infections, or clinically significant viral infections during the study (24 weeks). Two patients (4.5 percent) experienced injection site reactions at week 2. Four patients (9 percent) withdrew from the study and all were related to adverse effects.

##### Biologic Systemic Agents Versus Phototherapy

###### Adalimumab Versus NB-UVB Phototherapy

No RCTs or observational studies directly compared the biologic agent adalimumab with NB-UVB phototherapy.

###### Transitions Between Adalimumab and NB-UVB Phototherapy

One nonrandomized open-label study by Strober et al. evaluated patients who had a suboptimal response to NB-UVB phototherapy, defined as a PGA of “moderate” or worse after at least 2 months of therapy.30 After stopping NB-UVB therapy for 4 to 10 days, patients were transitioned to adalimumab treatment.30 The following harm outcomes were evaluated: injection site reaction, malignancy, infection, and study withdrawal. No additional harm outcomes were reported for patients who transitioned from NB-UVB phototherapy to adalimumab. Throughout week 26, there were no cases of injection site reactions or malignancies reported. Seven patients (24.1 percent) had an infectious adverse event and one patient (3.4 percent) experienced infection, which was defined as serious. Five patients (17.2 percent) withdrew from the study.

## Key Question 3

In patients with chronic plaque psoriasis treated with systemic biologic therapy, systemic nonbiologic therapy, or phototherapy, which patient or disease characteristics (e.g., age, gender, race, weight, smoking status, psoriasis severity, presence or absence of concomitant psoriatic arthritis, disease duration, baseline disease severity, affected BSA, disease location, number and type of previous treatments, failure of previous treatments and presence of neutralizing antibodies) affect intermediate and final outcomes?

### Key Points

- One post-hoc subgroup analysis of the CHAMPION RCT met inclusion criteria for Key Question 3. Two additional observational studies were identified although neither controlled for confounding and therefore were reported and discussed for descriptive purposes only.
- Data from the post-hoc subgroup analysis of CHAMPION, a trial that compared treatment with the biologic agent adalimumab with the nonbiologic agent methotrexate, suggested that as disease severity improves (measured with PASI), so did a patient’s HRQoL (measured with the DLQI).
- Two observational studies evaluated the impact of weight on PGA, the impact of a history of psoriatic arthritis (PsA) on plaque psoriasis or PsA pain, and the impact of prior exposure to a biologic agent on PASI. Conclusions cannot be made from this literature base as neither study controlled for confounding factors.

### Detailed Analysis

#### Outcome Evaluation

This Key Question is organized by the patient/disease characteristic and health outcome that is being described. One post-hoc subgroup analysis of the CHAMPION RCT met inclusion criteria for Key Question 3.^35^ Two additional observational studies were identified although neither controls for confounding and therefore are report and discussed for descriptive purposes only.30,31

##### Psoriasis Disease Severity and HRQoL

The CHAMPION RCT by Saurat et al, compared the biologic agent adalimumab with the nonbiologic agent methotrexate.17 A post-hoc analysis of the CHAMPION population evaluated the relationship between psoriasis severity, measured with the PASI, and the final health outcome HRQoL measured with the DLQI (Table 7).35 The mean DLQI change from baseline to week 16 was reported for four groups stratified by percent PASI improvement from baseline: PASI ≥75, PASI 50 to 75, PASI 25 to 50, and PASI< 25. Patients with greater PASI response had greater improvements in DLQI over the 16 week followup. The mean DLQI change from baseline to week 16 was significantly greater in PASI ≥75 group (−9.5±5.8) compared with PASI 50 to 75 (−5.8±4.5, p<0.01), PASI 25 to 50 (−4.2±4.6, p<0.001), and PASI <25 (−0.7±4.7, p<0.001) (Table 4). The other statistically significant difference in DLQI was in patients who had a PASI 50 to 75 compared with PASI<25 (p<0.001). All other comparisons were not statistically significant, although exact p-values were not reported.

Table 7 Relationship between disease severity and dermatology life quality index

Study | Characteristics | N | Followup | DLQI mean(SD) | P-values | P-values | P-values
Study | Characteristics | N | Followup | DLQI mean(SD) | Versus PASI 50 to 75 | Versus PASI 25 to 50 | Versus PASI <25
Saurat, 2008 | PASI ≥75^*^ | 131 | 16w | −9.5(5.8) | <0.01 | <0.001 | <0.001
Saurat, 2008 | PASI 50 to 75^*^ | 44 | 16w | −5.8(4.5) | --- | NS | <0.001
Saurat, 2008 | PASI 25 to 50^*^ | 25 | 16w | −4.2(4.6) | NS | --- | NS
Saurat, 2008 | PASI <25^*^ | 49 | 16w | −0.7(4.7) | <0.001 | NS | ---

DLQI = dermatology life quality index; N = number of patients; NS = not significant; PASI = Psoriasis Area Severity Index; p-value = probability value; SD = standard deviation; w = weeks; --- = not applicable

* Based on percentage improvement from baseline.

###### Weight and PGA

One nonrandomized open-label study by Strober et al. evaluated patients who had a suboptimal response to methotrexate or NB-UVB and were transitioned to adalimumab. Suboptimal response to methotrexate was defined as a PGA of “mild” or worse after at least four months of methotrexate therapy. Suboptimal response to NB-UVB was defined as a PGA of “moderate” or worse after at least two months of NB-UVB therapy.30 The relationship between patient’s weight and the intermediate outcome PGA was reported in this study based on a subgroup analysis, although methods to control for confounding were not used and therefore conclusions based on these data cannot be made.

Patients were stratified into two subgroups: patients weighting 100 kg or less and patients weighting more than 100 kg. For patients who transitioned from methotrexate to adalimumab, 67 percent (20 out of 30) of patients weighting 100 kg or less achieved a PGA of “clear” or “minimal at week 16 compared with 45 percent (5 out of 11) of patients weighing more than 100 kg (p=NR). For patients who transitioned from NB-UVB to adalimumab, 45 percent (10 out of 22) of patients weighting 100 kg or less achieved a PGA of “clear” or “minimal at week 16 compared with 57 percent (4 out of 7) of patients weighing more than 100 kg (p=NR) (Table 8).

Table 8 Relationship between patient’s weight and physician’s global assessment

Study | Population | Characteristics | Followup | PGA^*^ n/N (%) | P-values
Strober, 2011 | MTX transitioned to adalimumab | weight ≤100kg | 16w | 20/30 (66.7) | ---
Strober, 2011 | MTX transitioned to adalimumab | weight >100kg | 16w | 5/11 (45.5) | ---
Strober, 2011 | NB-UVB transitioned to adalimumab | weight ≤100kg | 16w | 10/22 (45.5) | ---
Strober, 2011 | NB-UVB transitioned to adalimumab | weight >100kg | 16w | 4/7 (57.1) | ---

kg = kilograms; MTX = methotrexate; NB-UVB = narrow-band ultraviolet B; n/N = number of patients per total population; PGA = physician’s global assessment;p-value = probability value; w = weeks; --- = not reported

* Number of patients achieving a PGA of “clear” or “minimal”.

###### History of PsA and Pain

The open label study by Strober et al.30 also evaluated the relationship between the presence of concomitant PsA and the intermediate outcome VAS for plaque psoriasis and PsA pain. However, methods to control for confounding were not used and therefore conclusions based on these data cannot be made. Patients were stratified into two groups: patients with a history of PsA and patients without a history of PsA. For patients who transitioned from methotrexate to adalimumab, the improvement in VAS for plaque psoriasis and PsA pain was greater in patients with a history of PsA compared with patients without a history of PsA (−19.2 versus −11.6; p=NR) (Table 9). For patients who transitioned from NB-UVB to adalimumab, the improvement in VAS for plaque psoriasis and PsA pain was greater in patients with a history of PsA compared with patients without a history of PsA (−47.1 versus −13.2; p=NR).

Table 9 The relationship between history of psoriatic arthritis and pain

Study | Population | Characteristics | Followup | Pain^*^ mean(SD) | P-values
Strober, 2011 | MTX transitioned to adalimumab | No history of PsA | 16w | −11.6(NR) | ---
Strober, 2011 | MTX transitioned to adalimumab | History of PsA | 16w | −19.2(NR) | ---
Strober, 2011 | NB-UVB transitioned to adalimumab | No history of PsA | 16w | −13.2(NR) | ---
Strober, 2011 | NB-UVB transitioned to adalimumab | History of PsA | 16w | −47.1(NR) | ---

MTX = methotrexate; NB-UVB = narrow-band ultraviolet B; NR = not reported; PsA = psoriatic arthritis; P-values = probability values; SD = standard deviation; VAS = visual analogue scale; w = weeks; --- = not reported

* Mean (SD) change from baseline in VAS for pain involving psoriatic plaques and/or PsA.

###### Type of Previous Treatments and PASI

One observational study by Mazzotta et al. evaluated patients currently being treated with etanercept who had previously been treated with nonbiologic systemic agents or phototherapy (cyclosporine, corticosteroids, fumaric acid esters, methotrexate, retinoids, and PUVA).32 Patients were included if they failed nonbiologic therapy (according to PASI and pain score), had an adverse event to nonbiologic therapy, or were noncompliant with nonbiologic treatment. The percentage of patients in each of these categories was not reported by the study. Most patients (98 of 124, 79 percent) were naïve to systemic biologics.

This study evaluated the relationship between being naïve to systemic biologic therapy and the intermediate outcome PASI (Table 10) in a univariate analysis. No methods were used to control for confounding therefore conclusions cannot be made based on these data. In both subgroups, there was a statistically significant improvement in the mean PASI from baseline to week 12 and week 24 (p<0.0001 for all comparisons). However, the difference between week 12 and 24 was only statistically significant in the subgroup of patients who were naïve to biologics (p<0.0001). There were no statistically significant differences in mean PASIs at baseline, week 12, and week 24 when patients naïve to biologic treatment were compared with patients who were not naïve to biologic treatment [(16.1 versus 14.5 at baseline), (4.9 versus 5.4 at week 12), and (2.8 versus 4.0 at week 24); p=NR]. PASI 50 and PASI 75 were not statistically significant at weeks 12 and 24 when comparing patients naïve to biologic treatment with patients who were not naïve to biologic treatment (p=NR), with the exception of PASI 50 at week 24 (p=0.013).

Table 10 The relationship between prior treatment with systemic biologic agent and Psoriasis Area Severity Index

Study | Characteristics | Followup | PASI 50 n/N (%) | PASI 75 n/N (%) | PASI mean (SD) | P-Values
Study | Characteristics | Followup | PASI 50 n/N (%) | PASI 75 n/N (%) | PASI mean (SD) | Mean PASI Versus Baseline | Mean PASI Versus Week 12 | Mean PASI Versus Week 24
Mazzotta, 2009 | Naïve to biologics^*^ | 12w | 79/98 (80.2) | 43/98 (43.7) | 4.9(4.0) | <0.0001 | --- | <0.0001
Mazzotta, 2009 | Prior exposure to biologics^*^ | 12w | 18/26 (69.2) | 8/26 (30.8) | 5.4(3.8) | <0.0001 | --- | 0.4113
Mazzotta, 2009 | Naïve to biologics^*^ | 24w | 88/98^†^ (89.9) | 74/98 (75.3) | 2.8(3.4) | <0.0001 | <0.0001 | ---
Mazzotta, 2009 | Prior exposure to biologics^*^ | 24w | 18/26^†^ (69.6) | 17/26 (65.2) | 4.0(4.5) | <0.0001 | 0.4113 | ---

n/N = number of patients per total population; PASI = Psoriasis Area Severity Index; SD = standard deviation; w = week; --- = not reported; p-value = probability value

* infliximab, efalizumab.

† p-value=0.013 for prior exposure to biologics versus naïve to biologics at week 24.