# References

1 Neimann AL, Porter SB, Gelfand JM. The epidemiology of psoriasis. Expert Rev Dermatol. 2006;1:63-75.
2 Christophers E. Psoriasis–epidemiology and clinical spectrum. Clin Exp Dermatol. 2001;26:314-20. [pmid: 11422182].
3 National Psoriasis Foundation Web site. About psoriasis: statistics. www.psoriasis.org/learn_statistics. Accessed Feb. 2, 2010. (Last accessed on April 16, 2012).
4 Menter A, Gottlieb A, Feldman SR, et al. Guidelines of care for the management of psoriasis and psoriatic arthritis: Section 1. Overview of psoriasis and guidelines of care for the treatment of psoriasis with biologics. J Am Acad Dermatol. 2008;58:826-850. [pmid: 18423260].
5 Smith CH, Anstey AV, Barker JN, et al. British Association of Dermatologists’ guidelines for biologic interventions for psoriasis 2009. Br J Dermatol. 2009;161:987-1019. [pmid: 19857207].
6 Nickoloff BJ, Nestle FO. Recent insights into the immunopathogenesis of psoriasis provide new therapeutic opportunities. J Clin Invest. 2004;113:1664-75. [pmid: 15199399].
7 Committee for Medicinal Products for Human Use (CHMP). Guideline on Clinical Investigation of Medicinal Products Indicated for the Treatment of Psoriasis. London. European Medicines Agency. Nov. 2004. CHMP Publication No. CHMP/EWP/2454/02.
8 Panayi GS. Immunology of psoriasis and psoriatic arthritis. Baillieres Clin Rheumatol. 1994;8:419-27. [pmid: 8076395].
9 Chang JC, Smith LR, Froning KJ, et al. Persistence of T-cell clones in psoriatic lesions. Arch Dermatol. 1997;133:703-8. [pmid: 9197823].
10 Mease PJ, Goffe BS, Metz J, et al. Etanercept in the treatment of psoriatic arthritis and psoriasis: a randomised trial. Lancet. 2000;356:385-90. [pmid: 10972371].
11 Menter A, Korman NJ, Elmets CA, et al. Guidelines of care for the management of psoriasis and psoriatic arthritis: Section 4. Guidelines of care for the management and treatment of psoriasis with traditional systemic agents. J Am Acad Dermatol. 2009;61:451-85. [pmid: 19493586].
12 Van Voorhees A, Feldman SR, Koo JYM, et al. for the National Psoriasis Foundation. The psoriasis and psoriatic arthritis pocket guide: treatment algorithms and management options. www.psoriasis.org/NetCommunity/Document.Doc?id=354. Accessed May 27, 2011. (Last accessed April 16, 2012).
13 Menter A, Korman NJ, Elmets CA, et al. Guidelines of care for the management of psoriasis and psoriatic arthritis: Section 5. Guidelines of care for the treatment of psoriasis with phototherapy and photochemotherapy. J Am Acad Dermatol. 2010;62:114-35. [pmid: 19811850].
14 Beyer V, Wolverton SE. Recent trends in systemic psoriasis treatment costs. Arch Dermatol. 2010;146:46-54. [pmid: 20083692].
15 Griffiths CE, Strober BE, van de Kerkhof P, et al. for the ACCEPT Study Group. Comparison of ustekinumab and etanercept for moderate-to-severe psoriasis. N Engl J Med. 2010;362:118-28. [pmid: 20071701].
16 Heydendael VM, Spuls PI, Opmeer BC, et al. Methotrexate versus cyclosporine in moderate-to-severe chronic plaque psoriasis. N Engl J Med. 2003;349:658-65. [pmid: 12917302].
17 Saurat JH, Stingl G, Dubertret L, et al. for the CHAMPION Study Investigators. Efficacy and safety results from the randomized controlled comparative study of adalimumab vs. methotrexate vs. placebo in patients with psoriasis (CHAMPION). Br J Dermatol. 2008;158:558-66. [pmid: 18047523].
18 Schmitt J, Zhang Z, Wozel G, et al. Efficacy and tolerability of biologic and nonbiologic systemic treatments for moderate-to-severe psoriasis: meta-analysis of randomized controlled trials. Br J Dermatol. 2008;158:351-9. [pmid: 18070214].
19 Assessing the risk of bias of individual studies when comparing medical interventions. Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Draft Publication. effectivehealthcare.ahrq.gov/.
20 Owens D, Lohr K, Atkins D, et al. AHRQ series paper 5: Grading the strength of a body of evidence when comparing medical interventions: AHRQ and the effective health care program. J Clin Epidemiol. 2010;63:513-23. [pmid: 19595577].
21 Barker J, Hoffmann M, Wozel G, et al. Efficacy and safety of infliximab vs. methotrexate in patients with moderate-to-severe plaque psoriasis: results of an open-label, active-controlled, randomized trial (RESTORE1). Br J Dermatol. 2011;165:1109-17. [pmid: 21910713].
22 Caproni M, Antiga E, Melani L, et al. Serum levels of IL-17 and IL-22 are reduced by etanercept, but not by acitretin, in patients with psoriasis: a randomized-controlled trial. J Clin Immunol. 2009;29:210-214. [pmid: 18763027].
23 Gisondi P, Del Giglio M, Cotena C, et al. Combining etanercept and acitretin in the therapy of chronic plaque psoriasis: a 24-week, randomized, controlled, investigator-blinded pilot trial. Br J Dermatol. 2008;158:1345-1349. [pmid: 18410408].
24 Study Evaluating the Efficacy and Safety of Etanercept and Acitretin in Korean Patient With Moderate to Severe Psoriasis. www.clinicaltrials.gov/ct2/show/NCT00936065. Accessed Jul. 1, 2012.
25 Inzinger M, Heschl B, Weger W, et al. Efficacy of psoralen plus ultraviolet A therapy vs. biologics in moderate to severe chronic plaque psoriasis: retrospective data analysis of a patient registry. J Invest Dermatol. 2011;165:640-5. [pmid: 21564068].
26 Gisondi P, Cotena C, Tessari G, et al. Anti-tumour necrosis factor-alpha therapy increases body weight in patients with chronic plaque psoriasis: a retrospective cohort study. J Eur Acad Dermatol Venereol. 2008;22:341-344. [pmid: 18005022].
27 Emerit I, Antunes J, Silva JM, et al. Clastogenic plasma factors in psoriasis—comparison of phototherapy and anti-TNF-α treatments. Photochem Photobiol. 2011;87:1427-32. [pmid: 21824151].
28 Gelfand JM, Wan J, Callis Duffin K, et al. Comparative effectiveness of commonly used systemic treatments or phototherapy for moderate to severe plaque psoriasis in the clinical practice setting. Arch Dermatol. 2012;148:487-94. [pmid: 22508874].
29 Garavaglia MC, Altomare G. Etanercept therapy in patients with psoriasis and concomitant HCV infection. Int J Immunopathol Pharmacol. 2010;23:965-969. [pmid: 20943071].
30 Strober BE, Poulin Y, Kerdel FA, et al. Switching to adalimumab for psoriasis patients with a suboptimal response to etanercept, methotrexate, or phototherapy: efficacy and safety results from an open-label study. J Am Acad Dermatol. 2011;64:671-681. [pmid: 21414495].
31 Magliocco MA, Lozano AM, Van Saders C, et al. An open-label study to evaluate the transition of patients with chronic plaque psoriasis from cyclosporine to alefacept. J Drugs Dermatol. 2007;6:424-427. [pmid: 17668540].
32 Mazzotta A, Esposito M, Costanzo A, et al. Efficacy and safety of etanercept in psoriasis after switching from other treatments: an observational study. Am J Clin Dermatol. 2009;10:319-324. [pmid: 19658444].
33 Costanzo A, Mazzotta A, Papoutsaki M, et al. Safety and efficacy study on etanercept in patients with plaque psoriasis. Br J Dermatol. 2005;152:187-189. [pmid: 15656833].
34 Bansback N, Sizto S, Sun H, et al. Efficacy of systemic treatments for moderate to severe plaque psoriasis: systematic review and meta-analysis. Dermatology. 2009;219:209-18. [pmid: 19657180].
35 Revicki D, Willian MK, Saurat JH, et al. Impact of adalimumab treatment on health-related quality of life and other patient-reported outcomes: results from a 16-week randomized controlled trial in patients with moderate to severe plaque psoriasis. Br J Dermatol. 2008;158:549-557. [pmid: 18047521].
36 Saurat JH, Langley R, Sting G, et al. Adalimumab treatment is associated with more rapid improvement in psoriasis versus methotrexate and versus placebo: results from the CHAMPION study. Br J Dermatol. 2007;157:S1-S9.
37 Mrowietz U, Gu Y, Okun M, et al. Methotrexate-treated psoriasis patients transitioning to adalimumab: Efficacy and safety outcomes. J Am Acad Dermatol. Feb. AB120. 2008:2609.
38 Open Label Study of Adalimumab in Subjects Who Have a Sub-optimal Response to Systemic Therapy or Phototherapy. clinicaltrials.gov/ct2/show/NCT00566722. Accessed Apr. 16, 2012.
39 The Effects of Infliximab Versus Methotrexate in the Treatment of Moderate to Severe Psoriasis. clinicaltrials.gov/ct2/show/NCT00251641. Accessed Apr. 16, 2012.
40 Shikiar R, Willian MK, Okun MM, et al. The validity and responsiveness of three quality of life measures in the assessment of psoriasis patients: results of a phase II study. Health Qual Life Outcomes. 2006;4:71. [pmid: 17005043].
41 Kalb RE, Strober B, Weinstein G, et al. Methotrexate and psoriasis: 2009 National Psoriasis Foundation Consensus Conference. J Am Acad Dermatol. 2009;60:824-37. [pmid: 19389524].