# Methods

The methods for this comparative effectiveness review (CER) follow the methods suggested in the Agency for Healthcare Research and Quality (AHRQ) Guide for Effectiveness and Comparative Effectiveness Reviews (Methods Guide) (www.effectivehealthcare.ahrq.gov/methodsguide.cfm). The main sections in this chapter reflect the elements of the protocol established for the CER.

## Input From Stakeholders

The Evidence-based Practice Center drafted a topic refinement document with proposed Key Questions after consult with Key Informants. Our Key Informants included five experts in the field of psoriasis. Three physicians provided the dermatologist’s perspective, one local and two national representatives. Another physician provided the general practitioner’s perspective. Last one expert provided the perspective of the National Psoriasis Foundation as well as outcomes research. The public was invited to comment on the topic refinement document and Key Questions. After reviewing the public commentary, responses to public commentary, and proposed revisions to the Key Questions, a preliminary protocol was generated and reviewed with the Technical Expert Panel. The aforementioned Key Informants constituted our Technical Expert Panel and provided feedback on the feasibility and importance of our approach and provided their unique insight. The draft CER underwent peer review and public commentary and revisions were made before finalizing the report.

## Searching for the Evidence

We developed two literature search strategies a priori. The first systematic literature search was used to identify studies for inclusion to answer Key Questions 1, 2 and 3. The strategy detailed in Appendix A was used to search in MEDLINE^®^ and the Cochrane Central Register of Controlled Trials. Language restrictions were not applied. A manual search of references from included studies and previously conducted systematic reviews was also conducted. Relevant citations were manually added to the literature base. A gray literature search for meeting abstracts was conducted in Web of Science, using the same search strategy as previously described, limiting search results to meeting proceedings. Abstracts that met inclusion criteria were paired with full text manuscripts when possible and were otherwise considered separately. For agents with a Food and Drug Administration (FDA)-approved indication for the treatment of psoriasis, a search for completed trials with posted results was conducted on www.clinicaltrials.gov and associated FDA regulatory documents for these drugs were manually searched. Data from gray literature search were used identify addition literature and to supplement published manuscripts identified in the database search when the studies could be matched. The Scientific Resource Center of the AHRQ Effective Health Care Program contacted the manufacturers of identified interventions and comparators for scientific information packets. The same inclusion/exclusion criteria applied to the database searches were applied to packets that were received. Relevant citations were manually added to the literature base.

The second literature search was used to systematically identify previously conducted adjusted indirect comparisons or network meta-analyses. The search strategy shown in Appendix A was used to search in MEDLINE^®^, The Cochrane Database of Systematic Reviews, Database of Abstracts of Reviews of Effects, and Health Technology Assessment database.

Both literature searches were updated in June 2012, concurrent with the peer review process. The same inclusion and exclusion criteria were applied and relevant literature was incorporated into the review.

## Inclusion and Exclusion Criteria

Two independent investigators assessed studies for inclusion in a parallel manner based on a priori defined criteria in two-step processes. In the first step, titles and abstracts were screened and studies that both investigators agreed to include were further evaluated as full text in a second step. Disagreements at either step were resolved by discussion, or when necessary, through a third investigator. Trials and observational studies that compared biologic systemic agents with either nonbiologic systemic agents or phototherapy were included. More specifically, the following observational study designs were included: cohort studies, case-control studies, and before and after studies that compared patients taking one of the therapies of interest who were then switched to a different therapy of interest with data available comparing before and after the switch. Other observational study designs were excluded. Studies published before 1975 were excluded as they were determined to be irrelevant in describing the currently available therapeutic interventions included in the CER. Systematic reviews with or without meta-analysis were included for manual reference searches as well as comparison of results with this CER. Meta-analyses that utilize methods to indirectly compare interventions of interest, including adjusted indirect comparisons or network meta-analyses, were included and summarized qualitatively for all three Key Questions.

To be included, the population evaluated in the study must have been adult patients (≥18 years) with chronic plaque psoriasis (or psoriasis vulgaris), or the study must have evaluated and reported data on a subgroup of adult patients with chronic plaque psoriasis. Only studies that evaluated interventions and comparators with an indication approved by the FDA at the time of writing this report were included in this CER. Studies in which patients were randomized to receive multiple therapies or were allowed to use concurrent therapies were included only if the common interventions were similar across groups compared and the final comparison was of a single biologic systemic agent with a single nonbiologic systemic agent or phototherapy. Studies with only a comparison with a placebo or untreated controls were not included. Studies must have reported at least one of the prespecified outcomes (intermediate, final, or harm) to be included. Gray literature in the form of meeting abstracts, published protocols from www.clinicaltrials.gov, and FDA regulatory documents were included if they met inclusion criteria. When possible, these literature sources were matched with published studies and used as supplemental information. Otherwise, these literature sources were considered independent sources of data. Specifically for Key Question 3, data that describe the association between the prespecified subgroups and outcomes—either through subgroup analysis in randomized trials or through control of confounding in observational studies (e.g., matching or multivariate analysis)—were included.

## Data Extraction and Data Management

Two reviewers used a standardized data extraction tool to independently extract data; disagreements were resolved through discussion (Appendix B). The following data were collected from each unique study: author identification, year of publication, funding source, study design characteristics and methodological quality criteria, study population (inclusion and exclusion criteria, geographic location, intervention, length of study, and duration of patient followup), patient baseline characteristics (including whether the patient is naïve to biologic therapy or not), intervention and comparator regimen in detail (name, strength, dose, frequency, route of administration, duration of therapy, if a drug holiday was allowed, and details regarding the regimen), use of concurrent standard medical therapies, data needed to assess intermediate and final health outcomes and harms, outcome definitions, and data reported for subgroups of interest defined in Key Question 3. Authors were contacted for clarification or to provide additional data when necessary.

## Assessment of Methodological Quality of Included Studies

We assessed the quality of included studies using recommendations from the Methods Guide).19 Using a standardized tool, two reviewers independently assessed the quality of each included study and resolved disagreements through discussion. Randomized trials were evaluated separately from observational studies, and each study received a quality rating of good, fair or poor (Table 4). We assess each randomized trial for the following criteria: methods for randomization, allocation concealment, similarity of groups at baseline, blinding of subjects and providers, differential loss to followup, overall loss to followup, use of intention to treat, blinding of event adjudicators, methods to ascertain outcomes, and reporting of prespecified outcomes. Observational studies were evaluated for the following criteria: selection of comparison group, control for confounding, baseline differences, method to ascertain exposure, methods to ascertain outcomes, blinding of event adjudicators, differential loss to followup, overall loss to followup, and reporting of prespecified outcomes.

Table 4 Overall quality-rating definitions

Grade | Definition
Good | Confidence that the study results are valid. Study reporting is adequate to judge that no major or minor sources of bias are likely to influence results. The study meets the majority of prespecified criteria.
Fair | Some confidence that the study results are valid. The study is susceptible to some bias, and the problems are not sufficient to invalidate the results. The study may be missing information, making it difficult to assess limitations and potential problems.
Poor | Low confidence that the study results are valid. The study has significant flaws that imply biases of various types that may invalidate the results. The biases may arise from serious errors in conduct, analysis or reporting, large amounts of missing information, or discrepancies in reporting.

## Data Synthesis

Data identified through the systematic review were summarized qualitatively as we determined that meta-analysis was not appropriate for several reasons. First, the literature base was very limited in quantity and there was often only one trial or study identified for any given comparison of interest. Most often, no trials were available and data evaluating comparisons of interest were observational in nature. Therefore, we qualitatively evaluated the data and report native measures of effect that were extracted from the included studies. Identified network meta-analyses from the second literature search were qualitatively described in respective Key Questions although not included in the evaluation of strength of evidence. Last, comparisons made within this report are limited to between class comparisons on an individual drug level, given possible heterogeneity within each class considered (see the glossary in Appendix I for drugs within each class). Within class comparisons were beyond the scope of this report.

## Grading the Strength of the Evidence

Two reviewers independently evaluated the strength of evidence for each comparison and outcome described in Key Questions 1 and 2 considered important, with disagreements resolved through discussion. Rating of the strength of evidence was conducted using recommendations from the Methods Guide.19 This system uses four required domains: risk of bias, consistency, directness, and precision. Additional optional domains were not applied.

Risk of bias is the degree to which the included studies, for a given outcome or comparison, have a high likelihood of adequate protection against bias. Risk of bias was ranked as high, medium, or low using the quality assessments of the individual trials included for the given outcome and comparison. Consistency refers to the degree of similarity in the direction of the effect sizes from included studies within an evidence base. We assessed whether or not the effect sizes from multiple sources were on the same side of unity, whether the range of effect sizes was narrow, and the degree of statistical heterogeneity. Consistency was rated as either consistent or inconsistent. When only one study was available, consistency could not be judged and was rated as not applicable. Directness refers to whether the evidence linked the compared interventions directly with health outcomes and compared two or more interventions in head-to-head trials. Indirectness implies that more than one body of evidence was required to link interventions to the most important health outcomes. We ranked outcomes as either direct or indirect. Precision refers to the degree of certainty surrounding the effect estimate with respect to a given outcome. A precise estimate is an estimate that would allow a clinically useful conclusion. An imprecise estimate is one for which the confidence interval is wide enough to include clinically distinct conclusions (e.g., both clinically important superiority and inferiority), a circumstance that will preclude a conclusion. We rated the effect estimate of each outcome as either precise or imprecise. The overall grade for strength of evidence for each comparison and outcome evaluated was rated and classified as high, moderate, low, or insufficient (Table 5). The four required domains were considered equally when grading the strength of evidence. Previously conducted meta-analyses or indirect comparisons were not included in the grading of strength of evidence.

Table 5 Strength of evidence rating definitions

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change confidence in the estimate of effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change confidence in the estimate of effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

## Evaluating the Applicability of the Evidence

Two reviewers independently reviewed the applicability of the individual studies with disagreements resolved through discussion. Summarization of the applicability of evidence was completed using recommendations from the Methods Guide.19 Seven domains were evaluated in assessing individual study applicability: enrolled population, enrollment eligibility criteria, assessment of final health outcomes, adequate study duration with clinically relevant treatment modalities, assessment of adverse events, sample size, and use of intention-to-treat analysis. Data required to evaluate these domains were extracted into evidence tables. Studies that met five or more criteria were classified as effectiveness studies. These data were also reviewed to determine the overall applicability of data per outcome, describing the population and conditions to which the evidence is most applicable.