# Introduction

## Background

Psoriasis is a common, chronic, autoimmune inflammatory skin disease affecting 2 to 3 percent of the worldwide population. The onset of psoriasis predominantly occurs early in adulthood (between the ages of 15 and 25 years) but may affect individuals at any age.1 The course of psoriasis is marked by chronic and acute phases with a wide variety in relapse and clearance rates.2 Additionally, psoriasis is often associated with other comorbidities such as an inflammatory arthritis known as psoriatic arthritis, obesity, inflammatory bowel disease, diabetes, and cardiovascular disease.2 Psoriasis has been associated with markedly elevated direct medical costs, work limitations, and productivity loss. Total health care costs of psoriasis are estimated at $11.25 billion annually.3 This economic burden, along with the clinically relevant reductions in quality of life experienced by many patients with psoriasis, underscores the need for prompt, effective, and sustained disease management.4,5

Among several clinical psoriasis phenotypes, chronic plaque psoriasis is the most frequent, accounting for all but 10 percent of cases.4–6 Chronic plaque psoriasis, also known as psoriasis vulgaris, often appears as well-demarcated, erythematous plaques covered with silvery white scales that vary in size up to several centimeters. Psoriatic skin lesions typically appear symmetrically on the scalp, trunk, and limbs (particularly on the knees and elbows) but may also affect the genitals, nails, palms, and soles of the feet.4,5 Different parameters determine disease severity such as the degree of body surface area (BSA) involved, activity of the lesions, the location of lesions in sensitive areas, duration of disease, treatment failures, and the impact on quality of life.2,7

Psoriasis is a multifactorial disease with genetic and environmental factors that contribute to the dysregulation of cellular inflammation. The presence of psoriatic plaques may be triggered or exacerbated by environmental conditions, including infection, physical or psychological stress, cold weather, and medications.4 The formation of psoriatic plaques involves the interplay of dendritic cells, T cells, antigen-presenting cells, cytokines, keratinocytes, and blood vessels. The presence of activated T cells within psoriatic plaques and the response to T cell-directed therapy suggest an immunologic nature of the disease.8,9 Various cytokines, like tumor necrosis factor (TNF)-alpha and interleukin 23 (IL-23), are also present in psoriatic lesions.10 Both cytokines and activated T cells promote the dysregulated growth of keratinocytes, leading to plaques of erythematous, scaly skin.

While disease localized to nonsensitive areas of skin may be managed effectively with topical agents (emollients, analogs of vitamins A and D, and corticosteroids), patients with more widespread disease often require systemic treatment due to the extent of BSA involvement, as well as the adverse impact on quality of life and activities of daily living.4,5 Therapeutic options for more widespread disease include systemic treatment with biologic agents, nonbiologic agents, and phototherapy. The therapies with data included in this report are further described in Table 1, Table 2, and Table 3. Nonbiologic systemic therapies may be effective but can be associated with significant short-term and long-term toxicities (hepatotoxicty, nephrotoxicity, hypertension, dyslipidemia, malignancy, and teratogenicity).11,12 Phototherapy, although considered to be one of the safer therapeutic options, requires strict compliance, and the long-term toxicity associated with it includes photocarcinogenesis.13 Unfortunately, some patients have disease that is resistant to one or more of the above-mentioned therapies or becomes refractory to treatment. As a result, patients often report high levels of dissatisfaction with such approaches to psoriasis treatment.4,5,11

Table 1 FDA-approved biologic systemic therapy with identified literature in this report

Drug Name^*^ (Brand) | Marketed by (Manufacturer) | Target of Therapy | FDA Indications
Adalimumab (Humira^®^) | Abbott Laboratories | TNF-α | Treatment of adults with chronic moderate-to-severe plaque psoriasis who are candidates for systemic therapy or phototherapy when other therapies are medically less appropriate; reducing signs and symptoms, inhibition of structural damage of active arthritis and improving physical function in patients with psoriatic arthritis; reducing signs and symptoms, including major clinical response, inhibiting progression of structural disease and improving physical function in active moderate-to-severe rheumatoid arthritis; reducing signs and symptoms in active ankylosing spondylitis; reducing signs and symptoms, inducing and maintaining clinical remission, in adult and pediatric patients with active moderate-to-severe active Crohn’s disease in patients with inadequate response to conventional therapy, including intolerance and refractory response to infliximab; reducing signs and symptoms of moderate-to-severe active polyarticular juvenile idiopathic arthritis in patients 4 years of age and older
Alefacept^†^ (Amevive^®^) | AstellasPharma US, Inc. | CD2 antigen on T-lymphocytes and NK cells | Treatment of chronic moderate-to-severe plaque psoriasis in patients who are candidates for systemic therapy or phototherapy
Etanercept (Enbrel^®^) | Amgen, Inc. and Pfizer (Wyeth Pharmaceuticals Inc.) | TNF-α and TNF-β | Treatment of adults with chronic moderate-to-severe plaque psoriasis who are candidates for systemic therapy or phototherapy; reducing signs and symptoms, inhibition of structural damage of active arthritis and improving physical function in patients with psoriatic arthritis; reducing signs and symptoms of active ankylosing spondylitis; reducing signs and symptoms of active moderate-to-severe active polyarticular juvenile idiopathic arthritis; reducing signs and symptoms, including major clinical response, inhibiting progression of structural disease, and improving physical function in active moderate-to-severe rheumatoid arthritis
Infliximab (Remicade^®^) | Centocor Ortho Biotech Inc. | TNF-α | Treatment of severe chronic plaque psoriasis in adults who are candidates for systemic therapy, and other systemic therapies are medically less appropriate; reducing signs and symptoms, including major clinical response, inhibiting progression of structural disease and improving physical function in psoriatic arthritis; (in combination with methotrexate) reducing signs and symptoms, including major clinical response, inhibiting progression of structural disease and improving physical function in moderate to severe active rheumatoid arthritis; reducing signs and symptoms, inducing and maintaining clinical remission in adult and pediatric patients with moderate to severe active Crohn’s disease in patients with inadequate response to conventional therapy; reducing number of draining enterocutaneous, rectovaginal fistulas, maintaining fistula closure in patients with fistulizing Crohn’s disease; reducing signs and symptoms in active ankylosing spondylitis; reducing signs and symptoms, inducing and maintaining clinical remission and mucosal healing and eliminating corticosteroid use in patients with moderate to severe active ulcerative colitis who have had inadequate response to conventional therapy
Ustekinumab (Stelara^®^) | Centocor Ortho Biotech (Cilag Ag) | IL-12 and IL-23 | Treatment for moderate to severe plaque psoriasis in patients (18 years and older) who are candidates for phototherapy or systemic therapy

FDA = Food and Drug Administration; IL = interleukin; NK = natural killer; TNF = tumor necrosis factor

* Drug name is the generic formulation, if available.

† Although no longer available on the U.S. market, this drug was available at the time of writing this report.

Table 2 FDA-approved nonbiologic systemic therapy with identified literature in this report

Drug Name^*^ | Marketed by (Manufacturer) | FDA Indications
Acitretin (Soriatane^®^) | Stiefel Laboratories Inc., a company of GlaxoSmithKline | Treatment of severe psoriasis
Cyclosporine, modified^†^ (Gengraf^®^) (Neoral^®^) | Abbott Laboratories Novartis Pharmaceuticals Corp. | Treatment of adult, nonimmunocompromised patients with severe recalcitrant plaque psoriasis who have failed to respond to at least one systemic therapy or in patients for whom other systemic therapies are contraindicated or cannot be tolerated; prophylaxis of organ rejection in kidney, liver, and heart allogeneic transplants; treatment of severe active rheumatoid arthritis where disease has not adequately responded to methotrexate
Methotrexate^†^ (Methotrexate LPF^®^) (Trexall^®^) | Hospira, Inc. Teva Pharmaceuticals USA (Barr Pharmaceuticals) | Symptomatic control of severe, recalcitrant, disabling psoriasis that is not adequately responsive to other forms of therapy; treatment of gestational choriocarcinoma, chorioadenomadestruens, and hydatidiform mole; prophylaxis and treatment of meningeal leukemia; used alone or in combination therapy in the treatment of breast cancer, epidermoidcarcinomas of the head and neck, advanced mycosis fungoides, lung cancer, and advanced-stage non-Hodgkin’s lymphomas; as combination therapy in prolongation of remission in nonmetastatic osteosarcoma; management of selected adults with severe, active rheumatoid arthritis, or children with active polyarticular juvenile rheumatoid arthritis who have had an insufficient therapeutic response to, or are intolerant of, an adequate trial of first-line therapy including full-dose nonsteroidal anti-inflammatory agents; trophoblastic neoplasms; acute lymphoblastic leukemia; meningeal leukemia; cutaneous T-cell lymphoma

FDA = Food and Drug Administration

* Drug name is the generic formulation, if available, or the developmental name as determined by the manufacturing company.

† Generic formulations commercially available.

Table 3 FDA-approved phototherapy with identified literature in this report

Modality | Description of Therapy | Example Models (Manufacturer)^*^ | FDA Indication^†^
NB-UVB | Exposure to UVB radiation ranging from 311 to 313 nm | DuaLight system (TheraLight™, Inc.) 3-series Phototherapy Cabinet (Daavlin Company) MultiClear XL (Curelight Ltd.) | UVB phototherapy for psoriasis, vitiligo, atopic dermatitis, and leukoderma
PUVA | Methoxypsoralen (8-MOP^®^) administered orally or topically 75–120 minutes prior to exposure to UVA radiation, followed by exposure to UVA radiation ranging from 320–400 nm | 8-MOP^®^ (ICN Pharmaceuticals, Inc.) DuaLight system (TheraLight™, Inc.) 3-series Phototherapy Cabinet (Daavlin Company) | 8-MOP^®^: For the symptomatic control of severe, recalcitrant, disabling psoriasis not adequately responsive to other forms of therapy and when the diagnosis has been supported by biopsy; to be administered in conjunction with long-wave ultraviolet radiation

8-MOP = 8-methoxypsoralenFDA = Food and Drug Administration; NB-UVB = narrowband ultraviolet B light; PUVA = psoralen plus ultraviolet A light

* Listed devices are intended to represent examples of currently available products. The list is not intended to be comprehensive.

† FDA indication as listed on the 510K preapproval documentation.

Biologic therapies for psoriasis use genetically engineered drugs that target specific steps involving T cells and cytokines (e.g., TNF-alpha and IL-23), which are important in the pathogenesis of psoriasis.4,5 Currently, three biologic TNF-alpha inhibitors (infliximab, etanercept, and adalimumab) and one anti-IL 12/23 agent (ustekinumab) have approval from the Food and Drug Administration (FDA) for psoriasis treatment. Although while writing this report alefacept was still on the U.S. market, this T-cell targeting agent has been voluntarily withdrawn from the U.S. market. Another T-cell targeting agent, efalizumab, was withdrawn from the U.S. market due to its potential risk of causing progressive multifocal leukoencephalopathy. Other biologic agents with similar mechanisms of action have FDA marketing approval, albeit not for the treatment of chronic plaque psoriasis (e.g., certolizumab pegol, golimumab, abatacept). While biologic treatments may represent a treatment option with fewer adverse effects, there are concerns about their higher costs versus nonbiologic systemic therapies. The estimated annual per-patient cost of biologic treatment ranges from $18,000 to $42,000 (based on the average wholesale price).14 This cost is in comparison with methotrexate, the most commonly prescribed nonbiologic systemic treatment for psoriasis worldwide, which costs approximately $1,200 per year.14

The American Academy of Dermatology has published guidelines for the treatment of psoriasis.4,11,13 As stated above, topical agents, or even targeted phototherapy, are effective therapies for limited disease. When treating patients for more extensive disease, there are no clear guidelines established for selecting first-line therapy, albeit the presence of concomitant psoriatic arthritis is an important determinant of treatment choice (often a TNF-alpha inhibitor with or without methotrexate).4 For patients with widespread disease, guidelines suggest therapy with either biologic or nonbiologic systemic agents or phototherapy with ultraviolet B (UVB) or with psoralen plus ultraviolet A (PUVA) therapy.4 There are few direct comparative trials either within or between biologic and nonbiologic classes directly comparing effectiveness.15–17 Recently, a trial that compared two biologic agents concluded a difference in efficacy, suggesting heterogeneity within the class and indicating drug comparisons may be preferred over class comparisons.15 Currently, guidelines suggest that clinicians balance individual patient characteristics with the reported adverse events and previously used treatment modalities when making therapeutic decisions.

In 2008, Schmitt and colleagues published a meta-analysis analyzing the efficacy and tolerability of biologic and nonbiologic systemic agents for moderate-to-severe plaque psoriasis.18 This study examined all randomized controlled trials published before January 2008 that enrolled greater than 50 patients with moderate-to-severe plaque psoriasis. Based on the results of their meta-analysis, the authors concluded that the efficacy of systemic agents approved for moderate-to-severe psoriasis likely differ considerably between biologic and nonbiologic agents, as well as within the two classes. One of the main research gaps identified in this meta-analysis was the lack of comparative effectiveness and safety data for biologic versus nonbiologic systemic treatments for moderate-to-severe plaque psoriasis. Since the completion of this systematic review, the first head-to-head trial comparing a biologic with a nonbiologic systemic treatment has been published.17 Additionally, comparative data from nonrandomized studies likely exist, although not sought or evaluated by Schmitt and colleagues.18 Moreover, the efficacy of phototherapy was not addressed in this meta-analysis.

To date, no comparative effectiveness review comparing the effectiveness and safety of biologic systemic with nonbiologic systemic treatment options or phototherapy for chronic plaque psoriasis has been completed. Throughout the report we refer to three “classes” of therapy: biologics, nonbiologics, and phototherapy, which is consistent with national practice guidelines. We realize the possible heterogeneity within each class, namely the biologics, and therefore do not make between class comparisons rather limit comparisons with the individual drug level. Comparisons of drugs within each class were beyond the scope of this report. Please see the glossary in Appendix I for a listing of drugs considered within each class.

## Objectives

To perform a comparative effectiveness review examining the benefits and harms of biologic systemic agents compared with nonbiologic systemic agents or phototherapy in patients with chronic plaque psoriasis. The analytic framework is presented in Figure 1.

## Key Questions^a^ a Key Question abbreviations: ALT = alanine aminotransferase; AST = aspartate aminotransferase; BMI = body mass index; BSA = body surface area; DLQI = Dermatology Life Quality Index; EQ-5D = EuroQol 5-Dimension™; GFR = glomerular filtration rate; HAQ-DI = Health Assessment Questionnaire Disability Index; HRQoL = health-related quality of life; MACE = major adverse cardiovascular event; PASI = Psoriasis Area and Severity Index; PGA = Physician’s Global Assessment; SCr = serum creatinine; TCP = thrombocytopenia

Key Question 1. In patients with chronic plaque psoriasis, what is the comparative effectiveness of systemic biologic agents and systemic nonbiologic agents (between-class comparisons on an individual drug level) or phototherapy when evaluating intermediate (plaque BSA measurement, PASI, Patient’s Assessment of Global Improvement, PGA, and individual symptom improvement) and final health outcomes [mortality, HRQoL (e.g., DLQI, HAQ-DI, EQ-5D) and other patient-reported outcomes, MACE, diabetes, and psychological comorbidities (e.g., depression, suicide)]?

Key Question 2. In patients with chronic plaque psoriasis, what is the comparative safety of systemic biologic agents and systemic nonbiologic agents (between-class comparisons on an individual drug level) or phototherapy (hepatotoxicity [e.g., AST, ALT], nephrotoxicity [e.g., SCr, GFR], hematologic toxicity [e.g., TCP, anemia, neutropenia], hypertension, alteration in metabolic parameters [e.g., glucose, lipids, weight, BMI, thyroid function], injection site reaction, malignancy, infection, and study withdrawal)?

Key Question 3. In patients with chronic plaque psoriasis treated with systemic biologic therapy, systemic nonbiologic therapy, or phototherapy, which patient or disease characteristics (e.g., age, gender, race, weight, smoking status, psoriasis severity, presence or absence of concomitant psoriatic arthritis, disease duration, baseline disease severity, affected BSA, disease location, number and type of previous treatments, failure of previous treatments and presence of neutralizing antibodies) affect intermediate and final outcomes?

## Analytic Framework

Figure 1 Analytic framework

ALT = alanine aminotransferase; AST = aspartate aminotransferase; BMI = body mass index; BSA = body surface area; DLQI = Dermatology Life Quality Index; EQ-5D = EuroQol 5-Dimension™; GFR = glomerular filtration rate; HAQ-DI = Health Assessment Questionnaire Disability Index; HRQoL = health-related quality of life; KQ = Key Question; MACE = major adverse cardiovascular events; PASI = Psoriasis Area and Severity Index; PGA = physician’s global assessment; SCr = serum creatinine; TCP = thrombocytopenia

This analytic framework figure is intended as an overview only. The links between the use of an intervention in a population and outcomes are described. The population includes patients suffering from chronic plaque psoriasis. The intervention of interest is systemic biologic agents compared to either systemic nonbiologic agents or phototherapy. The outcomes are separated into adverse events, intermediate outcomes, and final health outcomes. The adverse events of note include hepatotoxicity (e.g., AST, ALT), nephrotoxicity (e.g., Scr, GFR), hematologic toxicity (e.g., TCP, anemia, neutropenia), hypertension, alterations in metabolic parameters (e.g., glucose, lipids, weight, BMI, thyroid function), injection site reactions, malignancy, infection and study withdrawal. The intermediate outcomes are plaque BSA measurement, PASI score, Patient’s Assessment of Global Improvement, PGA, and individual symptom improvement. The final health outcomes are mortality, HRQoL (e.g., DLQI, HAQ-DI, and EQ-5D) and other patient reported outcomes, MACE, diabetes and psychological comorbidities (e.g., depression, suicide).