# Peer Reviewers

Jerry Bagel, M.D., FAAD

Psoriasis Treatment Center of Central New Jersey

Hightstown, NJ

Andrew Blauvelt, M.D.

Professor, Department of Dermatology

Oregon Health & Science University

Chief, Dermatology Service

Veterans Affairs Medical Center

Portland, OR

Lisa Kugelman, M.D.

Hartford Dermatology Associates

Clinical Faculty, Department of Dermatology, Yale University

Clinical Faculty, University of Connecticut School of Medicine

Jean-Hilaire Saurat, M.D.

Department of Dermatology

University of Geneva

Geneva, Switzerland

Peter Wolf, M.D.

Professor of Medicine

Department of Dermatology, Research Unit for Photodermatology

Medical University of Graz

Graz, Austria