# Key Informants and Technical Expert Panel

Bruce F. Bebo, Jr., Ph.D.

Director of Research and Medical Programs

National Psoriasis Foundation

Portland, OR

Andrew Blauvelt, M.D.

Professor, Department of Dermatology

Oregon Health & Science University

Chief, Dermatology Service

Veterans Affairs Medical Center

Portland, OR

Joel M. Gelfand, M.D., M.S.C.E.

Medical Director, Clinical Studies Unit

Assistant Professor of Dermatology

Associate Scholar, Center for Clinical

Epidemiology and Biostatistics

University of Pennsylvania

Kenneth P. Grossman, MD

Associate Company Medical Director

General Electric Company

Lisa Kugelman, M.D.

Hartford Dermatology Associates

Clinical Faculty, Department of Dermatology, Yale University

Clinical Faculty, University of Connecticut School of Medicine