# Discussion

Patients and health care providers encounter several important considerations when evaluating therapeutic options in the treatment of chronic plaque psoriasis. Despite being studied in comparison with placebo, biologic systemic agents have infrequently been compared directly with nonbiologic systemic therapies or phototherapy. Our literature review yielded only five randomized controlled trials (RCTs) and two observational studies directly comparing systemic biologics versus systemic nonbiologics and no RCTs and three observational study directly comparing systemic biologics and phototherapy. Overall, the quality of the studies was either good or fair, with a few rated as having poor quality. However, most often only one trial or observational study was available for a given comparison and outcome, and the majority of comparative studies were observational in nature and did not account for confounding. Together, these factors precluded the ability to statistically pool data. Therefore, a qualitative synthesis of the data was presented. A summary of the results with low, moderate, or high strength of evidence can be found in Table 11. Individual strength of evidence ratings per comparison can be found in Appendix G. None of the comparisons with phototherapies can be found in the table since there was insufficient evidence regardless of the comparison or outcome being evaluated. Although there are some comparisons that have been rated with low or moderate strength of evidence, given the current literature base there is insufficient evidence as a whole to determine the comparative effectiveness of systemic biologic agents compared with either systemic nonbiolgic agents or phototherapy, on an individual drug level, in patients with chronic plaque psoriasis.

Table 11 Summary of findings for the comparison of systemic biologic agents versus systemic nonbiologic agents

Comparison | Outcome^*^ | Type and Number of Studies | Conclusion | SOE
Adalimumab versus methotrexate | HRQoL | 1 RCT35 1 OBS28 | Adalimumab improves a patient’s HRQoL compared with methotrexate. | L
Adalimumab versus methotrexate | PASI | 1 RCT17 1 OBS28 | Adalimumab improves a patient’s PASI compared with methotrexate. | L
Adalimumab versus methotrexate | PGA | 1 RCT17 1 OBS28 | Adalimumab increases the number of patients achieving a PGA of “clear” or “minimal” compared with methotrexate. | L
Adalimumab versus methotrexate | Patient’s assessment of disease severity | 1 RCT35 | Adalimumab improves a patient’s assessment of disease severity compared with methotrexate. | L
Adalimumab versus methotrexate | Pain | 1 RCT35 | Adalimumab reduces a patient’s pain compared with methotrexate. | L
Adalimumab versus methotrexate | Pruritus | 1 RCT35 | Adalimumab reduces a patient’s pruritus compared with methotrexate. | L
Adalimumab versus methotrexate | Infection | 1 RCT17 | Infection rates do not differ between adalimumab and methotrexate. | L
Etanercept versus acitretin | PASI | 3 RCT22–24 | Etanercept improves a patient’s PASI compared with acitretin. | M
Infliximab versus methotrexate | HRQoL | 1 RCT21 | Infliximab improves a patient’s HRQoL compared with methotrexate. | L
Infliximab versus methotrexate | PASI | 1 RCT21 1 OBS26 | Infliximab improves a patient’s PASI compared with methotrexate. | L
Infliximab versus methotrexate | PGA | 1 RCT21 | Infliximab increases the number of patients achieving a PGA of “clear” or “minimal” compared with methotrexate. | L
Ustekinumab versus methotrexate | PGA | 1 OBS28 | Ustekinumab increases the number of patients achieving a PGA of “clear” or “minimal” compared with methotrexate. | L

HRQoL = health related quality of life; L = low; M = moderate; OBS = observational study; PASI = Psoriasis Area and Severity Index; PGA = Physician’s Global Assessment; RCT = randomized controlled trial; SOE = strength of evidence

* Outcomes with an insufficient strength of evidence are not listed in this table.

In the evaluation of systemic biologics versus systemic nonbiologics or phototherapy for final and intermediate health outcomes (Key Question 1), the use of the biologics adalimumab, etanercept, infliximab, and ustekinumab resulted in favorable outcomes when compared with individual nonbiologic agents (Table 11). However, we could not determine the comparative effectiveness of these therapies with regard to final health outcomes other than health-related quality of life (HRQoL), due to lack of evaluation in the included literature. We could not determine the comparative efficacy between other available biologics such as alefacept and systemic nonbiologic agents or between systemic biologic agents and phototherapy on any of the final or intermediate outcomes. This was due to either a lack of existing literature or a lack of direct statistical comparison between those agents.

The comparison of adalimumab with methotrexate, although based on a single RCT and observational study, had the most outcomes evaluated, although most were intermediate outcomes and all were based on low strength of evidence (Table 11).17,28 HRQoL was measured using both the dermatology life quality index (DLQI) and EuroQol 5-Dimension™ (EQ-5D) scales, with both showing favorable improvement in patients treated with adalimumab at 16 weeks. Changes seen in both treatment arms, however, can be considered clinically meaningful based on established minimally important differences of 2.3 to 5.7 for the DLQI, 0.09 to 0.22 for the EQ-5D index score, and 3.82 to 8.43 for the EQ-5D visual analogue scale (VAS).40 It is not surprising that HRQoL improved in those treated with adalimumab, as Psoriasis Area and Severity Index (PASI) was also significantly improved compared with methotrexate at 16 weeks, including complete clearance. Time to PASI 75 was also significantly shorter in adalimumab treated patients (28 versus 84 days). Other intermediate outcomes including Physician’s Global Assessment (PGA), patient assessment of disease severity, and individual symptoms of pain and pruritus were also improved in patients treated with adalimumab.

Compared with acitretin, three RCTs showed that etanercept improved a patient’s PASI with moderate strength of evidence.22–24 Both PASI 50 and PASI 75 were evaluated and showed favorable improvement in patients treated with etanercept at 24 weeks.

Compared with methotrexate, one observational study suggested that a higher proportion of patients treated with ustekinumab had a PGA of “clear” or “minimal”, based on an analysis adjusted for confounding.28

Compared with methotrexate, one RCT showed that infliximab improved a patient’s HRQoL, based on low strength of evidence. Three scales were used to measure HRQoL in this trial, DLQI, EQ-5D, and Short Form-36 Health Survey (SF-36) mental (MCS) and physical (PCS) and all showed favorable improvements in the infliximab treated patients at 16 weeks. Changes seen in both treatment arms, however, can be considered clinically meaningful based on established minimally important differences as previously reported, with addition of the SF-36 in which a change of 2.5 to 3.9 in the PCS and 4 to 6 in the MCS can be considered clinically important.40 Other intermediate outcomes including PASI and PGA were also improved in patients treated with infliximab, each based on low strength evidence.

We evaluated systemic biologics versus systemic nonbiologics or phototherapy for safety or tolerability outcomes (Key Question 2). All three classes of therapy are associated with known harms that are clearly defined within clinical practice guidelines.4,11,41 Some harms, such as changes in weight or the lipid profile may surface in the shorter term while others such as malignancy and infection would require much longer followup to accurately capture the risk. Furthermore, some toxicity can be cumulative, such as hepatic toxicity associated with methotrexate or nephrotoxicity associated with cyclosporine and would also require long term followup to accurately describe. Unfortunately, the longest followup period amongst included studies in which harms were reported was six months, although this was a rare exception. Most studies concluded at 12 to 16 weeks, which is unlikely to be of sufficient length for all important harms evaluated.

Based on the current literature base directly comparing biologics with nonbiologics or phototherapy, we were unable to determine comparative safety of these therapies due to paucity of data and in most cases a complete lack of direct comparative data. Although one observational study reported weight changes in patients taking methotrexate, etanercept, or infliximab, between drug comparisons were not made therefore we were unable to determine if the differences within arms were significantly different across drug therapies. Of all outcomes evaluated, there was a low strength of evidence that the rate of infection was not significantly different between the biologic agent adalimumab and the nonbiolgic agent methotrexate (Table 11). In this one RCT, authors stated that none of the infections were classified as serious, although further details were not specified.17

Key Question 3 aimed to evaluate patient and disease characteristics that modify outcomes when comparing systemic biologics, nonbiologics, and phototherapy. Important factors in selecting appropriate therapy include baseline patient characteristics as these will directly influence the safety and efficacy of chosen agents. Another key decisional uncertainty is the disease characteristics that are associated with either improved or worsen outcomes. However, there was a paucity of literature that provided insight on the relationship between patient and disease characteristics with final or intermediate health outcomes in patients treated with biologics compared with nonbiologics or phototherapy. Only one subgroup analysis from a RCT met our inclusion criteria. Two observational studies evaluated relationships between patient characteristic and outcomes although neither controlled for confounding and therefore cannot be used to draw conclusions.

Based on a post-hoc analysis of the randomized controlled comparative study of adalimumab versus methotrexate versus placebo in patients with psoriasis (CHAMPION) trial, data suggest that as disease severity improves, so does a patient’s HRQoL. The mean change in DLQI at 16 weeks was greatest for patients who achieved at least a PASI improvement of 75 percent (−9.5±5.8) while the mean change in DLQI was lowest for patients who achieved a PASI improvement of less than 25 percent (−0.7±4.7). In a RCT that compared the efficacy and safety of adalimumab versus placebo in patients with moderate to severe plaque psoriasis, investigators sought to correlate various measures of HRQoL to clinical outcomes.40 DLQI was moderately correlated with PASI (r=0.69, p<0.001).40 Data from this RCT also suggest that the minimal clinically important difference for the DLQI ranges from a change of 2.3 to 5.7.^40^ Based on these data, the changes in DLQI in patients achieving a PASI improvement of greater than 25 percent (−4.2 to −9.5) from the CHAMPION subgroup analysis can be considered clinically important improvements.

There were no previously conducted traditional meta-analyses identified by our literature search that addressed similar comparisons and research questions as this report. One mixed-treatment comparison that evaluated PASI 50, PASI 75, and PASI 90 suggested that the probability of achieving any of the three PASIs was highest for infliximab, followed by adalimumab, etanercept, methotrexate, cyclosporine, efalizumab, alefacept, and finally supportive care.34

## Applicability

Applicability assessments for individual studies can be found in Appendix H. Our literature base is most applicable to patients with more advanced chronic plaque psoriasis and is not applicable to milder forms. Five of the seven studies that directly compared biologics and nonbiologics required patients to have moderate to severe plaque psoriasis for enrollment, and in these studies the baseline mean PASI ranged from 10.4 to 26.3. In the remaining two studies, although moderate to severe plaque psoriasis was not an explicit inclusion criterion, the mean PASI at baseline for one study was consistent with the other studies and ranged from 8.2 to 18.8 whereas the other study did not report PASI at baseline. Only one of these seven studies was conducted in the United States and therefore the overall literature may not reflect local clinical practice. The majority of patients evaluated were not naïve to psoriasis treatment. All interventions evaluated in these studies are currently approved by the Food and Drug Administration and were at doses approved for chronic plaque psoriasis, therefore are relevant to treatment practice in the U.S. Four of seven studies evaluated final health outcomes and were generally not sufficient in length to adequately evaluate such outcomes, with exception of HRQoL. The followup in these studies ranged from 12 to 26 weeks. Alternatively, for intermediate outcomes, studies were sufficient in length to evaluate such outcomes with two exceptions. One study had a short followup period and the second was cross-sectional in design. Last, we did not consider studies long enough to accurately capture outcomes such as infection or malignancy. Otherwise, studies provide short term data about outcomes and in some cases this may not be sufficient to understand comparative safety, as is the case with methotrexate or cyclosporine where toxicities are cumulative.

Three observational studies directly compared biologics and phototherapy where moderate to severe plaque psoriasis was not an explicit inclusion criteria. However, the mean PASI at baseline was consistent with the other studies and ranged from 15.0 to 22.3.Therefore the literature reflects patients with more advanced chronic plaque psoriasis and is not applicable to mild forms. Two of the three studies were conducted outside of the United States and therefore the overall literature may not reflect clinical practice. The majority of patient in these studies were not naïve to treatment. The evaluated interventions are available for use in the United States but because phototherapy regimens are specifically tailored to patient characteristics we cannot comment whether regimens used in the study were sufficient or not. Only one final health outcome was evaluated and of the intermediate outcomes the duration of followup ranged from10.3 to 32 weeks. Adverse events were not evaluated in these studies.

## Research Gaps and Future Research Needs

In the treatment of chronic plaque psoriasis with biologic systemic agents, nonbiologic systemic agents and phototherapy, there are several avenues for future research. Current literature directly comparing biologic systemic agents versus nonbiologic systemic agents or phototherapy is limited. In total, only five RCTs comparing a biologic with a nonbiologic are included in this report, any no RCTs comparing a biologic with phototherapy were identified. Therefore, the most important area of future research is additional RCTs or large observational studies and registries that directly compare individual drugs/interventions from the three treatment modalities including systemic biologic, systemic nonbiolgic, or phototherapy. If a greater number of trials are conducted, meta-analytic techniques can be used to assess direct comparisons. Presently, the literature base is too scarce to conduct such an analysis. Future analyses using indirect comparisons may also help to supplement lack of direct comparative data.

Future trials evaluating biologic versus nonbiologic systemic agents or phototherapy should be adequately powered to assess final health outcomes that are important to decision makers, such as mortality, major adverse cardiovascular events, and psychological outcomes. This would likely require longer duration trials and larger sample sizes compared with the current literature base. Since the longest study was 32 weeks in duration, only short term outcome assessment was possible. Additional consideration of factors such as convenience of therapy should be weighed against these outcomes in future decision-making. A similar opportunity arises with harms, as even in the current literature base harms were rarely evaluated and if they were reported the frequency was rare and often trials were not of sufficient duration to adequately capture such risks.

Future research should be designed to determine if there are specific disease or patient factors that modify intermediate, final and adverse health outcomes when comparing biologics, nonbiologics, and phototherapy. Current research is too scarce to adequately assess the impact of patient or disease factors on these outcomes. Future studies should include a population more generalizable to the U.S. The majority of included studies (11 of 14 studies) were conducted in other countries, where clinical practice may not reflect practice within the U.S.