# Abbreviations

ALT: aspartate aminotransferase
AST: alanine aminotransferase
BMI: body mass index
BSA: body surface area
CI: confidence interval
DLQI: dermatology life quality index
EQ-5D: EuroQol 5-Dimension™
Kg: kilogram
Kg/m^2^: ilogram per meter squared
HRQoL: health-related quality of life
MACE: major adverse cardiovascular events
NB-UVB: narrowband-ultraviolet B
NR: not reported
RCT: randomized controlled trial
PASI: Psoriasis Area and Severity Index
PGA: Physician’s Global Assessment
PsA: psoriatic arthritis
PSSQ: Psoriasis Subject Satisfaction Questionnaire
PUVA: psoralen plus ultraviolet A
SCr: serum creatinine
SF-36: Short Form-36 Health Survey
SGA: Subject Global Assessment
TCP: thrombocytopenia
TNF: tumor necrosis factor
ULN: upper limit of normal
VAS: visual analogue scale
8-MOP: 8-methoxypsoralen